# Methods

## Literature Search Strategy

The topic of hormone replacement therapy and breast cancer was searched in the MEDLINE database from 1992 to January 2000. Full search strings are listed in Appendix 1. Since this review is an update, we did not review all prior studies but did want to overlap with some of the literature previously reviewed by the second Task Force. We also thought that the more recent studies would provide the most valid and reliable evaluation of HRT use and breast cancer risk, given changes in clinical practice, and improved knowledge of important BCA risk factors and potential confounders of the relationship between HRT and BCA. Criteria for inclusion in the systematic review were that the study was conducted in postmenopausal women and that it was in the English language or in a key non-English journal. We included meta-analyses, randomized controlled trials, observational cohort studies, and case-control studies published between 1992 and 2000, if they reported incidence, mortality, pathology, stage, or mammography pattern. MEDLINE updates were conducted monthly, and all abstracts were reviewed by 2 investigators to identify papers for full-text review. Editorials, letters, and reviews were also evaluated to ensure that no key papers were missed in the original MEDLINE search. Appendix 2 summarizes the results of the literature review.

## Literature Synthesis and Preparation of Systematic Evidence Review

Study data were abstracted onto data collection forms that were prepared at the beginning of the review. A difficulty in interpreting this literature is that analyses and results are reported differently among the studies. Most studies report point estimates comparing “ever” to “never” or non-use of HRT. However, some report their findings only as current use or after a specific duration of use. These are important differences to note, since some studies have identified elevated risks only in association with current use (as opposed to ever use). Also, ever use and current use may reflect a broad range of duration, from days to years. When possible, we differentiate these findings on the tables and in the text of this report. Hormone use was classified in each study as unopposed estrogen (ERT) or estrogen plus progesterone (CHRT) when it was specified. When the type of estrogen or progestin therapy was not specified, or the data were analyzed or reported together, exposure was categorized as HRT.

The most appropriate method of evaluating the relationship between HRT and BCA is a randomized, controlled trial. However, only 1 trial has been conducted. This trial ^26^ is older, involved high dose estrogen therapy, and is limited in size (168) and generalizability, and thus contributes little to the evidence and will not be discussed in this review. Therefore, this review almost entirely involves observational studies, which are limited by lack of randomization among women taking or not taking HRT.

Among the observational studies evaluating the relationship between HRT and breast cancer, cohort studies are methodologically stronger since they assess exposure prior to the onset of disease, and are not as dependent on the recall of hormone use as case-control studies. In addition, although there are 2 case-control studies of good quality, case-control studies are limited because some patients with disease refuse to participate, and because of the frequent inability to evaluate patients with severe disease or those who have died. Women who have died of BCA or who have metastatic disease may have had different HRT exposures, which might bias the results of the study. In addition, case-control studies are prone toward recall bias, where cases remember or report exposures differently than controls. In this review, therefore, we assign more importance to the results from cohort studies. In ranking the quality of both cohort and case-control studies, we give significant weight to adequate control of potential breast cancer risk factors because of known differences among HRT and non-HRT users that might influence breast cancer risk independent of HRT use. The methods of evaluating study quality were created by the current US Preventive Services Task Force ^27^ and are described in Appendix 3. Meta-analyses dating from 1988 were all reviewed and the data are displayed in Table 1.

Table 1. Incidence Meta-Analyses

Author, Journal, Date | Methods | Ever/Never Use | Current/Never | Long-term Use | Comments
| | RR (95% CI) | RR (95% CI) | RR (95% CI)
Armstrong '88 | Data from 16 published case-control studies | 1.01 (0.95–1.08)
Dupont & Page '91 | case control | 1.07 (1.0–1.15) | | | Dose 1.25 mg RR 1.07 (0.99–1.2)
| 10 cohort | | | | Prior benign breast disease
| | | | | 1.16 (0.89–1.5)
Grady '92 | 24 case control | 1.01 (0.97–1.05) | | (1.04–1.51)
| 10 cohort | | | for use ≥ 8 yrs.
| 1 clinical trial
Sillero-Arenas '92 | 23 case control | 1.06 (1.0– 1.12) | 1.23 (1.12–1.35) | (1.07–1.42)
| 13 Cohort | | | for use ≥ 12yrs., not increased until 12 yrs.
| 1 clinical trial
Colditz '93 | 31 case control | 1.02 (0.93–1.12) | 1.40 (1.2–1.63) | ≥10 1.23 (1.08–1.40) | No consistent relationship with time since first use
| | | | ≥15 1.29 (1.04–1.6) | No relationship with dose
| | | | ≥20 1.51 (0.98–2.34) | No relationship with family history or benign breast disease
Steinberg '94 | 16 case control | 1.0 | | For each year >5 yrs. RR increased by 0.015 (.004–0.021) | Evaluated relationship with family history and found significant increase (RR 3.4 95% CI 2.0–6.0)
| | | | Highest risk 15 yrs. | No association with benign breast disease
| | | | 1.3 (1.2–1.6)
Hemminki, '97 | 22 randomized controlled trials of ERT/CHRT reviewed. Data derived from 9 in which BCA incidence was reported | 0.85 (0.38–1.89)
Collaborative Group on Hormonal Factors in Breast Cancer '97 | 51 case control studies | 1.14 (p≤.001) | (p≤.001) | >5yrs. | Interaction with BMI
| 52,705 with breast cancer | | Current or within 1–4 years previously | (1.21–1.49) | No significant increase risk in past users
| 108,411 without breast cancer | | 1.023 (1.011–1.036) for each year of use | | Current = ≤ 12 months
| Main analyses based on 53,865 women with known age at menopause. | | | | *Overall excess due to localized disease
| | | | | Large deficit advanced disease in first 5 years after beginning HRT