# Introduction

In this systematic evidence review, we evaluate data on the relationship between the use of postmenopausal hormone replacement therapy (HRT) and the risk of breast cancer (BCA). This report is an update of the second US Preventive Services Task Force report, and therefore primarily reviews literature from the last 8 years to update the results of prior analyses evaluating this relationship, as well as the role of postmenopausal progesterone, in breast cancer development and mortality. The context of this review is in the overall evaluation of postmenopausal hormone replacement therapy as chemoprophylaxis for chronic conditions. The results from this report will be used as part of an overall report on the risks and benefits of hormone replacement therapy for postmenopausal women.

## Background

Hormone replacement therapy is used in the United States and worldwide to treat symptoms of menopause and to prevent chronic conditions such as osteoporosis. It is one of the most commonly prescribed drugs in the United States; a recent survey in the United States of postmenopausal women ages 50 to 75 showed that nearly 38% of women were currently using estrogen or hormone replacement therapy (58.7% of those with prior hysterectomy and 19.6% without hysterectomy). ^1^ A major and as yet unanswered clinical question is whether hormone replacement therapy increases a woman's risk of breast cancer. This issue is a critical one because the use of HRT is prevalent and because breast cancer is a relatively common disease, so that even a small increase in breast cancer in association with hormone use could significantly influence public health.

The importance of endogenous estrogen in the development of breast cancer has been evaluated and confirmed in multiple studies of differing methodologies. Studies in animals have shown that breast cancer can be induced by the administration of estrogen. ^2^ Among humans, some studies have shown that women with increased levels of circulating estrogen are at higher risk for the subsequent development of breast cancer. ^3–6^ Other studies have had conflicting findings, ^7^ and some have shown this relationship in postmenopausal women only. ^8^

Reproductive events are important risk factors for breast cancer. Those shown to increase risk include early menarche ^9^ and late menopause, ^10^ both of which prolong exposure to higher levels of estrogen as well as other reproductive hormones. Other reproductive experiences, such as late age at first pregnancy and nulliparity, increase breast cancer risk. ^11^ Oopherectomy among premenopausal women is protective against breast cancer, ^12^ possibly because of reduced exposure to estrogen. Other risk factors also suggest an important role for estrogen in BCA development. In postmenopausal women, obesity, which correlates with increased estrogen levels, is also associated with an increased risk of BCA. ^12^ Recent studies have also shown that increased bone density, possibly a reflection of lifetime estrogen exposure, is associated with increased rates of breast cancer. ^13^ Finally, age-adjusted rates of increase in breast cancer incidence slow at menopause when estrogen levels fall. ^12^

Also supporting the role of estrogen in the development of breast cancer are convincing data showing that tamoxifen, an estrogen receptor modulator that has antagonistic effects in the breast, reduces recurrence rates of breast cancer among women who have had breast cancer. ^14^ In addition, one large US study has shown that tamoxifen reduced the development of incident breast cancer among women at higher than average risk for its development. ^15^

In association with reproductive events, significant changes in progesterone levels (as well as other hormones) occur and may also influence breast cancer development. Progesterone alone or acting synergistically with estrogen regulates breast epithelial cell proliferation during the normal menstrual cycle, ^16^ and hormone therapy that includes progesterone may increase the risk of breast cancer more than estrogen alone. ^17^ In addition, when BCA does occur, the presence or absence of progesterone receptors on breast tumors is associated with prognosis. ^18,^ ^19^ These observations and concepts, as well as earlier epidemiologic data, ^17,^ ^20^ raise concerns that progesterone may also be important in the development of breast cancer. However, exposure to endogenous and/or exogenous progesterone has been less frequently evaluated in epidemiologic, serologic, and clinical studies.

The clinical and observational data suggesting a relationship between endogenous estrogen exposure and the development and etiology of breast cancer have led to concerns about the use of exogenous noncontraceptive estrogen and breast cancer risk. A number of studies have evaluated this relationship, and the findings have been mixed. An important limitation of many past studies is that few have addressed the role of combination estrogen and progesterone therapy in the development of breast cancer. The current standard of practice is for progesterone to be prescribed with estrogen for all women with an intact uterus to prevent the development of endometrial hyperplasia and/or malignancy. However, because use of progesterone in association with estrogen is a relatively recent practice, few epidemiologic studies have evaluated the relationship of progesterone and/or the combination of estrogen and progestins to breast cancer risk. Several studies suggest elevated risks associated with progesterone, but these often have wide confidence intervals and lack statistical significance. ^17,^ ^20^ Fortunately, recent studies have evaluated risks associated with combination therapy, and these will be reviewed in this report. ^21,^ ^22^

Several important questions regarding hormone replacement therapy and breast cancer risk among postmenopausal women have not yet been answered in the medical literature. These questions primarily relate to risks associated with current, short-term and long-term hormone use, as well as risks associated with combination therapy involving estrogen and progesterone. These questions are outlined in detail below, and this report systematically reviews the recent literature evaluating these risks.

## Recommendations of Second Task Force

In the 1996 edition of the US Preventive Services Task Force Guide to Clinical Preventive Services, ^23^ the association of hormone replacement therapy and breast cancer was summarized after evaluating data from more than 40 observational studies and 6 meta-analyses. Broadly, the summary findings found that, compared to the risk for women who have never taken hormones, the risk of breast cancer among current users and women who had used estrogen long-term was increased by approximately 20–50%. The USPSTF also found little evidence that adding progestins to estrogen influenced the risk of breast cancer associated with hormone replacement therapy. ^23^ Since 1995, several important studies with data from large cohorts have provided particularly important information about this association.

## Analytic Framework and Key Questions

The analytic frameworks in Figures 1 and 2 show the target population, interventions, and health outcome measures we examined for the overall question of the benefits and risks of postmenopausal HRT. Arrows 1 and 2 in Figure 2, and the analytic framework in Figure 3, correspond to issues of HRT and breast cancer specifically covered in this report. The key questions outlined in Figure 4 correspond to the numbered arrows in the analytic framework, and guided our literature review. We were concerned with HRT as chemoprophylaxis for chronic conditions rather than as a treatment for menopausal symptoms, and therefore focused on the use of either estrogen alone or estrogen combined with progesterone in healthy, postmenopausal women.

Figure 1. Potential Benefits of Hormone Replacement Therapy

Figure 2. Adverse Effects of Hormone Replacement Therapy

Figure 3. Hormone Replacement Therapy and Breast Cancer

Figure 4. Post-menopausal Hormone Replacement Therapy and Breast Cancer

1. Does exogenous estrogen or estrogen & progesterone increase the risk of fatal breast cancer?

a. Does HRT influence prognostic characteristics when breast cancer is diagnosed?

2. Does short-term exogenous estrogen increase the risk of breast cancer?

3. Does long-term exogenous estrogen increase the risk of breast cancer?

4. Does estrogen and progesterone increase the risk of breast cancer?

5. Is current use of either estrogen or combined hormone replacement therapy associated with increased risk of breast cancer?

6. Are there sub-populations of women at higher risk of breast cancer in association with hormone replacement therapy?

7. Does hormone replacement therapy change breast density on mammograms?

There are several critical key questions to consider when evaluating the research describing the role of exogenous estrogen or estrogen/progesterone in breast cancer development and prognosis. First, is either estrogen alone or estrogen with progesterone associated with a change in breast cancer mortality? Second, does short-term estrogen use increase the risk of breast cancer? The third question, which is most relevant to the use of estrogen to prevent chronic conditions, is whether long-term estrogen increases breast cancer risk. The fourth question, which reflects the current standard of practice, is whether the combination of estrogen and progesterone, either short-term or long-term, increases the risk of breast cancer. Fifth, is current use of estrogen or hormone replacement therapy associated with increased risk of breast cancer? Sixth, are there sub-populations of women who might be at increased risk of breast cancer when using HRT? Finally, because increased breast mammographic density is independently associated with an increase in breast cancer risk, ^24^ as well as with decreased accuracy of mammography, ^25^ does estrogen or estrogen/progestins change breast density?