# Appendix 4. Study Summaries

## Meta-analyses

More than 50 observational studies have evaluated the relationship between hormone replacement therapy (HRT) and breast cancer (BCA) incidence or mortality, and the majority have shown no statistically significant association, although several have had point estimates in either direction. This suggests that an association, if it does exist, is likely to be small, and that very large sample sizes may be needed to detect a small but potentially important association. In an effort to increase sample sizes (and thus power), 7 meta-analyses have evaluated the relationship between ever use of hormone replacement therapy and breast cancer using data derived from observational studies. Summary data from the 7 meta-analyses are displayed in Table 1, but only the six meta-analyses published between 1992-2000 are described in detail below. In addition, one meta-analysis combining data from 9 randomized controlled trials of estrogen replacement therapy (ERT) or combined hormone replacement therapy (CHRT) evaluated the risk of BCA associated with HRT. It is very difficult to interpret the results of meta-analyses combining data from observational studies because it is difficult to be certain of the quality of the data that were pooled in the meta-analyses. If the studies do not adequately control for confounding or use inappropriate controls, the summary estimates will be biased. After reviewing much of the literature pertaining to HRT and BCA risk, we found very few studies to be of high quality. Consequently, the results of meta-analyses combining studies of less than high quality should be interpreted cautiously.

Sillero-Arenas 1992 ^31^ : Twenty-seven published studies dating from 1971 through June 1990 were blindly reviewed for quality by 2 independent reviewers. Ever-use of HRT was associated with a summary relative risk of 1.06 (95% CI, 1.0–1.12). When only case-control studies were evaluated, the summary relative risk for ever use was 1.01 (95% CI, 0.95–1.08); for cohort studies it was 1.16 (95% CI,1.05–1.28). When duration was evaluated, there was no overall increase in BCA risk until after 12 years (RR 1.23; 95% CI, 1.07–1.42), and no dose-response relationship was identified.

Grady 1992 ^34^ : This analysis reviewed literature from 1970 through 1990 that evaluated the risk of BCA associated with HRT use and included 39 studies. The summary relative risk for ever use of HRT was 1.01 (95% CI, 0.97–1.05). The study identified no association with BCA risk and dose of HRT. To evaluate the risk associated with long-term use, the authors combined data from studies reporting 8 or more years of HRT use and calculated a summary relative risk of 1.3 (95% CI, 1.2–1.6). Because there were very few studies, there was no calculation of a summary risk for CHRT.

Colditz 1993 ^29^ : This study evaluated data from 31 studies and calculated a relative risk of 1.02 (95% CI, 0.93–1.12) for ever use. Current use was associated with increased risk of 40% (RR 1.40; 95% CI, 1.08–1.40). Combining data from 17 studies, Colditz observed no relation or trend between years of ERT and BCA risk. However, use for ≥10 years was associated with relative risk of 1.23 (95% CI, 1.08–1.40).

The overall relative risk associated with CHRT, based on 4 studies, was 1.13 (95% CI, 0.78–1.64). The risk associated with HRT use was also evaluated in women with a history of benign breast disease, and no relationship was identified. An interesting analysis also evaluated studies by geographic location and found that the summary relative risk of BCA from European studies was 1.34 (95% CI, 1.09–1.65) and from other countries 1.04 (95% CI,.98–1.09). The reason for different findings between the European and non-European studies is unclear. One possibility is that in Europe, synthetic estrogen is the predominant form of HRT and it is associated with higher circulating estrogen levels. ^29^ In other regions, natural conjugated estrogens are more commonly used. Another consideration is that European studies are often less well adjusted for known BCA confounders, which may result in higher risk estimates.

Steinberg 1994 ^32^ : This analysis used data from 16 case-control studies dating from 1976-1989. The summary relative risk was 1.0 for ever use of ERT. For women with any type of menopause, the risk associated with HRT did not increase until after 5 years, whereafter each year greater than 5 years increased the relative risk by 0.015 (95% CI, 0.004–0.021). Fifteen years of use was associated with increased risk of 30% (RR 1.3; 95% CI 1.2–1.6). This study also identified an interaction of HRT and positive family history (RR for HRT 3.4 among women with a positive family history, RR 1.5 among women without family history).

Collaborative Group on Hormonal Factors in Breast Cancer 1997 ^12^ : In 1997 the Collaborative Group reanalyzed approximately 90% of the worldwide epidemiologic evidence describing the relationship between HRT use and breast cancer. Of the 63 eligible studies, original data were contributed by 51 studies (49 published, 2 unpublished). Data were evaluated in a case-control format. Cases were defined as women with invasive breast cancer; controls were women without breast cancer. Information on tumor spread was available from 21 studies. Current use was defined as use at the time of BCA diagnosis or within one year.

There were many important epidemiologic findings in this study, and many known BCA risk factors were reaffirmed. One finding was that menopausal status was an important determinant of BCA risk, since postmenopausal women had a lower risk of BCA than premenopausal women of the same age and child-bearing pattern. Therefore, if menopausal status and age at menopause are not adequately evaluated in epidemiologic studies, there can be substantial confounding by these variables, since they are also associated with HRT use.

To deal with this issue, the main analyses of this study involved only postmenopausal women with known age at menopause and included 53,865 postmenopausal women (17,949 cases and 35,916 controls). The median age at diagnosis was 60 and the median year of diagnosis 1985. Thirty percent of the cases and 34% of the controls had used HRT at some time. For all studies combined, the odds ratio (OR) was 1.14 for ever use (p=0.00001). Among ever-users of HRT, there was increasing risk of BCA with increasing duration of use (p=0.003). The relative risk of BCA was 1.35 (95% CI, 1.21–1.49) for ≥ 5 years' use. In addition, the relative risk of BCA was elevated significantly among current users (RR 1.21), but not among past users.

The interaction between HRT use and several other risk factors was examined, and lower body mass index (BMI) and weight were shown to be associated with elevated risks among HRT users of ≥5 years duration. There was no increase in BCA risk in association with HRT among women ≥65 kg or with BMI ≥25.0 kg/m^z^. Tumor spread was reported in 54% of cases and ever-users were much more likely to have localized disease. Among current or recent users of HRT, the excess risk of BCA was confined to localized disease. Approximately 80% used preparations, mostly containing estrogen, and 12% used CHRT. No association was noted between type of HRT and BCA.

Hemminki 1997 ^35^ : This analysis used pooled data from 22 randomized controlled trials of estrogen therapy in studies evaluating outcomes such as bone density or lipids. It reported on breast cancer incidence among those randomized to receive HRT compared to those randomized to placebo. Of the 22 trials reviewed, 9 reported on rates of breast cancer among women randomized to hormone replacement therapy or placebo. Although these studies involved both ERT and CHRT, the data were combined and the estimated relative risk of incident breast cancer was 0.85 (95% CI, 0.38–1.89) comparing users to non-users. This study has several limitations, including a small number of women and events, relatively short-term HRT use, probable selection of women at lower than average risk of BCA for inclusion in HRT trials, and no evaluation for duration.

## Cohort Studies

We reviewed 16 cohort study reports from 10 cohorts and rated them in quality as good, fair, or poor, based on the following criteria: size and representativeness of the cohort, adequate assessment of HRT use, adequate assessment of potential breast cancer risk factors, and duration and completeness of follow-up.

The Nurses Health Study (NHS) 1995 ^20^ : The NHS is a cohort study of good quality involving nearly 70,000 postmenopausal nurses in the United States who were enrolled in 1976. Each woman initially completed a mailed questionnaire describing known or suspected risk factors for breast cancer with mail follow-up every 2 years. After 725,550 person-years of follow-up, 1,935 cases of newly diagnosed invasive BCA were identified. Follow-up of the cohort is 95% complete, and control for confounding factors fairly good, though no adjustment was made for alcohol use or body mass index in the multivariable analyses. The NHS is the only cohort study published in the last 5 years showing increased breast cancer incidence among current users of ERT (RR 1.36; 95% CI, 1.14–1.54), CHRT (RR 1.41; 95% CI, 1.15–1.74), and progesterone only (RR 2.24; 95% CI, 1.26–3.98). When this increased risk among current users was evaluated by duration of use, the study showed that the risk was increased after 5 years of use in women ages 55 to 64 (RR 1.54–1.7) and among all women after 10 or more years (RR 1.46 95% CI, 1.20–1.76). Past use of any duration was not associated with an increased risk of breast cancer. A prior evaluation of this cohort, published in 1990, indicated an interaction of hormone replacement therapy with alcohol use. ^57^ In the earlier report, the age-adjusted relative risk of breast cancer was 0.99 among women who did not drink alcohol and used HRT, and increased among current alcohol and HRT users (RR 1.56, 95% CI, 1.2–2.0). The authors did not report this association fully adjusted for other risk factors, and the association was not reviewed in their 1995 publication.

The Iowa Women's Health Study (IWHS)1999, 1997, 1995 ^36,^ ^65,^ ^94^ : This prospective cohort study of good quality was initiated in 1985. Women ages 55–69 with valid Iowa licenses were identified at random from the 1985 Iowa Department of Motor Vehicles registry. A 16-page questionnaire was sent to members of this population and returned by 41,386, who then became the cohort. The 16-page questionnaire was designed to address important risk factors for cardiovascular disease and cancer. The most recent publication from this cohort evaluating the risk of breast cancer associated with hormone replacement therapy ^36^ involves a mean follow-up time of 11 years and 371,471 person-years. A total of 1,520 incident breast malignancies were identified from follow-up questionnaires, the SEER Network Cancer Registry and the National Death Index. Overall, there was no association between ever use of hormone replacement therapy and breast cancer risk (RR use ≤ 5 years 1.07). However, when the findings were evaluated by type of breast cancer, favorable histology BCA accounted for 82 of the incident cancers and the relative risk was significantly elevated among those with ≤ 5 years of ever use (RR 1.81) and ≥ 5 years of ever use (RR 2.65). For favorable histology, current use of estrogen for fewer than 5 years was associated with a RR of 4.42 (95% CI, 2.0–9.76) and for more than 5 years with a RR of 2.63 (95% CI, 1.18–5.89). Current use of 5 or fewer years was also associated with a relative risk of invasive ductal or lobular carcinoma of 1.38 (95% CI, 1.03–1.85). The relative risks of invasive breast cancer with unfavorable prognosis and/or in situ breast cancer associated with ever use of estrogen or ever use of long-term estrogen were not increased. A limitation of this cohort study (or the publications to date) is that there is no analysis by type of hormone replacement therapy (CHRT versus ERT). A prior report from this cohort evaluated risk of breast cancer among women with and without a family history of breast cancer. The overall adjusted relative risk of breast cancer was 1.34 for current use of estrogen for 5 or fewer years (95% CI, 0.98–1.8). The risk of BCA in association with HRT was not increased among women with a family history of BCA.. ^65^ Another finding from this cohort was an elevated relative risk of breast cancer among women using hormone replacement therapy who used more than 5 grams of alcohol per day on average (RR ≥1.8). ^67^ No association was shown between HRT and breast cancer among women who were not using alcohol, suggesting biological effect modification.

National Health and Nutrition Examination Survey I (NHANES I) 1999 ^40^ : Between 1971 and 1974, 5,761 postmenopausal women representing various regions of the United States were interviewed and underwent a baseline examination. Every 4 years they received follow-up phone interviews. Hormone use was evaluated as ever/never use, with attempts to evaluate duration. Potential risk factors and confounders were well characterized except for alcohol use and benign breast disease. Breast cancer cases were identified by self-report and medical records, and pathology was reviewed at the National Cancer Institute. After an average of 12.7 years of follow-up (72,253 person years), 219 cases of breast cancer had occurred. The adjusted relative risk of ever versus never use of hormone replacement therapy was 0.8 (95% CI, 0.6–1.1). The adjusted relative risk for fewer than 3 years of use was 0.9 (95% CI, 0.6–1.4), for 3 to 6 years of use 0.5 (95% CI, 0.3–0.9), and for more than 10 years 0.8 (95% CI, 0.5–1.3). This is a good quality study; it is a nationally representative cohort with good assessment of confounding factors and good follow-up. Limitations are its relatively small size and lack of information on hormone composition.

Breast Cancer Detection Demonstration Project (BCDDP)2000, 1994 ^21,^ ^66,^ ^87^ : This was a large breast cancer detection screening trial performed in the United States. It included 46,355 postmenopausal women who were enrolled between 1973 and 1980, and followed for incident breast cancer for a median duration of 12.3 years (437,687 person-years). During follow-up, 2,082 cases of breast cancer were reported. Hormone use was characterized within the study by telephone interviews and mailed questionnaires. Ever use of ERT, CHRT, or estrogen and CHRT was not associated with an increased relative risk of breast cancer. Current use of ERT was associated with a relative risk of 1.1 (95% CI, 1.0–1.3), and current CHRT use with a relative risk of 1.4 (95% CI, 1.1–1.9). For both ERT and CHRT, the relative risk of breast cancer associated with hormones was elevated only among thinner women with body mass index of ≤ 24.4 kg/m2. Among lean women using ERT, the risk of breast cancer was elevated at 8–16 years and more than 16 years, with relative risks of 1.5 and 1.6, respectively, and positive for trend. There was no increase in BCA risk with use of ERT of any duration in women with BMI > 24.4 kg 1m^z^. Among CHRT users, the relative risk of breast cancer was elevated at 4 or more years of use at 2.0 (95% CI, 1.3–3.0); point estimates for CHRT use among heavier women were also evaluated (RR 1.3–1.5), but not statistically significant. The relative risk of breast cancer with ERT increased 0.03 (0.01–0.06) per year and for CHRT 0.12 (0.02–0.25) per year of use. This study is of good quality. It is an important study because it is one of the first studies to show a statistically significant increase in BCA in association with CHRT above that of ERT alone, though there have been elevated point estimates in other studies. This study is of good quality. Its results may be less generalizable than others because the women in the BCDDP were a higher BCA risk population.

A prior report ^87^ from this cohort indicated significant increases in in situ BCA in this cohort associated with ever use of both ERT (RR 1.4; 95% CI, 1.0–2.0) and CHRT (RR 2.3; 95% CI, 1.3–3.9). However, in the more recent publication, increased duration of ERT use in lean women increased the risk of both early-stage and late-stage invasive disease. Also, in the more recent report, there was no significant increase in risk of in situ cancer associated with either regimen.

Finally, a 1999 publication from this cohort reported mortality rates by duration of use among past and current HRT users. ^66^ Mortality was reduced among current users of < 12 years duration for both node-positive and node-negative BCA. Mortality was increased among node-negative (RR 1.8; 95% CI, 0.8–4.3) and node-positive (RR 4.4; 95% CI, 1.7–11.8) past users with ≥ 145 months duration of use. ^66^

Netherlands 1995 ^37^ : A prospective study of 62,573 women ages 55 to 69 was conducted in the Netherlands. The cohort was assembled in September 1986, and information on exogenous hormone use and other risk factors was collected by mail questionnaire. A computerized record linkage with the Dutch national database of pathology reports was used to ascertain cases. After adjustment for most important risk factors for breast cancer, the relative risk of ever use of hormone replacement therapy was 1.0. There were no associations with duration of use, years since first use, years since last use, or age at first use. A sub-analysis of this paper involved evaluating the interaction of oral contraceptive use and hormone replacement therapy use; no interaction or increased risk was identified. This study is of fair quality based on its population base, age of the cohort, and good follow-up, but had only fair evaluation of confounding factors.

Cancer Prevention Study 1996 ^64^ : This study evaluated deaths among a cohort of women enrolled in a cancer-prevention study. It enrolled 422,373 post-menopausal women in 1982 and followed them until December 1991. Breast cancer risk factors, comorbidity, and hormone use were evaluated at entry with a self-administered mailed questionnaire. Hormone use was characterized as ever, current, or former, and by duration of use, age at first use, and years since last use. Vital status was determined by phone queries utilizing volunteers and the National Death Index. Breast cancer deaths were defined as those with breast cancer as the underlying diagnosis. Within this cohort, the overall risk of breast cancer death among ever versus never users was reduced with a relative risk of 0.84 (95% CI, 0.75–0.94). Past versus never use of HRT was also associated with reduced risk of BCA death (RR 0.78; 95% CI, 0.68–0.89). When duration and risk of death were evaluated, there was not a significant duration effect. This study is of fair quality, based on its lack of information on participation, the use of self-administered questionnaires, and relatively short follow-up.

Finnish Cohort 1998 ^38^ : A prospective study of women born between 1923 and 1930 and living in Finland utilized data from a free mammography screening program between 1987 and 1990. The women were presumed to be menopausal because of their age. These 6,433 women were followed for 8 years (53,305 person years) for breast cancer or breast-cancer-related death using a national registry of hospital discharge data, death certificates, and the Finnish Cancer Registry. Estrogen exposure, comorbidity, and breast cancer risk factors were evaluated by a validated nurse-administered questionnaire, and estrogen use was characterized as ever, never, former, and current, although the formulation was not specified. After 8 years of follow-up, the relative risk of ever breast cancer associated with current hormone replacement therapy was 0.57 (95% CI, 0.27–1.20), and the risk associated with former use 0.94 (95% CI, 0.47–1.9). Duration of use and progesterone use were not evaluated in this study. The quality of the study is rated poor because of poor follow-up and failure to assess confounding factors.

Swedish Cohort 1996 ^46^ : This prospective cohort study of women in Upsala Health Care Region of Sweden followed 22,579 women who received hormone replacement therapy between 1977 and 1980 for an average of 13.2 years. The mean age of the participants was 54.5 years. Pharmacy records were used to characterize estrogen use by type, and a mailed questionnaire was sent to a random subset of women to ascertain risk factors for breast cancer. Breast cancer cases were identified by record-linkage to Swedish cancer and death registries. Within this cohort, after 13.2 years, 624 incident breast cancers and 102 deaths were identified. The standardized incidence ratio was 1.0, and there was no association with duration of use. The risk of death, which was also evaluated in this cohort and compared to a standard population, was reduced (SMR 0.72; 95% CI, 0.58–0.89). The quality of this study is poor based on poor control of confounding.

Saskatchewan Cohort 1994 ^41^ : This cohort study from Canada, which began in 1976, involved nearly 33,000 women ages 43 through 49 from Saskatchewan, and followed them through 1990. Evaluation of estrogen and progesterone exposure was based on review of a prescription database. This study showed an increased relative risk of breast cancer associated with ERT of 1.33 (95% CI, 1.11–1.59) and, when evaluated by duration, found ERT use for more than 36 months associated with a relative risk of 1.50 (95% CI, 1.06–2.13). No increase in relative risk was shown with ever use of progesterone only or with one year of CHRT. The significance of these findings is limited, however, because there was no adjustment for important breast cancer confounders in the analyses. Also, this is a very young cohort, and their menopausal status is unclear.

Kaiser Cohort 1996 ^62^ : This cohort study, conducted between 1969 and 1971 and involving women in the San Francisco Kaiser health maintenance organization, compared 245 women who had used HRT for 5 or more years with 232 age-matched non HRT users during 1969-1971. Exposure to HRT was based on prescription and medical records. Women were followed until December 1992 or death from BCA. The relative risk of death from BCA was 1.89 (95% CI, 0.43–8.36) among HRT users. However, because of uncertain and potentially biased selection of women for HRT use, lack of adjustment for reproductive risk factors, alcohol use, family history of BCA and benign breast disease, and possible misclassification of hormone use, the quality of the study is poor.

## Case-Control Studies

Between 1992 and 2000, 15 case-control studies were published. Fourteen of these evaluated hormone replacement therapy and breast cancer incidence; the other considered breast cancer mortality. Each of the case-control studies was ranked in quality (good, fair, or poor) by size, case ascertainment, population-based versus referral-based, response rates of cases and controls, control of confounding, and adequate and non-biased selection of controls. Each study will be discussed in order from highest to lowest quality.

Newcomb 1995 ^47^ : This population-based case-control study was conducted in Wisconsin, New Hampshire, Massachusetts, and Maine between April 1989 and December 1991. The cases were all women with newly diagnosed breast cancer, of which 98% were histologically confirmed. The women were interviewed within 8–21 months of diagnosis, and the response rate was 81%. The 3,130 cases were randomly matched to 3,698 controls by driver's license lists and Medicare files. Assessment of estrogen exposure was evaluated by phone interview, but the type of estrogen and dose were not evaluated. Recent use was defined as within 2 years of the BCA diagnosis (or index date), and hormone replacement therapy was defined as more than 3 months of consecutive use of estrogen, either with or without progesterone. Ever use of hormone replacement therapy was associated with an odds ratio of 1.05 (95% CI, 0.93–1.18). Former use of hormone replacement therapy had an odds ratio of 1.12 (95% CI, 0.98–1.29). There was no association with duration of HRT and breast cancer. There also was no association with use of CHRT and breast cancer (adjusted OR = 1.01). Finally, there were no interactions with other risk factors identified.

Stanford 1995 ^48^ : This population-based case-control study was conducted in King County, Washington, utilizing the SEER database and enrolling women ages 50 to 64 with newly-diagnosed breast cancer. The study enrolled 450 Caucasian women with invasive breast cancer and 87 women with in situ breast cancer. The controls were residents of King County ages 50 through 64 who were identified through random-digit dialing and matched within 5 years of age to the cases. Interviews were used to assess dates of estrogen use, as well as the duration, brand, and dose of estrogen, and progesterone use. Ever use of estrogen alone was associated with an odds ratio of 0.9 (95% CI, 0.6–1.1). Ever use of progestin alone was associated with an odds ratio of 0.5 (95% CI, 0.1–2.0). The only association with longer duration of use was a reduced risk of breast cancer with 8 to 15 years of estrogen use (odds ratio of 0.5). Among women who had started estrogen alone over 15 years earlier, the odds ratios were also reduced, ranging 0.3–0.5, and statistically significant. Among users of estrogen and progesterone who had started over 10 years earlier, the odds ratio was 0.3 (95% CI, 0.1–0.9). These odds ratios suggest decreased risk of breast cancer among HRT users. This study is rated as good quality.

Grodstein 1997 ^61^ : This is a good quality, nested case-control study based on the Nurses Health Study cohort described above. In this cohort, 3,637 women died and were randomly matched to 10 controls each by age at menopause and at the 2-year period near the case-patient's death. The multivariate adjusted relative risk of death associated with current versus never hormone replacement therapy use was 0.76 (0.56 to 1.02), and past hormone replacement therapy use versus never use relative risk was 0.83(0.63–1.09). Risk of death by duration of use was not evaluated.

Ross 2000 ^22^ : To date only one study has evaluated the risk of BCA associated with cyclic progesterone use. This population-based study involving 2,653 women with breast cancer identified by the Cancer Surveillance Program in California between March 1987 and December 1989 was published in 2000. The cases were individually matched by age, race, and neighborhood to 2,429 controls. Estrogen assessment was determined by interview within one year of diagnosis of the case, with detailed assessment of estrogen use, utilizing pictures. Information on demographics, physical characteristics, and other breast cancer risk factors was also obtained. In this study, each 5 years of all HRT use was associated with an odds ratio of 1.10 (95% CI, 1.02–1.18). Five years' use of combined hormone therapy was associated with an odds ratio of 1.24 (95% CI, 1.07–1.45). Risk estimates were higher for sequential combined hormone replacement therapy, odds ratio 1.38 (95% CI, 1.13–1.68), than for continuous combined hormone replacement therapy, with an odds ratio of 1.09 (95% CI, 0.88–1.35). The odds ratio for estrogen use alone by duration was elevated only after 15 years of use, at 1.24. For combined hormone replacement therapy, the odds ratio was 1.51 after 5 years' of use. This is the only study to date comparing sequential and cyclical progesterone use. It is of good-fair methodology, its major limitation being that a significant proportion of breast cancer patients were unable to participate because of death or severe illness.

Henrich 1998 ^52^ : This case-control study included 109 post-menopausal women above age 45 with breast cancer initially identified with mammography near New Haven, Connecticut. Five controls per case were matched by age, screening site, prior mammogram, year of mammography, and payment status (n=654). HRT use was associated with an odds ratio of 1.54 (95% CI, 0.94–2.82), any ERT with an odds ratio of 1.66 (95% CI, 0.98–2.82), and CHRT use with an odds ratio of 1.02 (95% CI, 0.32–3.21). When only invasive breast cancer was considered, ever use of HRT was associated with an odds ratio of 1.93 (95% CI, 1.06–3.49). This study is of fair quality limited largely by small size and lack of control of important breast cancer risk factors.

Weinstein 1993 ^45^ : This study compared 837 postmenopausal women from New York state diagnosed with breast cancer between 1984 and 1986 with controls identified by driver's license files who were matched by age, county, and postmenopausal status. Telephone interviews were conducted using a structured questionnaire, although interviewers were not blinded to case or control status. Risk factors were well evaluated and controlled for in the analysis. In this study, ever use of estrogen was associated with an adjusted odds ratio of 1.14 (95% CI, 0.84–1.40). The adjusted odds ratios for increasing duration ranged between 1.22 for less than one year's use to 0.88 for more than 5 years of use, neither of which were statistically significant. The authors reported a statistically significant odds ratio of 1.88 among women who were thinner, but this finding was not adjusted for other risk factors. A limitation of this study is that small numbers of women reported progesterone use and a large number were uncertain of their hormone formulation. It is of fair quality limited primarily by poor response rates in both cases and controls.

Yang 1992 ^42^ : This study evaluated 699 women younger than age 75 with breast cancer diagnosed between 1988 and 1989. These cases were compared to 685 age-similar controls drawn from voting lists. Risk factors and hormone use were evaluated by questionnaire. After adjusting for age and type of menopause, ever use of ERT was associated with a relative risk of 1.1 (95% CI, 0.8–1.4) and ever use of any progestin with a relative risk of 1.2 (95% CI, 0.6–2.2). There was no increase in risk associated with increasing duration of use until after 10 years (RR 1.6; 95% CI, 1.1–2.5). This study is of fair quality, based on poor response rates.

Brinton 1998 ^43^ : This population-based case-control study involved women in Atlanta under age 55 with newly-diagnosed breast cancer who were frequency matched by region to 919 controls. HRT exposure was evaluated by record review and personal interviews. Attempts were made to define dates, duration, and dose of hormones. Benign breast disease, alcohol use, and family history of breast cancer were not controlled for in the analysis. Ever use of HRT was associated with an odds ratio of 0.9 (95% CI, 0.7–1.2). No duration effect was shown, and, among women taking ERT, ever use was associated with an odds ratio of 0.7 (95% CI, 0.5–0.9); no association was shown with ever use of CHRT (RR 0.99). A limitation of this study is that the cases and controls had relatively low exposure to estrogen because of the young age of the cohort. A subcategory analysis showed significantly increased risk (RR 3.19; 95% CI, 1.4–7.4) of breast cancer among those using oral contraceptives for over 10 years, and hormone replacement therapy for over 3 years.

Italian case-control studies ^44,^ ^50,^ ^54^ : A number of reports have been published evaluating a hospital-based set of cases from Milan and 6 other Italian regions. The cases were assembled between January 1983 and February 1984. The largest of these included 5,984 women, ages 22 through 74, with histologically confirmed breast cancer. The 5,504 controls were ages 15 to 74 from the same geographic regions admitted to major teaching hospitals. Estrogen exposure was assessed with an in-hospital interview. The odds ratio for ever versus never use of estrogen was 1.2 (95% CI, 1.0–1.4). There was no effect shown with duration other than among women age 65 and older, where less than 60 months of use was associated with an odds ratio of 1.6 (95% CI, 1.1–2.3), and over 60 months of use was associated with an odds ratio of 2.2 (95% CI, 1.0–4.7). This study is of poor quality; limitations include a low prevalence (10%) of hormone replacement therapy and the fact that the study was not confined to postmenopausal women. In addition, controls were chosen from hospital admissions for orthopedic conditions, which may have led to bias in eliminating hormone replacement therapy use in the controls. This same study evaluated hormone replacement therapy use in nulliparous women and found no significant association between hormone replacement therapy and breast cancer in this subset, with an odds ratio of 1.22 for ever use (95% CI, 0.8–1.84).

Lipworth 1995 ^49^ : A study of 820 women from Athens with newly diagnosed breast cancer from 1989-1991 found an adjusted odds ratio for ever use of ERT of 1.52 (95% CI, 1.24–2.25). Use for less than one year was associated with increased risk (RR 1.75; 95% CI, 1.02–3.01) and risks for more than 2 years of use were not significantly elevated. The study's quality is poor, however, because risks were not adjusted for family history of breast cancer or benign breast disease. Also, use of orthopedic controls may have biased results in the direction of greater association if some of the controls were hospitalized with osteoporosis or its complications.

Persson 1997 ^46^ : This population-based study from Upsala, Sweden, conducted between 1990 and 1992, included 435 incident cases of breast cancer, primarily detected by mammogram. The odds ratio for ever use of HRT was 1.1 (95% CI, 0.8–1.4). No increase in risk was shown until after 11 years of HRT use (RR 2.1; 95% CI, 1.1– 4.0). When associations were evaluated by type of HRT, estradiol and conjugated estrogens had an odds ratio of 0.5 (95% CI 0.3–1.0) and CHRT an odds ratio of 1.4 (95% CI, 0.9–2.1), suggesting increased risk with CHRT. This study is of poor quality based on small size and the inclusion of premenopausal women.

Magnusson 1999 ^53^ : This study involved 2,563 cases of incident breast cancer in a cohort of postmenopausal women from Sweden identified between October 1993 and March 1995. Ever use of any HRT was associated with an odds ratio of 1.65 (95% CI, 1.43–1.89). ERT use had an odds ratio of 1.94 (95% CI, 1.47–2.55), and CHRT an odds ratio of 1.63 (95% CI, 1.37–1.94). A dose-related increase in risk of breast cancer was seen in every category of hormone use with longer duration of therapy. The risk associated with HRT was also increased among women with lower body mass index compared to those with higher body mass, suggesting an interaction. The interpretation of this study is limited however, since several important breast cancer risk factors were not controlled for (family history of breast cancer, prior benign breast disease, alcohol use, and socioeconomic status).

Levi 1996 ^51^ : This study evaluated exposure to HRT among 230 women ages 23–70 admitted to a Vaud, Switzerland hospital with breast cancer. The cases were compared to 507 controls admitted for a spectrum of diseases but excluding those potentially associated with HRT. Overall, there was no association identified between BCA and short-term HRT use (OR 1.2), although risk was elevated with use of less than 10 years (OR 1.7; 95% CI, 1.1–2.9). The study is of poor quality because it is not limited to postmenopausal women and there may have been bias in choosing controls by systematically excluding women with HRT exposure.