# Appendix 1. Search Strategy

The topic of HRT and breast cancer was searched in the Medline database including 1994 to January 2000.

1. exp hormone replacement therapy
  - estrogen replacement therapy
2. hormone replacement.tw. (text word taken from title and abstract of article)
3. estrogen replacement.tw.
4. exp estrogens/ ad,tu (ad = administration & doseage; tu = therapeutic use)
  - equilenin estrogens, catechol
  - equilin estrognes, conjugated
  - estradiol estrogens, non-steroidal
  - estriol estrone
5. exp estrogens, synthetic/ ad,tu
  - estrogens, non-steroidal epimestrol
  - chlorotrainisene ethinyl estradiol
  - coumestrol mestranol
  - dienestrol quinestrol
  - diethylstilbstrol hexestrol
  - zearalenone zeranol
6. 1 or 2 or 3 or 4 or 5
7. breast neoplasms
8. breast neoplasms, male
9. 7 or 8
10. 6 and 9
11. limit 10 to human
12. limit 11 to english language
13. looked at english abstracts of foreign articles