# References

1 Helfand M, Buckley DI, Freeman M, et al. (2009). Emerging risk factors for coronary heart disease: A summary of systematic reviews conducted for the U.S. Preventive Services Task Force. Ann Intern Med.
2 Pignone MP, Phillips CJ, Atkins D, et al. (2001). Screening and treating adults for lipid disorders. Am J Prev Med.
3 Pignone MP, Phillips CJ, Lannon CM, et al. (2001). Screening for Lipid Disorders.
4 U.S. Preventive Services Task Force. (2008). Screening for Lipid Disorders in Adults: Recomendation Statement Agency for Healthcare Research and Quality.
5 Chou R, Dana T, Blazina I, et al. Screening for Lipid Disorders in Younger Adults: Systematic Review to Update the 2008 U.S. Preventive Services Task Force Recommendation Agency for Healthcare Research & Quality.
6 Mensah GA, Brown DW. (2007). An overview of cardiovascular disease burden in the United States. Health Affairs.
7 Hoyert DL. (2012). 75 years of mortality in the United States, 1935-2010. NCHS Data Brief.
8 Minino AM. (2013). Death in the United States, 2011. NCHS Data Brief.
9 Go AS, Mozaffarian D, Roger VL, et al. (2013). Heart disease and stroke statistics—2013 update a report from the American Heart Association. Circulation.
10 Hoyert DL, Xu J. (2012). Deaths: preliminary data for 2011. Natl Vital Stat Rep.
11 Roger VL, Go AS, Lloyd-Jones DM, et al. (2012). Heart disease and stroke statistics--2012 update: a report from the American Heart Association. Circulation.
12 Centers for Disease Control and Prevention. (2011). Prevalence of coronary heart disease--United States, 2006-2010. Morb Mortal Wkly Rep.
13 Davies MJ. (2000). The pathophysiology of acute coronary syndromes. Heart.
14 Lerner DJ, Kannel WB. (1986). Patterns of coronary heart disease morbidity and mortality in the sexes: a 26-year follow-up of the Framingham population. Am Heart J.
15 Lecerf JM, de Lorgeril M. (2011). Dietary cholesterol: from physiology to cardiovascular risk. Br J Nutr.
16 National Institutes of Health. (2002). Detection, Evaluation and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) National Cholesterol Education Program.
17 Sheifer SE, Gersh BJ, Yanez ND, et al. (2000). Prevalence, predisposing factors, and prognosis of clinically unrecognized myocardial infarction in the elderly. J Am Coll Cardiol.
18 Sigurdsson E, Thorgeirsson G, Sigvaldason H, et al. (1995). Unrecognized myocardial infarction: epidemiology, clinical characteristics, and the prognostic role of angina pectoris: the Reykjavik Study. Ann Intern Med.
19 Welsh JA, Sharma A, Abramson JL, et al. (2010). Caloric sweetener consumption and dyslipidemia among us adults. JAMA.
20 Toth PP, Potter D, Ming EE. (2012). Prevalence of lipid abnormalities in the United States: the National Health and Nutrition Examination Survey 2003-2006. J Clin Lipidol.
21 Centers for Disease Control and Prevention. (2010). Cholesterol: Risk Factors.
22 Coffey S. (2011). Dyslipidemia. U.S. Department of Health and Human Services, Health Resources and Services Administration.
23 Stein JH. (2003). Dyslipidemia in the era of HIV protease inhibitors. Prog Cardiovasc Dis.
24 Saari K, Koponen H, Laitinen J, et al. (2004). Hyperlipidemia in persons using antipsychotic medication: a general population-based birth cohort study. J Clin Psychiatry.
25 Sniderman AD, Williams K, Contois JH, et al. (2011). A meta-analysis of low-density lipoprotein cholesterol, non-high-density lipoprotein cholesterol, and apolipoprotein B as markers of cardiovascular risk. Circ Cardiovasc Qual Outcomes.
26 Di Angelantonio E, Sarwar N, Perry P, et al. (2009). Major lipids, apolipoproteins, and risk of vascular disease. JAMA.
27 Robinson JG, Wang S, Smith BJ, et al. (2009). Meta-analysis of the relationship between non-high-density lipoprotein cholesterol reduction and coronary heart disease risk. J Am Coll Cardiol.
28 Ramjee V, Sperling LS, Jacobson TA. (2011). Non-high-density lipoprotein cholesterol versus apolipoprotein B in cardiovascular risk stratification: do the math. J Am Coll Cardiol.
29 Arsenault BJ, Mora S, Nestel PJ, et al. (2012). Clinician's Corner. Association of LDL cholesterol, non – HDL cholesterol, and apolipoprotein B levels with risk of cardiovascular events. JAMA.
30 Stone NJ, Robinson J, Lichtenstein AH, et al. (2013). 2013 ACC/AHA Guideline on the Treatment of Blood Cholesterol to Reduce Atherosclerotic Cardiovascular Risk in Adults A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol.
31 Kashani A, Phillips CO, Foody JM, et al. (2006). Risks associated with statin therapy a systematic overview of randomized clinical trials. Circulation.
32 Thompson PD, Clarkson PM, Rosenson RS. (2006). An assessment of statin safety by muscle experts. Am J Cardiol.
33 Alsheikh-Ali AA, Ambrose MS, Kuvin JT, et al. (2005). The safety of rosuvastatin as used in common clinical practice: a postmarketing analysis. Circulation.
34 Richardson K, Schoen M, French B, et al. (2013). Statins and cognitive function: A systematic review. Ann Intern Med.
35 Dale KM, Coleman CI, Henyan NN, et al. (2006). Statins and cancer risk: a meta-analysis. JAMA.
36 Ridker PM, Cook NR. (2013). Statins: new American guidelines for prevention of cardiovascular disease. Lancet.
37 Lloyd-Jones DM, Goff D, Stone NJ. (2013). Statins, risk assessment, and the new American prevention guidelines. Lancet.
38 Karmali KN, Goff DC, Ning H, et al. (2014). A systematic examination of the 2013 ACC/AHA pooled cohort risk assessment tool for atherosclerotic cardiovascular disease. J Am Coll Cardiol.
39 Miedema MD, Lopez FL, Blaha MJ, et al. (2015). Eligibility for statin therapy according to new cholesterol guidelines and prevalent use of medication to lower lipid levels in an older US Cohort: the Atherosclerosis Risk in Communities Study Cohort. JAMA Intern Med.
40 Pursnani A, Massaro JM, D'Agostino RB, et al. (2015). Guideline-based statin eligibility, coronary artery calcification, and cardiovascular events. JAMA.
41 Lopez-Jimenez F, Simha V, Thomas RJ, et al. (2014). A summary and critical assessment of the 2013 AA/AHA guideline on the treatment of the blood cholesterol to reduce atherosclerotic cardiovascular disease risk in adults: filling the gaps. Mayo Clin Proc.
42 National Institute for Health and Care Excellence (NICE). (2014). Lipid modification: cardiovascular risk assessment and the modification of blood lipids for the primary and secondary prevention of cardiovascular disease.
43 Board J. (2014). Joint British Societies' consensus recommendations for the prevention of cardiovascular disease (JBS3). Heart.
44 The Task Force for the Management of Dyslipidaemias of the European Society of Cardiology and the European Atherosclerosis Society. (2011). ESC/EAS Guidelines for the management of dyslipidaemias. Eur Heart J.
45 Anderson TJ, Gregoire J, Hegele RA, et al. (2013). 2012 update of the Canadian Cardiovascular Society guidelines for the diagnosis and treatment of dyslipidemia for the prevention of cardiovascular disease in the adult. Can J Cardiol.
46 International Atherosclerosis Society. (2014). Global recommendations for the management of dyslipidemia.
47 Department of Veterans Affairs. (2014). VA/DoD clinical practice guideline for the management of dyslipidemia for cardiovascular risk reduction.
48 Cholesterol Treatment Trialists Collaborators, Mihaylova B, Emberson J, et al. (2012). The effects of lowering LDL cholesterol with statin therapy in people at low risk of vascular disease: meta-analysis of individual data from 27 randomised trials. Lancet.
49 Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. Br Med J.
50 Cornell JE, Mulrow CD, Localio R, et al. (2014). Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med.
51 Sterne JA, Sutton AJ, Ioannidis J, et al. (2011). Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ.
52 Furberg CD, Adams HP, Applegate WB, et al. (1994). Effect of lovastatin on early carotid atherosclerosis and cardiovascular events. Asymptomatic Carotid Artery Progression Study (ACAPS) Research Group. Circulation.
53 ACAPS Group. (1992). Rationale and design for the Asymptomatic Carotid Artery Plaque Study (ACAPS). Control Clin Trials.
54 Downs JR, Clearfield M, Weis S, et al. (1998). Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels: results of AFCAPS/TexCAPS. Air Force/Texas Coronary Atherosclerosis Prevention Study. JAMA.
55 Downs JR, Beere PA, Whitney E, et al. (1997). Design & rationale of the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Am J Cardiol.
56 Downs JR, Clearfield M, Tyroler HA, et al. (2001). Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TEXCAPS): additional perspectives on tolerability of long-term treatment with lovastatin. Am J Cardiol.
57 Gotto AM, Whitney E, Stein EA, et al. (2000). Application of the National Cholesterol Education Program and joint European treatment criteria and clinical benefit in the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Eur Heart J.
58 Gotto AM, Whitney E, Stein EA, et al. (2000). Relation between baseline and on-treatment lipid parameters and first acute major coronary events in the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Circulation.
59 Gotto AM. (2007). Establishing the benefit of statins in low-to-moderate--risk primary prevention: the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Atheroscler Suppl.
60 Sever PS, Dahlof B, Poulter NR, et al. (2003). Prevention of coronary and stroke events with atorvastatin in hypertensive patients who have average or lower-than-average cholesterol concentrations, in the Anglo-Scandinavian Cardiac Outcomes Trial--Lipid Lowering Arm (ASCOT-LLA): a multicentre randomised controlled trial. Lancet.
61 Sever PS, Dahlof B, Poulter NR, et al. (2001). Rationale, design, methods and baseline demography of participants of the Anglo-Scandinavian Cardiac Outcomes Trial. ASCOT investigators. J Hypertens.
62 Sever PS, Poulter NR, Dahlof B, et al. (2005). Reduction in cardiovascular events with atorvastatin in 2,532 patients with type 2 diabetes: Anglo-Scandinavian Cardiac Outcomes Trial--lipid-lowering arm (ASCOT-LLA). Diabetes Care.
63 Knopp RH, d'Emden M, Smilde JG, et al. (2006). Efficacy and safety of atorvastatin in the prevention of cardiovascular end points in subjects with type 2 diabetes: the Atorvastatin Study for Prevention of Coronary Heart Disease Endpoints in non-insulin-dependent diabetes mellitus (ASPEN). Diabetes Care.
64 Chan KL, Teo K, Dumesnil JG, et al. (2010). Effect of lipid lowering with rosuvastatin on progression of aortic stenosis: results of the aortic stenosis progression observation: measuring effects of rosuvastatin (ASTRONOMER) trial. Circulation.
65 Beishuizen ED, van de Ree MA, Jukema JW, et al. (2004). Two-year statin therapy does not alter the progression of intima-media thickness in patients with type 2 diabetes without manifest cardiovascular disease. Diabetes Care.
66 Bone HG, Kiel DP, Lindsay RS, et al. (2007). Effects of atorvastatin on bone in postmenopausal women with dyslipidemia: a double-blind, placebo-controlled, dose-ranging trial. J Clin Endocrinol Metab.
67 Mercuri M, Bond MG, Sirtori CR, et al. (1996). Pravastatin reduces carotid intima-media thickness progression in an asymptomatic hypercholesterolemic mediterranean population: the Carotid Atherosclerosis Italian Ultrasound Study. Am J Med.
68 Sirtori CR, Bianchi G, Bond MG, et al. (1995). Pravastatin intervention trial on carotid artery atherosclerosis in patients with mild hypercholesterolemia: the CAIUS study. Int J Card Imaging.
69 Colhoun HM, Betteridge DJ, Durrington PN, et al. (2004). Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the Collaborative Atorvastatin Diabetes Study (CARDS): multicentre randomised placebo-controlled trial. Lancet.
70 Colhoun HM, Thomason MJ, Mackness MI, et al. (2002). Design of the Collaborative AtoRvastatin Diabetes Study (CARDS) in patients with type 2 diabetes. Diabetic Med.
71 Neil HAW, DeMicco DA, Luo D, et al. (2006). Analysis of efficacy and safety in patients aged 65-75 years at randomization: Collaborative Atorvastatin Diabetes Study (CARDS). Diabetes Care.
72 Heljić B, Velija-Asimi Z, Kulic M. (2009). The statins in prevention of coronary heart diseases in type 2 diabetics. Bosn J Basic Med Sci.
73 Anderssen SA, Hjelstuen AK, Hjermann I, et al. (2005). Fluvastatin and lifestyle modification for reduction of carotid intima-media thickness and left ventricular mass progression in drug-treated hypertensives. Atherosclerosis.
74 Ridker PM, Danielson E, Fonseca FAH, et al. (2008). Rosuvastatin to prevent vascular events in men and women with elevated C-reactive protein. N Engl J Med.
75 Ridker PM, Fonseca FAH, Genest J, et al. (2007). Baseline characteristics of participants in the JUPITER trial, a randomized placebo-controlled primary prevention trial of statin therapy among individuals with low low-density lipoprotein cholesterol and elevated high-sensitivity C-reactive protein. Am J Cardiol.
76 Ridker PM, Group JS. (2003). Rosuvastatin in the primary prevention of cardiovascular disease among patients with low levels of low-density lipoprotein cholesterol and elevated high-sensitivity C-reactive protein: rationale and design of the JUPITER trial. Circulation.
77 Albert MA, Glynn RJ, Fonseca FAH, et al. (2011). Race, ethnicity, and the efficacy of rosuvastatin in primary prevention: the Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER) trial. Am Heart J.
78 Glynn RJ, Koenig W, Nordestgaard BG, et al. (2010). Rosuvastatin for primary prevention in older persons with elevated C-reactive protein and low to average low-density lipoprotein cholesterol levels: exploratory analysis of a randomized trial. Ann Intern Med.
79 Ridker PM, Macfadyen JG, Nordestgaard BG, et al. (2010). Rosuvastatin for primary prevention among individuals with elevated high-sensitivity c-reactive protein and 5% to 10% and 10% to 20% 10-year risk. Implications of the Justification for Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER) trial for “intermediate risk”. Circulation.
80 Koenig W, Ridker PM. (2011). Rosuvastatin for primary prevention in patients with European systematic coronary risk evaluation risk > 5% or Framingham risk >20%: post hoc analyses of the JUPITER trial requested by European health authorities. Eur Heart J.
81 Mora S, Glynn RJ, Hsia J, et al. (2010). Statins for the primary prevention of cardiovascular events in women with elevated high-sensitivity C-reactive protein or dyslipidemia: results from the Justification for the Use of Statins in Prevention: An Intervention Trial Evaluating Rosuvastatin (JUPITER) and meta-analysis of women from primary prevention trials. Circulation.
82 Salonen R, Nyyssonen K, Porkkala E, et al. (1995). Kuopio Atherosclerosis Prevention Study (KAPS). A population-based primary preventive trial of the effect of LDL lowering on atherosclerotic progression in carotid and femoral arteries. Circulation.
83 Nakamura H, Arakawa K, Itakura H, et al. (2006). Primary prevention of cardiovascular disease with pravastatin in Japan (MEGA Study): a prospective randomised controlled trial. Lancet.
84 Tajima N, Kurata H, Nakaya N, et al. (2008). Pravastatin reduces the risk for cardiovascular disease in Japanese hypercholesterolemic patients with impaired fasting glucose or diabetes: diabetes subanalysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study. Atherosclerosis.
85 Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study Group. (2004). Design and baseline characteristics of a study of primary prevention of coronary events with pravastatin among Japanese with mildly elevated cholesterol levels. Circ J.
86 Uchiyama S, Nakaya N, Mizuno K, et al. (2009). Risk factors for stroke and lipid-lowering effect of pravastatin on the risk of stroke in Japanese patients with hypercholesterolemia: analysis of data from the MEGA Study, a large randomized controlled trial. J Neurol Sci.
87 Kushiro T, Mizuno K, Nakaya N, et al. (2009). Pravastatin for cardiovascular event primary prevention in patients with mild-to-moderate hypertension in the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study. Hypertension.
88 Mizuno K, Nakaya N, Ohashi Y, et al. (2008). Usefulness of pravastatin in primary prevention of cardiovascular events in women: analysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA study). Circulation.
89 Nakaya N, Mizuno K, Ohashi Y, et al. (2011). Low-dose pravastatin and age-related differences in risk factors for cardiovascular disease in hypercholesterolaemic Japanese: analysis of the management of elevated cholesterol in the primary prevention group of adult Japanese (MEGA study). Drugs Aging.
90 Nakamura H, Mizuno K, Ohashi Y, et al. (2009). Pravastatin and cardiovascular risk in moderate chronic kidney disease. Atherosclerosis.
91 Nishiwaki M, Ikewaki K, Ayaori M, et al. (2013). Risk reductions for cardiovascular disease with pravastatin treatment by dyslipidemia phenotype: a post hoc analysis of the MEGA Study. J Cardiol.
92 Muldoon MF, Ryan CM, Sereika SM, et al. (2004). Randomized trial of the effects of simvastatin on cognitive functioning in hypercholesterolemic adults. Am J Med.
93 Crouse JR, Raichlen JS, Riley WA, et al. (2007). Effect of rosuvastatin on progression of carotid intima-media thickness in low-risk individuals with subclinical atherosclerosis: the METEOR Trial. JAMA.
94 Crouse J, Grobbee DE, O'Leary DH, et al. (2004). Measuring effect on intima medial thickness: a evaluation of rosuvastatin in subclinical artherosclerosis - the rationale and methodology of the METEOR Study. Cardiovasc Drugs Ther.
95 Asselbergs FW, Diercks GFH, Hillege HL, et al. (2004). Effects of fosinopril and pravastatin on cardiovascular events in subjects with microalbuminuria. Circulation.
96 Shepherd J, Cobbe SM, Ford I, et al. (1995). Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia. West of Scotland Coronary Prevention Study Group. N Engl J Med.
97 Clearfield M, Whitney EJ, Weis S, et al. (2000). Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS): baseline characteristics and comparison with USA population. J Cardiovasc Risk.
98 Clearfield M, Downs JR, Weis S, et al. (2001). Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS): efficacy and tolerability of long-term treatment with lovastatin in women. J Womens Health Gend Based Med.
99 Kendrick J, Shlipak MG, Targher G, et al. (2010). Effect of lovastatin on primary prevention of cardiovascular events in mild CKD and kidney function loss: a post hoc analysis of the Air Force/Texas Coronary Atherosclerosis Prevention Study. Am J Kidney Dis.
100 Ridker PM, Rifai N, Clearfield M, et al. (2001). Measurement of C-reactive protein for the targeting of statin therapy in the primary prevention of acute coronary events. N Engl J Med.
101 Freeman DJ, Norrie J, Sattar N, et al. (2001). Pravastatin and the development of diabetes mellitus: evidence for a protective treatment effect in the West of Scotland Coronary Prevention Study. Circulation.
102 Newman CB, Szarek M, Colhoun HM, et al. (2008). The safety and tolerability of atorvastatin 10 mg in the Collaborative Atorvastatin Diabetes Study (CARDS). Diab Vasc Dis Res.
103 Yusuf S, Bosch J, Dagenais G, et al. (2016). Cholesterol Lowering in Intermediate-Risk Persons without Cardiovascular Disease. N Engl J Med.
104 Lonn E, Bosch J, Pogue J, et al. (2016). Novel approaches in primary cardiovascular disease prevention: The HOPE-3 trial rationale, design, and participants' baseline characteristics. Can J Cardiol.
105 Taylor F, Huffman MD, Macedo AF, et al. (2013). Statins for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev.
106 Shepherd J. (1995). The West of Scotland Coronary Prevention Study: a trial of cholesterol reduction in Scottish men. Am J Cardiol.
107 U.S. Food & Drug Administration Division of Metabolism and Endocrinology Products (DMEP). (2009). Memorandum: 15 December 2008, Advisory Committee meeting for rosuvastatin Department of Health and Human Services Food and Drug Administration, Center for Drug Evaluation and Research.
108 McGorrian C, Yusuf S, Islam S, et al. (2011). Estimating modifiable coronary heart disease risk in multiple regions of the world: the INTERHEART Modifiable Risk Score. Eur Heart J.
109 Ridker PM, Pradhan A, MacFadyen JG, et al. (2012). Cardiovascular benefits and diabetes risks of statin therapy in primary prevention: an analysis from the JUPITER trial. Lancet.
110 Jick SS, Bradbury BD. (2004). Statins and newly diagnosed diabetes. Br J Clin Pharmacol.
111 Culver AL, Ockene IS, Balasubramanian R, et al. (2012). Statin use and risk of diabetes mellitus in postmenopausal women in the Women's Health Initiative. Arch Intern Med.
112 Sattar N, Preiss D, Murray HM, et al. (2010). Statins and risk of incident diabetes: a collaborative meta-analysis of randomised statin trials. Lancet.
113 Goff DC, Lloyd-Jones DM, Bennett G, et al. (2014). 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol.
114 Chambless LE, Folsom AR, Sharrett AR, et al. (2003). Coronary heart disease risk prediction in the Atherosclerosis Risk in Communities (ARIC) study. J Clin Epidemiol.
115 National Cholesterol Education Program Expert Panel on Detection Evaluation, Treatment of High Blood Cholesterol in Adults. (2002). Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation.
116 D'Agostino RB, Vasan RS, Pencina MJ, et al. (2008). General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation.
117 Assmann G, Cullen P, Schulte H. (2002). Simple scoring scheme for calculating the risk of acute coronary events based on the 10-year follow-up of the prospective cardiovascular Munster (PROCAM) study. Circulation.
118 Hippisley-Cox J, Coupland C, Vinogradova Y, et al. (2008). Predicting cardiovascular risk in England and Wales: prospective derivation and validation of QRISK2. BMJ.
119 Ridker PM, Buring JE, Rifai N, et al. (2007). Development and validation of improved algorithms for the assessment of global cardiovascular risk in women: the Reynolds Risk Score. JAMA.
120 Ridker PM, Paynter NP, Rifai N, et al. (2008). C-reactive protein and parental history improve global cardiovascular risk prediction: the Reynolds Risk Score for men. Circulation.
121 Conroy RM, Pyorala K, Fitzgerald AP, et al. (2003). Estimation of ten-year risk of fatal cardiovascular disease in Europe: the SCORE project. Eur Heart J.
122 Matheny M, McPheeters M, Glasser A, et al. (2011). Systematic Review of Cardiovascular Disease Risk Assessment Tools Agency for Healthcare Research & Quality.
123 U.S. Preventive Services Task Force. (2016). Aspirin Use for the Primary Prevention of Cardiovascular Events: Final Research Plan.
124 D'Agostino RB, Grundy S, Sullivan LM, et al. (2001). Validation of the framingham coronary heart disease prediction scores: Results of a multiple ethnic groups investigation. JAMA.
125 Siontis GC, Tzoulaki I, Siontis KC, et al. (2012). Comparisons of established risk prediction models for cardiovascular disease: systematic review. BMJ.
126 Preiss D, Kristensen SL. (2015). The new pooled cohort equations risk calculator. Can J Cardiol.
127 Muntner P, Colantonio LD, Cushman M, et al. (2014). Validation of the atherosclerotic cardiovascular disease pooled cohort risk equations. JAMA.
128 DeFilippis AP, Young R, Carrubba CJ, et al. (2015). An analysis of calibration and discrimination among multiple cardiovascular risk scores in a modern multiethnic cohort. Ann Intern Med.
129 Cook NR, Ridker PM. (2014). Further insight into the Cardiovascular Risk Calculator: the roles of statins, revascularizations, and underascertainment in the Women's Health Study. JAMA Intern Med.
130 Rana JS, Tabada GH, Solomon MD, et al. (2016). Accuracy of the Atherosclerotic Cardiovascular Risk Equation in a large contemporary, multiethnic population. J Am Coll Cardiol.
131 Kreger BE, Odell PM, D'Agostino RB, et al. (1994). Long-term intraindividual cholesterol variability: natural course and adverse impact on morbidity and mortality--the Framingham Study. Am Heart J.
132 Bakx JC, van den Hoogen HJ, Deurenberg P, et al. (2000). Changes in serum total cholesterol levels over 18 years in a cohort of men and women: The Nijmegen Cohort Study. Prev Med.
133 Ferrara A, Barrett-Connor E, Shan J. (1997). Total, LDL, and HDL cholesterol decrease with age in older men and women. The Rancho Bernardo Study 1984-1994. Circulation.
134 Glasziou PP, Irwig L, Heritier S, et al. (2008). Monitoring cholesterol levels: measurement error or true change?. Ann Intern Med.
135 Wilsgaard T, Jacobsen BK, Schirmer H, et al. (2001). Tracking of cardiovascular risk factors: the Tromso study, 1979-1995. Am J Epidemiol.
136 Ulmer H, Kelleher C, Diem G, et al. (2003). Long-term tracking of cardiovascular risk factors among men and women in a large population-based health system: the Vorarlberg Health Monitoring & Promotion Programme. Eur Heart J.
137 Ray KK, Seshasai SRK, Erqou S, et al. (2010). Statins and all-cause mortality in high-risk primary prevention: a meta-analysis of 11 randomized controlled trials involving 65,229 participants. Arch Intern Med.
138 Tonelli M, Lloyd A, Clement F, et al. (2011). Efficacy of statins for primary prevention in people at low cardiovascular risk: A meta-analysis. CMAJ.
139 Stone NJ, Robinson J, Lichtenstein AH, et al. (2013). Evidence Report: Managing high blood cholesterol in adults—systematic evidence review from the cholesterol expert panel, 2013 US Department of Health and Human Services.
140 ALLHAT Officers and Coordinators for the ALLHAT Collaborative Research Group. (2002). Major outcomes in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin vs usual care: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT-LLT). JAMA.
141 Hennekens CH. (2004). The ALLHAT-LLT and ASCOT-LLA trials: are the discrepancies more apparent than real?. Curr Atheroscler Rep.
142 Heart Protection Study Collaborative Group. (2007). Randomized trial of the effects of cholesterol-lowering with simvastatin on peripheral vascular and other major vascular outcomes in 20,536 people with peripheral arterial disease and other high-risk conditions. J Vasc Surg.
143 Bukkapatnam RN, Gabler NB, Lewis WR. (2010). Statins for primary prevention of cardiovascular mortality in women: a systematic review and meta-analysis. Prev Cardiol.
144 Kaul S, Morrissey RP, Diamond GA. (2010). By Jove! What is a clinician to make of JUPITER?. Arch Intern Med.
145 Bonovas S, Filioussi K, Flordellis CS, et al. (2007). Statins and the risk of colorectal cancer: a meta-analysis of 18 studies involving more than 1.5 million patients. J Clin Oncol.
146 Finegold JA, Manisty CH, Goldacre B, et al. (2014). What proportion of symptomatic side effects in patients taking statins are genuinely caused by the drug? Systematic review of randomized placebo-controlled trials to aid in individual patient choice. Eur J Prev Cardiolog.
147 Macedo AF, Taylor F, Casas JP, et al. (2014). Unintended effects of statins from observational studies in the general population: systematic review and meta-analysis. BMC Med.
148 Parker BA, Capizzi JA, Grimaldi AS, et al. (2013). Effect of statins on skeletal muscle function. Circulation.
149 Nissen SE, Stroes E, Dent-Acosta RE, et al. (2016). Efficacy and tolerability of evolocumab vs ezetimibe in patients with muscle-related statin intolerance: the GAUSS-3 randomized clinical trial. JAMA.
150 Kostis JB, Dobrzynski JM. (2014). Prevention of cataracts by statins: a meta-analysis. J Cardiovasc Pharmacol Ther.
151 Preiss D, Sattar N. (2011). Statins and the risk of new-onset diabetes: a review of recent evidence. Curr Opin Lipidol.
152 Rajpathak SN, Kumbhani DJ, Crandall J, et al. (2009). Statin therapy and risk of developing type 2 diabetes: a meta-analysis. Diabetes Care.
153 Preiss D, Seshasai SR, Welsh P, et al. (2011). Risk of incident diabetes with intensive-dose compared with moderate-dose statin therapy: a meta-analysis. JAMA.
154 Dormuth CR, Filion KB, Paterson JM, et al. (2014). Higher potency statins and the risk of new diabetes: multicentre, observational study of administrative databases. BMJ.
155 Holmes MV, Lange LA, Palmer T, et al. (2014). Causal effects of body mass index on cardiometabolic traits and events: a Mendelian randomization analysis. Am J Hum Genet.
156 Swerdlow DI, Preiss D, Kuchenbaecker KB, et al. (2014). HMG-coenzyme A reductase inhibition, type 2 diabetes, and bodyweight: evidence from genetic analysis and randomised trials. Lancet.
157 Strom BL, Schinnar R, Karlawish J, et al. (2015). Statin therapy and risk of acute memory impairment. JAMA Intern Med.
158 Shepherd J, Blauw GJ, Murphy MB, et al. (2002). Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet.
159 Song F, Xiong T, Parekh-Bhurke S, et al. (2011). Inconsistency between direct and indirect comparisons of competing interventions: meta-epidemiological study. BMJ.
160 Morrison A, Polisena J, Husereau D, et al. (2012). The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care.
161 Pham B, Klassen TP, Lawson ML, et al. (2005). Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol.
162 Lundh A, Sismondo S, Lexchin J, et al. (2012). Industry sponsorship and research outcome. Cochrane Database Syst Rev.
163 Sismondo S. (2008). Pharmaceutical company funding and its consequences: a qualitative systematic review. Contemp Clin Trials.
164 Golder S, Loke YK. (2008). Is there evidence for biased reporting of published adverse effects data in pharmaceutical industry-funded studies?. Br J Clin Pharmacol.
165 Naci H, Dias S, Ades AE. (2014). Industry sponsorship bias in research findings: a netword meta-analysis of LDL cholesterol redution in randomized trials of statins. BMJ.
166 Kavousi M, Leening MJ, Nanchen D, et al. (2014). Comparison of application of the ACC/AHA guidelines, Adult Treatment Panel III guidelines, and European Society of Cardiology guidelines for cardiovascular disease prevention in a European cohort. JAMA.
167 Sabatine MS, Giugliano RP, Wiviott SD, et al. (2015). Efficacy and safety of evolocumab in reducing lipids and cardiovascular events. N Engl J Med.
168 Robinson JG, Farnier M, Krempf M, et al. (2015). Efficacy and safety of alirocumab in reducing lipids and cardiovascular events. N Engl J Med.
169 Strandberg TE, Kolehmainen L, Vuorio A. (2014). Evaluation and treatment of older patients with hypercholesterolemia: a clinical review. JAMA.
170 Bruckert E, Lievre M, Giral P, et al. (2003). Short-term efficacy and safety of extended-release fluvastatin in a large cohort of elderly patients. Am J Geriat Cardio.