# Acknowledgements

The authors thank Jennifer Croswell, MD, MPH, and AHRQ Medical Officer Quyen Ngo-Metzger, MD, MPH, as well as current and former members of the U.S. Preventive Services Task Force who contributed to topic discussions.