# 1 Introduction

## Purpose and Previous U.S. Preventive Services Task Force Recommendation

This review evaluates benefits and harms of statin therapy for prevention of cardiovascular disease (CVD) in adults without prior cardiovascular events. The U.S. Preventive Services Task Force (USPSTF) has not previously addressed this issue.

Prior USPSTF reviews^1-3^ on lipid screening evaluated evidence on benefits of treatment with statins in patients with lipid disorders but did not address evidence regarding use of statins in patients at higher cardiovascular risk based on other factors (e.g., 10-year individualized cardiovascular risk assessment, presence of nonlipid cardiovascular risk factors). Prior USPSTF recommendations (last updated in 2008)^4^ focused on who to screen for lipid disorders without addressing specific aspects of treatment, such as use of statins in patients without dyslipidemia, selection of statins, and dosing strategies.

The 2001 USPSTF review on lipid screening found strong direct evidence that drug therapy reduces coronary heart disease (CHD) events and CHD mortality in middle-aged men (age ≥35 and ≤70 years) with abnormal lipid levels and a potential risk of CHD events of greater than 1 percent per year. It also found that drug therapy may reduce total mortality in patients with dyslipidemia who are at higher risk (>1.5% per year). The 2001 USPSTF review also found evidence suggesting that drug therapy is also effective in other adults, including older men (age >70 years) and middle-aged and older women (age ≥45 years) at similar levels of risk, though evidence was less direct.

Given the tremendous burden of CVD, its potential preventability, the widespread use of statins, the recognition that lipid levels are not the only factor used to determine suitability for statin therapy, and the uncertainty about optimal treatment strategies, the USPSTF commissioned this review to inform the development of new recommendations on use of statin therapy for prevention of CVD in adults. This review focuses on use of statins in adults age 40 years or older. A separate evidence review was commissioned by the USPSTF on lipid screening in younger adults.^5^

## Condition Definition

The purpose of statin therapy is to reduce the risk of CVD and associated morbidity and mortality. The term “cardiovascular disease” is somewhat nonspecific but in this report refers to atherosclerotic diseases that affect the heart and blood vessels, in particular ischemic CHD, cerebrovascular disease, and peripheral vascular disease. CVD can result in myocardial infarction (MI) and cerebrovascular disease, including stroke.

## Prevalence and Burden of Disease/Illness

CVD is the leading cause of morbidity and mortality in the United States and is responsible for one of every three deaths.^6^ CHD alone accounts for more than half of all cardiovascular events in adults younger than age 75 years and is the single leading cause of death.^7-9^ In 2011, there were an estimated 375,000 deaths due to CHD and 130,000 deaths due to cerebrovascular disease.^10^ CHD caused 12 percent of deaths in persons ages 25 to 44 years, 21 percent of deaths in persons ages 45 to 64 years, and 26 percent of deaths in persons age 65 years or older.^8^ Estimates based on Framingham Heart Study participants from 1971 to 1996 indicate that the lifetime risk (through age 80 years) of CHD for 40-year-old men with a total cholesterol (TC) level of 200, 200 to 239, and 240 mg/dL or greater were 31, 43, and 57 percent, respectively, with respective 10-year cumulative risks of 3, 5, and 12 percent. In 2008, heart disease and stroke accounted for nearly !300 billion in health care costs.^11^

Prevalence of CHD increases with age, ranging from 1 percent in 18- to 44-year-olds to 7 percent in 45- to 64-year-olds and 20 percent in adults older than age 65 years, and is higher in men (8%) than in women (5%).^12^ Prevalence of CHD varies by race/ethnicity, affecting 12 percent of American Indians/Alaska Natives, 7 percent of blacks, 6 percent of Hispanics, 6 percent of whites, and 4 percent of Asian/Pacific Islanders. In 2010, heart disease was associated with 972 age-adjusted potential life-years lost per 100,000 persons younger than age 75 years.^13,14^

## Etiology and Natural History

The etiology of CVD is multifactorial and is affected by well-established risk factors, such as age, sex, family history of early-onset CVD, smoking status, and presence and severity of obesity, dyslipidemia, hypertension, and diabetes.

Cholesterol is a lipid that is present in all animal cells; it is vital to cell membrane structure and acts as a precursor to vitamin D, adrenal and gonadal steroid hormones, and bile acids.^15^ Cholesterol is a primary contributor to plaque formation and is the main target of statin therapy. Cholesterol is transported in the body as particles of lipid and protein (lipoproteins).^16^ There are three main classes of lipoproteins: high-density lipoprotein cholesterol (HDL-C), low-density lipoprotein cholesterol (LDL-C), and very low-density lipoprotein cholesterol (VLDL-C). LDL-C makes up 60 to 70 percent of total serum cholesterol, HDL-C contributes 20 to 30 percent, and VLDL-C contributes 10 to 15 percent. LDL-C is the main atherogenic lipoprotein and is the primary target of cholesterol-lowering therapy, though some forms of VLDL-C are precursors to LDL-C and also promote atherosclerosis. HDL-C is inversely related to risk of CHD. The risk of CVD increases as LDL-C levels increase. However, CVD can occur in patients with relatively low or normal lipid levels, depending on the presence and severity of other risk factors.

The natural history of CVD varies but often involves a long asymptomatic stage of gradual buildup of atherosclerotic plaque in affected arterial vessels. An important challenge in preventing the negative consequences of CVD is that its first clinical manifestation can be catastrophic, including sudden cardiac death, acute MI, or stroke.^14^ Among persons who die suddenly of CHD, more than half had no antecedent symptoms.^9^ In addition, MI is frequently silent, causing no recognized symptoms but negatively impacting prognosis.^17,18^

## Risk Factors

Modifiable risk factors for CHD include dyslipidemia (high LDL-C, low HDL-C, or high triglyceride [TG] levels), hypertension, smoking, thrombogenic/hemostatic state, diabetes, obesity, physical inactivity, and atherogenic diet (high in saturated fatty acids, cholesterol, and sodium).^16^ Nonmodifiable risk factors include older age (≥45 years in men or ≥55 years in women), male sex, and family history of early-onset CHD.

Risk factors for dyslipidemia include physical inactivity, obesity, abdominal obesity, metabolic syndrome, hypertension, atherogenic diet, consumption of dietary added sugars, genetic factors, age, and male sex.^16,19-21^ Elevated TG levels are associated with overweight and obesity, physical inactivity, smoking, excess alcohol intake, high carbohydrate diet, other diseases such as diabetes and nephritic syndrome, medications such as corticosteroids or estrogens, and genetic factors.^16^ Hyperlipidemia is also associated with conditions such as HIV infection, renal transplant, and use of certain medications, such as antipsychotic medications and anti-HIV protease inhibitors.^22-24^

Non–HDL-C (i.e., TC minus HDL-C) is a measure that includes all potentially atherogenic lipoprotein particles, including LDL, VLDL, intermediate-density lipoprotein, and lipoprotein(a), which may be a more accurate predictor of CHD risk than LDL-C.^25-27^ Apolipoprotein B directly measures the total number of atherogenic particles, though it is unclear whether it is superior to HDL-C as a marker of CHD risk.^25,28,29^ In addition, non–HDL-C is easier and less costly to measure. In 2008, the USPSTF recommended lipid screening with a fasting or nonfasting HDL-C measurement, combined with either TC level or a measure of LDL-C.^4^

Other potential risk factors for CVD include alternative lipid measures such as apolipoproteins, TC-to-HDL ratio, and other lipoprotein levels and nonlipid factors such as inflammatory markers (e.g., C-reactive protein [CRP] and homocysteine) and thrombogenic factors (e.g., fibrinogen, antithrombin III, and factor V Leiden).^16^ In 2009, a USPSTF evidence review of nine emerging risk factors, including CRP, leukocyte count, homocysteine, and lipoprotein levels, found that evidence was insufficient to support their use to reclassify persons at intermediate risk of CVD as high risk, although it found promising evidence for CRP.^1^

## Rationale for Preventive Treatment

CVD is often associated with a prolonged asymptomatic phase, is highly prevalent, and is an important cause of mortality and morbidity in adults age 40 years or older. Treatment of persons at higher risk of CVD with statins could prevent future events, including MI and stroke, and improve morbidity, mortality, and quality of life.

## Interventions/Treatment

Statins are a class of drugs that work by inhibiting the enzyme 3-hydroxy-3-methylglutaryl coenzyme A reductase, the rate-limiting step in the manufacture of cholesterol. Statins reduce LDL-C, TC, and TG levels; slightly increase HDL-C levels; and are also thought to have anti-inflammatory and other plaque stabilization effects.^30^

Seven statins are available in the United States: atorvastatin, fluvastatin, lovastatin, pitavastatin, pravastatin, rosuvastatin, and simvastatin. The statins, dose ranges, and relative potency (based on average lipid-lowering effects) are shown in Table 1.^30^ Potential harms of statins include hepatotoxicity (ranging from mild transaminitis to hepatic failure),^31^ muscle injury (ranging from myalgia to overt rhabdomyolysis),^32^ renal dysfunction,^33^ and diabetes. Adverse effects on behavior and cognition^34^ and increased risk of cancer^35^ have also been linked with statins but not clearly established, with some studies showing no association. In the case of cognition, some studies suggest that statins may reduce risk of dementia.

Table 1 Statin Dosing and ACC/AHA Classification of Intensity

Statin | Dosage
Statin | Low-intensity (LDL-C reduction <30%) | Moderate-intensity (LDL-C reduction 30% to <50%) | High-intensity (LDL-C reduction >50%)
Atorvastatin | NA | 10 to 20 mg | 40 to 80 mg
Fluvastatin | 20 to 40 mg | 40 mg 2×/day; XL 80 mg | NA
Lovastatin | 20 mg | 40 mg | NA
Pitavastatin | 1 mg | 2 to 4 mg | NA
Pravastatin | 10 to 20 mg | 40 to 80 mg | NA
Rosuvastatin | NA | 5 to 10 mg | 20 to 40 mg
Simvastatin | 10 mg | 20 to 40 mg | NA

From ACC/AHA, 2013.^30^ Dosages shown are total daily dosages; exceptions are noted.

Abbreviations: ACC=American College of Cardiology; AHA=American Heart Association; LDL-C=low-density lipoprotein cholesterol; NA=not applicable.

## Current Clinical Practice

Approximately 36 million Americans are currently treated with statins.^30^ Recommendations on the use of statins for prevention of CVD are evolving. Prior to 2013, treatment in the United States generally followed a guideline from the Adult Treatment Panel III (ATP III), which recommended global risk evaluation (either based on number of risk factors or using a global calculator to estimate 10-year risk) to guide use of lipid-lowering therapy.^16^ LDL-C thresholds for initiation of lipid-lowering therapy varied from 130 mg/dL or greater to 190 mg/dL or greater, depending on the assessed risk category (defined as: low, based on estimated risk of <10% for a CVD event after 10 years; intermediate, based on estimated risk of 10% to 20%; or high, based on estimated risk of >20%). Drug options for lipid lowering included statins, bile acid sequestrants, nicotinic acid, and fibrates, though statins were designated as the initial drug of choice given proven efficacy for lowering LDL-C and evidence showing improved clinical outcomes. Therapy with a statin or other lipid-lowering therapy was targeted to achieve goal LDL-C levels that varied from less than 100 mg/dL to less than 160 mg/dL, depending on the risk category.

The American College of Cardiology (ACC) and the American Heart Association (AHA) issued an updated guideline on lipid-lowering therapy at the end of 2013, and it differs from that of ATP III in a number of ways.^30^ In the new guideline, statins are the recommended first-line lipid-lowering therapy to reduce CVD risk, as evidence on effectiveness of lipid-lowering therapy for primary prevention in improving clinical outcomes is strongest for statins. Target populations for statin therapy were redefined as four groups: persons with atherosclerotic CVD, persons with an LDL-C level of 190 mg/dL or greater, persons ages 40 to 75 years with diabetes and an LDL-C level of 70 to 189 mg/dL, or persons not in the previous three categories with an estimated 10-year risk of 7.5 percent or greater. In the latter group, shared decisionmaking is recommended prior to initiation of statin therapy. Rather than managing statin therapy to achieve a target LDL-C level, the ACC/AHA recommends fixed-dose statin therapy, with the intensity (based on the dose and potency of the statin used) of therapy determined by the risk profile. Finally, the new guideline recommends the use of a newly developed global risk calculator to estimate risk.

Release of the updated guideline has generated debate regarding the accuracy of the new risk calculator, the move away from LDL-C target-based treatment strategies, and the threshold used to select patients for therapy.^36,37^ Research indicates that application of the ACC/AHA guideline substantially increases the proportion of patients eligible for treatment with statins compared with the ATP III guideline.^38-40^ Much of the increase in eligibility is attributable to the lower 10-year CVD risk threshold in the ACC/AHA guideline, with age a major driver of risk.

## Recommendations of Other Groups

The ATP III and updated ACC/AHA guidelines are discussed above.

The Mayo Clinic Task Force recommendations on use of statins are generally consistent with those of the ACC/AHA, though lifestyle modification alone is suggested for patients who are likely to be successful at reducing risk to less than 7.5 percent.^41^ In the United Kingdom, the National Institute for Health and Care Excellence^42^ recommends statin use in persons with a 10-year CVD risk of 10 percent or greater, based on the QRISK calculator (see Contextual Question 2). In line with this recommendation, the Joint British Societies recommend statin therapy in persons with a 10-year risk of 10 percent or greater.^43^ In 2011, the European Society of Cardiology and the European Atherosclerosis Society recommended use of lipid-lowering therapy (including, but not limited to, statins) based on assessed CVD risk, targeted to an LDL-C level of less than 70 mg/dL to less than 115 mg/dL, depending on the risk level.^44^ In 2012, the Canadian Cardiovascular Society recommended treatment with health behavior modification and statins in persons with high 10-year risk (≥20%), based on Framingham risk factors, or persons with moderate risk (≥10% to <20%) and an LDL-C level of 135.3 mg/dL or greater.^45^ Among persons with low risk (<10%), statin use is only recommended for those with genetic dyslipidemia or an LDL-C level of 193.3 mg/dL or greater. The International Atherosclerosis Society recommends no cholesterol-lowering medication for persons at low risk (<15% 10-year risk); for persons at higher risk, medication use is optional (10-year risk of 15% to 24%) or generally (10-year risk of 25% to 40%) or universally (10-year risk >40%) recommended.^46^ For primary prevention, the U.S. Department of Veterans Affairs/Department of Defense 2014 guideline recommends moderate-intensity statin therapy for persons with an estimated 10-year risk of 12 percent or greater, and shared decisionmaking for persons with a 10-year risk of 6 to 12 percent.^47^