# Appendix D Meta-Analysis Figures

Appendix D1 Meta-Analysis: Statins Versus Placebo on All-Cause Mortality

Note: See Appendix B for trial name abbreviations.

Appendix D1 is a forest plot titled Meta-Analysis: Statins Versus Placebo on All-Cause Mortality. Risk ratios were reported or calculated for 15 studies, with a pooled risk ratio of 0.86 (95% confidence interval, 0.80 to 0.93) and an overall I-squared value of 0%.

Appendix D2 Meta-Analysis: Statins Versus Placebo on Cardiovascular Mortality

Appendix D2 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Cardiovascular Mortality. Risk ratios were reported or calculated for 10 studies, with a pooled risk ratio of 0.82 (95% confidence interval, 0.71 to 0.94) and an overall I-squared value of 0%.

Appendix D3 Meta-Analysis: Statins Versus Placebo on Fatal and Nonfatal Stroke

Appendix D3 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Fatal and Nonfatal Stroke. Risk ratios were reported or calculated for 13 studies, with a pooled risk ratio of 0.71 (95% confidence interval, 0.62 to 0.82) and an overall I-squared value of 0%.

Appendix D4 Meta-Analysis: Statins Versus Placebo on Fatal and Nonfatal Myocardial Infarction

Appendix D4 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Fatal and Nonfatal Myocardial Infarction. Risk ratios were reported or calculated for 12 studies, with a pooled risk ratio of 0.64 (95% confidence interval, 0.57 to 0.71) and an overall I-squared value of 0%.

Appendix D5 Meta-Analysis: Statins Versus Placebo on Revascularization

Appendix D5 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Revascularization. Risk ratios were reported or calculated for 7 studies, with a pooled risk ratio of 0.63 (95% confidence interval, 0.56 to 0.72) and an overall I-squared value of 0%.

Appendix D6 Meta-Analysis: Statins Versus Placebo on Composite Cardiovascular Outcomes

Footnotes

^1^ CHD event, CVA or Ml

^2^ Fatal or nonfatal Ml, unstable angina or sudden cardiac death

^3^ Fatal CHD, nonfatal Ml, chronic stable angina, unstable angina, fatal and nonfatal heart failure

^4^ CV mortality, fatal or nonfatal Ml, nonfatal CVA revascularization, resuscitated cardiac arrest, unstable angina

^5^ Unspecified CV events

^6^ Fatal CHD, Ml, unstable angina or resuscitated cardiac arrest

^7^ Unspecified coronary events

^8^ CV mortality, nonfatal Ml, nonfatal CVA

^9^ Ml, sudden death, CVA, TIA or heart failure

^10^ CV mortality, nonfatal Ml, nonfatal CVA, unstable angina or revascularization

^11^ Fatal or nonfatal Ml, cardiac and sudden death, revascularization or angina

^12^ CV mortality or hospitalization for CV mobidlty

^13^ CHD death or nonfatal Ml

Appendix D6 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Composite Cardiovascular Outcomes. Risk ratios were reported or calculated for 13 studies, with a pooled risk ratio of 0.70 (95% confidence interval, 0.63 to 0.78) and an overall I-squared value of 36%.

Appendix D7 Funnel Plot: Risk of Bias in Randomized Trials of Statins Versus Placebo on All-Cause Mortality

Appendix D7 is titled Funnel Plot: Risk of Bias in Randomized, Controlled Trials of Statins Versus Placebo on All-Cause Mortality. There are circular symbols representing individual studies, plotted on an x-axis of risk ratios (from 0.01 to 100) and a y-axis of the standard error of the logarithm of the risk ratios (from 2 to 0). A dotted center line represents the pooled estimate, around which most studies fall.

Appendix D8 Funnel Plot: Risk of Bias in Randomized Trials of Statins Versus Placebo on Cardiovascular Mortality

Appendix D8 is titled Funnel Plot: Risk of Bias in Randomized, Controlled Trials of Statins Versus Placebo on Cardiovascular Mortality. There are circular symbols representing individual studies, plotted on an x-axis of risk ratios (from 0.01 to 100) and a y-axis of the standard error of the logarithm of the risk ratios (from 2 to 0). A dotted center line represents the pooled estimate, around which most studies fall, with 1 outlier.

Appendix D9 Funnel Plot: Risk of Bias in Randomized Trials of Statins Versus Placebo on Fatal and Nonfatal Stroke

Appendix D9 is titled Funnel Plot: Risk of Bias in Randomized, Controlled Trials of Statins Versus Placebo on Fatal and Nonfatal Stroke. There are circular symbols representing individual studies, plotted on an x-axis of risk ratios (from 0.01 to 100) and a y-axis of the standard error of the logarithm of the risk ratios (from 2 to 0). A dotted center line represents the pooled estimate, around which most studies fall.

Appendix D10 Funnel Plot: Risk of Bias in Randomized Trials of Statins Versus Placebo on Fatal and Nonfatal Myocardial Infarction

Appendix D10 is titled Funnel Plot: Risk of Bias in Randomized, Controlled Trials of Statins Versus Placebo on Fatal and Nonfatal Myocardial Infarction. There are circular symbols representing individual studies, plotted on an x-axis of risk ratios (from 0.01 to 100) and a y-axis of the standard error of the risk ratio (from 2 to 0). A dotted center line represents the pooled estimate, around which most studies fall.

Appendix D11 Funnel Plot: Risk of Bias in Randomized Trials of Statins Versus Placebo on Composite Cardiovascular Outcomes

Appendix D11 is titled Funnel Plot: Risk of Bias in Randomized, Controlled Trials of Statins Versus Placebo on Composite Cardiovascular Outcomes. There are circular symbols representing individual studies, plotted on an x-axis of risk ratio (from 0.01 to 1) and a y-axis of the standard error of the risk ratio (from 1 to 0). A dotted center line represents the pooled estimate, around which most studies fall.

Appendix D12 Meta-Analysis: Statins Versus Placebo on Withdrawals Due to Adverse Events

Appendix D12 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Withdrawal Due to Adverse Events. Risk ratios were reported or calculated for 9 studies, with a pooled risk ratio of 0.95 (95% confidence interval, 0.75 to 1.21) and an overall I-squared value of 86%.

Appendix D13 Meta-Analysis: Statins Versus Placebo on Serious Adverse Events

Appendix D13 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Serious Adverse Events. Risk ratios were reported or calculated for 7 studies, with a pooled risk ratio of 0.99 (95% confidence interval, 0.94 to 1.04) and an overall I-squared value of 0%.

Appendix D14 Meta-Analysis: Statins Versus Placebo on Any Cancer

Appendix D14 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Any Cancer. Risk ratios were reported or calculated for 10 studies, with a pooled risk ratio of 1.02 (95% confidence interval, 0.90 to 1.16) and an overall I-squared value of 43%.

Appendix D15 Meta-Analysis: Statins Versus Placebo on Fatal Cancer

Appendix D15 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Fatal Cancer. Risk ratios were reported or calculated for 5 studies, with a pooled risk ratio of 0.85 (95% confidence interval, 0.59 to 1.21) and an overall I-squared value of 61%.

Appendix D16 Meta-Analysis: Statins Versus Placebo on Incident Diabetes

Appendix D16 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Incident Diabetes. Risk ratios were reported or calculated for 6 studies, with a pooled risk ratio of 1.05 (95% confidence interval, 0.91 to 1.20) and an overall I-squared value of 52%.

Appendix D17 Meta-Analysis: Statins Versus Placebo on Myalgia

Appendix D17 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Myalgia. Risk ratios were reported or calculated for 8 studies, with a pooled risk ratio of 0.96 (95% confidence interval, 0.79 to 1.16) and an overall I-squared value of 42%.

Appendix D18 Meta-Analysis: Statins Versus Placebo on Rhabdomyolysis

Appendix D18 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Rhabdomyolysis. Risk ratios were reported or calculated for 8 studies, with a pooled risk ratio of 1.57 (95% confidence interval, 0.41 to 5.99) and an overall I-squared value of 0%.

Appendix D19 Meta-Analysis: Statins Versus Placebo on Myopathy

Appendix D19 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Myopathy. Risk ratios were reported or calculated for 4 studies, with a pooled risk ratio of 1.09 (95% confidence interval, 0.48 to 2.47) and an overall I-squared value of 0%.

Appendix D20 Meta-Analysis: Statins Versus Placebo on Liver Enzyme Abnormalities

Appendix D20 is a forest plot titled Meta-Analysis: Statins Versus Placebo on Liver Enzyme Abnormalities. Risk ratios were reported or calculated for 11 studies, with a pooled risk ratio of 1.10 (95% confidence interval, 0.90 to 1.35) and an overall I-squared value of 0%.