# Appendix C Evidence and Quality Tables

Appendix C1 Evidence Table of Randomized Trials of Statins

Appendix C2 Quality Assessment of Randomized Trials of Statins