# Appendix B Abbreviations of Trial Names

Abbreviation: Trial Name
ACAPS: Asymptomatic Carotid Artery Progression Study
AFCAPS/TexCAPS: Air Force/Texas Coronary Atherosclerosis Prevention Study
ASCOT-LLA: Anglo-Scandinavian Cardiac Outcomes Trial – Lipid Lowering Arm
ASPEN: Atorvastatin Study for Prevention of Coronary Heart Disease Endpoints in Non-insulin Dependent Diabetes Mellitus
ASTRONOMER: Aortic Stenosis Progression Observation: Measuring Effects of Rosuvastatin
CAIUS: Carotid Atherosclerosis Italian Ultrasound Study
CARDS: Collaborative Atorvastatin Diabetes Study
HOPE-3: Heart Outcomes Prevention Evaluation
HYRIM: Hypertension High Risk Management
JUPITER: Justification for the Use of Statins in Prevention: and Intervention Trial Evaluating Rosuvastatin
KAPS: Kuopio Atherosclerosis Prevention Study
MEGA: Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese
METEOR: Measuring Effects on Intima-Media Thickness: an Evaluation of Rosuvastatin
PREVEND-IT: Prevention of Renal and Vascular Endstage Disease Intervention Trial
WOSCOPS: West of Scotland Prevention Study Group