# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Randomized, Controlled Trials and Controlled Observational Studies

#### Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) and Cochrane Central Register of Controlled Trials

1. exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
2. (atorvastatin or fluvastatin or lovastatin or pitavastatin or pravastatin or rosuvastatin or simvastatin).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
3. (lipitor or lescol or mevacor or livalo or pravachol or crestor or zocor).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
4. 2 or 3
5. 1 or 4
6. exp Cardiovascular Diseases/
7. (cardiovascular or coronary or heart or mortality or CHD or CVD).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
8. 6 or 7
9. 5 and 8
10. Primary Prevention/
11. prevent$.mp.
12. 9 and (10 or 11)
13. limit 12 to humans
14. limit 13 to English language
15. limit 13 to abstracts
16. 14 or 15
17. limit 16 to (clinical trial, all or clinical trial or comparative study or controlled clinical trial or randomized controlled trial)
18. 16 and (random$ or control$ or cohort).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
19. 17 or 18

### Systematic Reviews

#### Ovid MEDLINE(R) without Revisions

1. exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
2. (atorvastatin or fluvastatin or lovastatin or pitavastatin or pravastatin or rosuvastatin or simvastatin).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
3. (lipitor or lescol or mevacor or livalo or pravachol or crestor or zocor).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
4. 2 or 3
5. 1 or 4
6. exp Cardiovascular Diseases/
7. (cardiovascular or coronary or heart or mortality or CHD or CVD).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
8. 6 or 7
9. 5 and 8
10. Primary Prevention/
11. prevent$.mp.
12. 9 and (10 or 11)
13. limit 12 to humans
14. limit 13 to English language
15. limit 13 to abstracts
16. 14 or 15
17. limit 16 to (meta analysis or systematic reviews)
18. limit 16 to evidence based medicine reviews
19. 17 or 18

#### Cochrane Database of Systematic Reviews

1. statin$.ti.
2. limit 1 to full systematic reviews

## Appendix A2 Inclusion and Exclusion Criteria

| Include | Exclude
Key Question 1. Benefits
Population | Asymptomatic adults (age ≥40 years) without prior CVD events (e.g., myocardial infarction, angina, revascularization, CVA, or transient ischemic attack), including persons who are at increased risk for CVD events based on 10-year or lifetime individualized CVD risk level or presence of specific CVD risk factors | Populations in other age groups or with a prior CVD-related event
Interventions | Statins | Other drugs or non-drug interventions (e.g., diet, exercise)
Comparators | No treatment or usual care without statin | Other comparators not listed as included
Outcomes | CHD and/or CVA-related morbidity or mortality; all-cause mortality | Intermediate outcomes (e.g., lipid levels, measures of atherosclerosis such as intima media thickness)
Study Design | Randomized clinical trials | Other study designs
Settings | Primary care or primary care–generalizable | Settings not generalizable to primary care; studies outside the stated timeframe
Key Question 2. Harms
Population | Asymptomatic adults (age ≥40 years) without prior CVD events (e.g., myocardial infarction, angina, revascularization, CVA, or transient ischemic attack), including persons who are at increased risk for CVD events based on 10-year or lifetime individualized CVD risk level or presence of specific CVD risk factors | Populations in other age groups or with a prior CVD-related event
Interventions | Statins | Other drugs or non-drug interventions (e.g., diet, exercise)
Comparators | Placebo | Other comparators not listed as included
Outcomes | Side effects from drug interventions, such as myopathy, rhabdomyolysis, myalgia, cognitive loss, diabetes, elevations in liver function tests or creatine phosphokinase levels | Adverse events not related to statin use
Study Design | Randomized clinical trials, and controlled observational studies reporting harms | Other study designs
Settings | Primary care or primary care–generalizable | Settings not generalizable to primary care; studies outside the stated timeframe
Key Question 3. Statin Potency
Population | Asymptomatic adults (age ≥40 years) without prior CVD events (e.g., myocardial infarction, angina, revascularization, CVA, or transient ischemic attack), including persons who are at increased risk for CVD events based on 10-year or lifetime individualized CVD risk level or presence of specific CVD risk factors | Populations in other age groups or with a prior CVD-related event
Interventions | Statins | Other drugs or non-drug interventions (e.g., diet, exercise)
Comparators | Higher vs. lower-potency statin therapy | Other comparators not listed as included
Outcomes | CHD- and/or CVA-related morbidity or mortality; all-cause mortality. Side effects from drug interventions, such as myopathy, rhabdomyolysis, myalgia, cognitive loss, diabetes, and elevations in liver function tests or creatine phosphokinase levels | Outcomes not listed as included
Study Design | Randomized clinical trials | Other study designs
Settings | Primary care or primary care–generalizable | Settings not generalizable to primary care; studies outside the stated timeframe

Abbreviations: CHD=coronary heart disease; CVA=cardiovascular accident (stroke); CVD=cardiovascular disease; KQ=key question.

## Appendix A3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Studies may be included for more than one KQ.

Abbreviations: CHD=coronary heart disease; CVA=cerebrovascular accident; CVD=cardiovascular disease; KQ=key question; LDL-C=low-density lipoprotein cholesterol.

Note: Indirect evidence not shown in figure.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 3007 abstracts of potentially relevant articles were identified through MEDLINE and Cochrane databases, while 346 articles were reviewed at the full-text level after excluding 2661 nonrelevant abstracts and background articles. From the 346 articles reviewed for inclusion, 291 were excluded. Articles were excluded due to wrong population (34), wrong population due to >10% history of cardiovascular disease at baseline (38), wrong intervention (8), wrong outcomes (46), wrong study design for key question (39), wrong publication type (45), not English language but possibly relevant (3), in systematic review but not directly used (2), wrong comparison (18), abstract only (2), or using original studies instead (56). After excluding these studies, 21 studies in 55 publications were included that provide evidence for the key questions, as follows: 19 trials for Key Question 1a, 0 trials (direct evidence) for Key Question 1b, 7 trials for Key Question 1c, 17 trials and 2 observational studies for Key Question 2, and 3 trials (direct evidence) for Key Question 3.

## Appendix A4 Excluded Studies With Reasons for Exclusion

Key to Exclusion Codes

Code 3 | Wrong population
Code 4 | Wrong intervention
Code 5 | Wrong outcomes
Code 6 | Wrong study design for Key Question
Code 7 | Not a study
Code 8 | Not English language but possibly relevant
Code 9 | Wrong population (proportion of patients with prior CVD events at baseline was >10%)
Code 12 | In systematic review, not directly used
Code 13 | Wrong comparison
Code 14 | Using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication)
Code 15 | Unable to obtain full-text (abstract only)

(1997). Baseline risk factors and their association with outcome in the West of Scotland Coronary Prevention Study. The West of Scotland Coronary Prevention Study Group. Am J Cardiol.
(1997). Compliance and adverse event withdrawal: their impact on the West of Scotland Coronary Prevention Study. Eur Heart J.
(1993). Effects of pravastatin in patients with serum total cholesterol levels from 5.2 to 7.8 mmol/liter (200 to 300 mg/dl) plus two additional atherosclerotic risk factors. The Pravastatin Multinational Study Group for Cardiac Risk Patients. Am J Cardiol.
(1999). The effects of pravastatin on hospital admission in hypercholesterolemic middle-aged men: West of Scotland Coronary Prevention Study. J Am Coll Cardiol.
(1998). Influence of pravastatin and plasma lipids on clinical events in the West of Scotland Coronary Prevention Study (WOSCOPS). Circulation.
(2000). Pravastatin use and risk of coronary events and cerebral infarction in Japanese men with moderate hypercholesterolemia: the Kyushu Lipid Intervention Study. J Atheroscler Thromb.
(1998). Prevention of cardiovascular events and death with pravastatin in patients with coronary heart disease and a broad range of initial cholesterol levels. The Long-Term Intervention with Pravastatin in Ischaemic Disease (LIPID) Study Group. N Engl J Med.
(2009). Rosuvastatin for cardiovascular prevention: too many uncertainties. Prescrire Int.
(1995). Screening experience and baseline characteristics in the West of Scotland Coronary Prevention Study. The WOSCOPS Study Group. West of Scotland Coronary Prevention Study. Am J Cardiol.
Afonso L, Veeranna V, Zalawadiya S, et al. (2011). Predictors of residual cardiovascular risk in patients on statin therapy for primary prevention. Cardiology.
Agarwal V, Phung OJ, Tongbram V, et al. (2010). Statin use and the prevention of venous thromboembolism: a meta-analysis. Int J Clin Pract.
Alberton M, Wu P, Druyts E, et al. (2012). Adverse events associated with individual statin treatments for cardiovascular disease: an indirect comparison meta-analysis. QJM.
ALLHAT Officers and Coordinators for the ALLHAT Collaborative Research Group. (2002). Major outcomes in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin vs usual care: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT-LLT). JAMA.
Amarenco P. (2007). Atorvastatin in prevention of stroke and transient ischaemic attack. Expert Opin Pharmacother.
Amarenco P, Benavente O, Goldstein LB, et al. (2009). Results of the Stroke Prevention by Aggressive Reduction in Cholesterol Levels (SPARCL) trial by stroke subtypes. Stroke.
Amarenco P, Goldstein LB, Callahan A, et al. (2009). Baseline blood pressure, low- and high-density lipoproteins, and triglycerides and the risk of vascular events in the Stroke Prevention by Aggressive Reduction in Cholesterol Levels (SPARCL) trial. Atherosclerosis.
Amarenco P, Goldstein LB, Messig M, et al. (2009). Relative and cumulative effects of lipid and blood pressure control in the Stroke Prevention by Aggressive Reduction in Cholesterol Levels trial. Stroke.
Amarenco P, Goldstein LB, Sillesen H, et al. (2010). Coronary heart disease risk in patients with stroke or transient ischemic attack and no known coronary heart disease: findings from the Stroke Prevention by Aggressive Reduction in Cholesterol Levels (SPARCL) trial. Stroke.
Amarenco P, Goldstein LB, Szarek M, et al. (2007). Effects of intense low-density lipoprotein cholesterol reduction in patients with stroke or transient ischemic attack: the Stroke Prevention by Aggressive Reduction in Cholesterol Levels (SPARCL) trial. Stroke.
Amarenco P, Labreuche J. (2009). Lipid management in the prevention of stroke: review and updated meta-analysis of statins for stroke prevention. Lancet neurol.
Amarenco P, Tonkin AM. (2004). Statins for stroke prevention: disappointment and hope. Circulation.
Amarenco P, Tonkin AM. (2004). Statins prevent strokes in high-risk patients. J Fam Pract.
(2007). Establishing the benefit of statins in low-to-moderate-risk primary prevention: The Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Atheroscler Suppl.
(2005). Atorvastatin significantly reduces cardiovascular disease and stroke in people with type 2 diabetes. Evidence-based Healthcare & Public Health.
Arad Y, Spadaro LA, Roth M, et al. (2005). Treatment of asymptomatic adults with elevated coronary calcium scores with atorvastatin, vitamin C, and vitamin E: the St. Francis Heart Study randomized clinical trial. J Am Coll Cardiol.
Arampatzis CA, Goedhart D, Serruys PW, et al. (2005). Fluvastatin reduces the impact of diabetes on long-term outcome after coronary intervention--a Lescol Intervention Prevention Study (LIPS) substudy. Am Heart J.
Ardigo D, Vaccaro O, Cavalot F, et al. (2014). Effectiveness of treat-to-target strategy for LDL-cholesterol control in type 2 diabetes: Post-hoc analysis of data from the MIND.IT study. Eur J Prev Cardiolog.
Ardoin SP, Schanberg LE, Sandborg CI, et al. (2014). Secondary analysis of APPLE study suggests atorvastatin may reduce atherosclerosis progression in pubertal lupus patients with higher C reactive protein. Ann Rheum Dis.
Armani A, Toth PP. (2006). The CARDS trial: diabetic patients dealt a winning hand. CuRR, Atheroscler Rep.
Armani A, Toth PP. (2007). SPARCL: the glimmer of statins for stroke risk reduction. CuRR, Atheroscler Rep.
Armitage J, Bowman L, Collins R, et al. (2009). Effects of simvastatin 40 mg daily on muscle and liver adverse effects in a 5-year randomized placebo-controlled trial in 20,536 high-risk people. BMC Clin Pharmacol.
Arsenault BJ, Barter P, DeMicco DA, et al. (2014). Prediction of cardiovascular events in statin-treated stable coronary patients of the treating to new targets randomized controlled trial by lipid and non-lipid biomarkers. PLoS ONE.
Athyros VG, Tziomalos K, Karagiannis A, et al. (2010). Atorvastatin: safety and tolerability. Expert Opin Drug Saf.
Aung PP, Maxwell HG, Jepson RG, et al. (2007). Lipid-lowering for peripheral arterial disease of the lower limb. Cochrane Database Syst Rev.
Baigent C, Landray M, Leaper C, et al. (2005). First United Kingdom Heart and Renal Protection (UK-HARP-I) study: biochemical efficacy and safety of simvastatin and safety of low-dose aspirin in chronic kidney disease. Am J Kidney Dis.
Bak AA, Huizer J, Leijten PA, et al. (1998). Diet and pravastatin in moderate hypercholesterolaemia: a randomized trial in 215 middle-aged men free from cardiovascular disease. J Intern Med.
Ballard KD, Parker BA, Capizzi JA, et al. (2013). Increases in creatine kinase with atorvastatin treatment are not associated with decreases in muscular performance. Atherosclerosis.
Bang CN, Gislason GH, Greve AM, et al. (2014). Statins reduce new-onset atrial fibrillation in a first-time myocardial infarction population: a nationwide propensity score-matched study. Eur J Prev Cardiolog.
Bang CN, Okin PM. (2014). Statin treatment, new-onset diabetes, and other adverse effects: a systematic review. CuRR, Cardiol Rep.
Barylski M, Nikfar S, Mikhailidis DP, et al. (2013). Statins decrease all-cause mortality only in CKD patients not requiring dialysis therapy--a meta-analysis of 11 randomized controlled trials involving 21,295 participants. Pharmacol Res.
Barylski M, Nikolic D, Banach M, et al. (2014). Statins and new-onset diabetes. CuRR, Pharm Des.
Bays H, Cohen DE, Chalasani N, et al. (2014). An assessment by the Statin Liver Safety Task Force: 2014 update. J Clin Lipidol.
Beishuizen ED, Jukema JW, Tamsma JT, et al. (2005). No effect of statin therapy on silent myocardial ischemia in patients with type 2 diabetes without manifest cardiovascular disease. Diabetes Care.
Bellamy MF, Pellikka PA, Klarich KW, et al. (2002). Association of cholesterol levels, hydroxymethylglutaryl coenzyme-A reductase inhibitor treatment, and progression of aortic stenosis in the community. J Am Coll Cardiol.
Berthold HK, Unverdorben S, Zittermann A, et al. (2004). Age-dependent effects of atorvastatin on biochemical bone turnover markers: a randomized controlled trial in postmenopausal women. Osteoporos Int.
Bjarnason NH, Riis BJ, Christiansen C. (2001). The effect of fluvastatin on parameters of bone remodeling. Osteoporos Int.
Blankenhorn DH, Azen SP, Kramsch DM, et al. (1993). Coronary angiographic changes with lovastatin therapy. The Monitored Atherosclerosis Regression Study (MARS). Ann Intern Med.
Blauw GJ, Lagaay AM, Smelt AH, et al. (1997). Stroke, statins, and cholesterol. A meta-analysis of randomized, placebo-controlled, double-blind trials with HMG-CoA reductase inhibitors. Stroke.
Boekholdt SM, Hovingh GK, Mora S, et al. (2014). Very low levels of atherogenic lipoproteins and the risk for cardiovascular events: a meta-analysis of statin trials. J Am Coll Cardiol.
Bogiatzi C, Hackam DG, McLeod AI, et al. (2014). Secular trends in ischemic stroke subtypes and stroke risk factors. Stroke.
Bouchard M-H, Dragomir A, Blais L, et al. (2007). Impact of adherence to statins on coronary artery disease in primary prevention. Br J Clin Pharmacol.
Bradford RH, Shear CL, Chremos AN, et al. (1991). Expanded Clinical Evaluation of Lovastatin (EXCEL) study results. I. Efficacy in modifying plasma lipoproteins and adverse event profile in 8245 patients with moderate hypercholesterolemia. Arch Intern Med.
Browning JD. (2006). Statins and hepatic steatosis: perspectives from the Dallas Heart Study. Hepatology.
Bruckert E, Ferrieres J. (2014). Evidence supporting primary prevention of cardiovascular diseases with statins: Gaps between updated clinical results and actual practice. Arch Cardiovasc Dis.
Bruckert E, Lievre M, Giral P, et al. (2003). Short-term efficacy and safety of extended-release fluvastatin in a large cohort of elderly patients. Am J Geriatr Cardiol.
Bukkapatnam RN, Gabler NB, Lewis WR. (2010). Statins for primary prevention of cardiovascular mortality in women: a systematic review and meta-analysis. Prev Cardiol.
Bulbulia R, Bowman L, Wallendszus K, et al. (2011). Effects on 11-year mortality and morbidity of lowering LDL cholesterol with simvastatin for about 5 years in 20,536 high-risk individuals: a randomised controlled trial. Lancet.
Calderon RM, Cubeddu LX, Goldberg RB, et al. (2010). Statins in the treatment of dyslipidemia in the presence of elevated liver aminotransferase levels: a therapeutic dilemma. Mayo Clin Proc.
Callahan A, Amarenco P, Goldstein LB, et al. (2011). Risk of stroke and cardiovascular events after ischemic stroke or transient ischemic attack in patients with type 2 diabetes or metabolic syndrome: secondary analysis of the Stroke Prevention by Aggressive Reduction in Cholesterol Levels (SPARCL) trial. Arch Neurol.
Carlsson CM, Papcke-Benson K, Carnes M, et al. (2002). Health-related quality of life and long-term therapy with pravastatin and tocopherol (vitamin E) in older adults. Drugs Aging.
Chang J, Ahn JE, Landsman N, et al. (2013). Efficacy of contemporary medical management for asymptomatic carotid artery stenosis. Am Surg.
Chang YH, Hsieh MC, Wang CY, et al. (2013). Reassessing the benefits of statins in the prevention of cardiovascular disease in diabetic patients--a systematic review and meta-analysis. Rev.
Charlton-Menys V, Betteridge DJ, Colhoun H, et al. (2009). Apolipoproteins, cardiovascular risk and statin response in type 2 diabetes: the Collaborative Atorvastatin Diabetes Study (CARDS). Diabetologia.
Cheezum MK, Hulten EA, Smith RM, et al. (2013). Changes in preventive medical therapies and CV risk factors after CT angiography. JACC Cardiovasc Imaging.
Chen YH, Feng B, Chen ZW. (2012). Statins for primary prevention of cardiovascular and cerebrovascular events in diabetic patients without established cardiovascular diseases: a meta-analysis. Exp Clin Endocrinol Diabetes.
Cho Y, Choe E, Lee YH, et al. (2015). Risk of diabetes in patients treated with HMG-CoA reductase inhibitors. Metabolism.
Cholesterol Treatment Trialists C, Mihaylova B, Emberson J, et al. (2012). The effects of lowering LDL cholesterol with statin therapy in people at low risk of vascular disease: meta-analysis of individual data from 27 randomised trials. Lancet.
Clearfield M, Downs JR, Lee M, et al. (2005). Implications from the Air Force/Texas Coronary Atherosclerosis Prevention Study for the Adult Treatment Panel III guidelines. Am J Cardiol.
Colhoun HM, Betteridge DJ, Durrington PN. (2004). Atorvastatin delays first MI for patients with diabetes. J Fam Pract.
Colhoun HM, Betteridge DJ, Durrington PN, et al. (2009). Effects of atorvastatin on kidney outcomes and cardiovascular disease in patients with diabetes: an analysis from the Collaborative Atorvastatin Diabetes Study (CARDS). Am J Kidney Dis.
Collins R, Armitage J, Parish S, et al. (2003). MRC/BHF Heart Protection Study of cholesterol-lowering with simvastatin in 5963 people with diabetes: a randomised placebo-controlled trial. Lancet.
Colquhoun D, Keech A, Hunt D, et al. (2004). Effects of pravastatin on coronary events in 2073 patients with low levels of both low-density lipoprotein cholesterol and high-density lipoprotein cholesterol: results from the LIPID study. Eur Heart J.
Conrad MF, Baloum V, Mukhopadhyay S, et al. (2013). Progression of asymptomatic carotid stenosis despite optimal medical therapy. J Vasc Surg.
Corrao G, Ibrahim B, Nicotra F, et al. (2014). Statins and the risk of diabetes: evidence from a large population-based cohort study. Diabetes Care.
Crouse JR, Byington RP, Bond MG, et al. (1995). Pravastatin, Lipids, and Atherosclerosis in the Carotid Arteries (PLAC-II). Am J Cardiol.
Cui Y, Watson DJ, Girman CJ, et al. (2009). Effects of increasing high-density lipoprotein cholesterol and decreasing low-density lipoprotein cholesterol on the incidence of first acute coronary events (from the Air Force/Texas Coronary Atherosclerosis Prevention Study). Am J Cardiol.
Cushman M, McClure LA, Lakoski SG, et al. (2010). Eligibility for statin therapy by the JUPITER trial criteria and subsequent mortality. Am J Cardiol.
Daida H, Nohara R, Hata M, et al. (2014). Can intensive lipid-lowering therapy improve the carotid intima-media thickness in Japanese subjects under primary prevention for cardiovascular disease? The JART and JART extension subanalysis. J Atheroscler Thromb.
de Vries FM, Denig P, Pouwels KB, et al. (2012). Primary prevention of major cardiovascular and cerebrovascular events with statins in diabetic patients: a meta-analysis. Drugs.
DeFilippis AP, Bansal S, Blumenthal RS. (2008). Long-term follow-up of the West of Scotland Coronary Prevention Study. N Engl J Med.
Deharo P, Pankert M, Quilici J, et al. (2014). Safety and effectiveness of the association ezetimibe-statin (E-S) versus high dose rosuvastatin after acute coronary syndrome: The SAFE-ES study. Ann Cardiol Angeiol (Paris).
Dey S, Mukherjee D. (2003). Clinical perspectives on the role of anti-platelet and statin therapy in patients with vascular diseases. CuRR, Vasc Pharmacol.
Di Lullo L, Addesse R, Comegna C, et al. (2005). Effects of fluvastatin treatment on lipid profile, C-reactive protein trend, and renal function in dyslipidemic patients with chronic renal failure. Adv Ther.
Diercks GF, Janssen WM, van Boven AJ, et al. (2000). Rationale, design, and baseline characteristics of a trial of prevention of cardiovascular and renal disease with fosinopril and pravastatin in nonhypertensive, nonhypercholesterolemic subjects with microalbuminuria (the Prevention of REnal and Vascular ENdstage Disease Intervention Trial [PREVEND IT]). Am J Cardiol.
Doggen CJ, Lemaitre RN, Smith NL, et al. (2004). HMG CoA reductase inhibitors and the risk of venous thrombosis among postmenopausal women. J Thromb Haemost.
Drewes YM, Poortvliet RK, Blom JW, et al. (2014). Homocysteine levels and treatment effect in the PROspective Study of Pravastatin in the Elderly at Risk. J Am Geriatr Soc.
Everett BM, Glynn RJ, MacFadyen JG, et al. (2010). Rosuvastatin in the prevention of stroke among men and women with elevated levels of C-reactive protein: justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER). Circulation.
Fabregas M, Berges I, Fina F, et al. (2014). Effectiveness of an intervention designed to optimize statins use: a primary prevention randomized clinical trial. BMC Fam Pract.
Fang W-t, Li H-J, Zhang H, et al. (2012). The role of statin therapy in the prevention of atrial fibrillation: a meta-analysis of randomized controlled trials. Br J Clin Pharmacol.
Fassett RG, Robertson IK, Ball MJ, et al. (2010). Effect of atorvastatin on kidney function in chronic kidney disease: a randomised double-blind placebo-controlled trial. Atherosclerosis.
Fauchier L, Clementy N, Babuty D. (2013). Statin therapy and atrial fibrillation: systematic review and updated meta-analysis of published randomized controlled trials. CuRR, Opin Cardiol.
Fauchier L, Pierre B, de Labriolle A, et al. (2008). Antiarrhythmic effect of statin therapy and atrial fibrillation a meta-analysis of randomized controlled trials. J Am Coll Cardiol.
Feldman HH, Doody RS, Kivipelto M, et al. (2010). Randomized controlled trial of atorvastatin in mild to moderate Alzheimer disease: LEADe. Neurology.
Fellstrom B, Holdaas H, Jardine AG, et al. (2007). Effect of rosuvastatin on outcomes in chronic haemodialysis patients: baseline data from the AURORA study. Kidney Blood Press Res.
Fellstrom B, Holdaas H, Jardine AG, et al. (2009). Cardiovascular disease in patients with renal disease: the role of statins. CuRR, Med Res Opin.
Fellstrom B, Zannad F, Schmieder R, et al. (2005). Effect of rosuvastatin on outcomes in chronic haemodialysis patients : design and rationale of the AURORA study. CuRR, Control Trials Cardiovasc Med.
Fellstrom BC, Jardine AG, Schmieder RE, et al. (2009). Rosuvastatin and cardiovascular events in patients undergoing hemodialysis. N Engl J Med.
Feng Z, Rui H, Jingyi R, et al. The relationship between lipid-lowing efficacy, plasma concentrations and safety of short-term simvastatin and atorvastatin therapy with different dosages in Chinese population. J Am Coll Cardiol.
Ford I, Murray H, Packard CJ, et al. (2007). Long-term follow-up of the West of Scotland Coronary Prevention Study. N Engl J Med.
Ford I, Murray H, McCowan C, et al. (2016). Long-term safety and efficacy of lowering low-density lipoprotein cholesterol with statin therapy 20-year follow-up of west of Scotland coronary prevention study. Circulation.
Freeman DJ, Robertson M, Brown EA, et al. (2011). Incident venous thromboembolic events in the Prospective Study of Pravastatin in the Elderly at Risk (PROSPER). BMC geriatr.
Fu JH, Mok V, Lam W, et al. (2010). Effects of statins on progression of subclinical brain infarct. Cerebrovasc Dis.
Gagne JJ, Choudhry NK, Kesselheim AS, et al. (2014). Comparative effectiveness of generic and brand-name statins on patient outcomes: a cohort study. Ann Intern Med.
Gehlbach P, Li T, Hatef E. (2015). Statins for age-related macular degeneration. Cochrane Database Syst Rev.
Genest J, Pedersen TR. (2003). Prevention of cardiovascular ischemic events: high-risk and secondary prevention. Circulation.
Ghattas AE, Pimenta J. (2007). Efficacy of atorvastatin when not administered daily. Arq Bras Cardiol.
Glynn RJ, Danielson E, Fonseca FAH, et al. (2009). A randomized trial of rosuvastatin in the prevention of venous thromboembolism. N Engl J Med.
Goldfine AB. (2012). Statins: Is it really time to reasses benefits and risks?. N Engl J Med.
Goldstein LB, Amarenco P, Szarek M, et al. (2008). Hemorrhagic stroke in the Stroke Prevention by Aggressive Reduction in Cholesterol Levels study. Neurology.
Gotto AM. (2000). Insights on treating an over-the-counter-type subgroup: data from the Air Force/Texas Coronary Atherosclerosis Prevention Study Population. Am J Cardiol.
Gotto AM. (1999). Lipid management in patients at moderate risk for coronary heart disease: insights from the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Am J Med.
Gotto AM, Boccuzzi SJ, Cook JR, et al. (2000). Effect of lovastatin on cardiovascular resource utilization and costs in the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). AFCAPS/TexCAPS Research Group. Am J Cardiol.
Grant RW, Meigs JB. (2007). Prevalence and treatment of low HDL cholesterol among primary care patients with type 2 diabetes: an unmet challenge for cardiovascular risk reduction. Diabetes Care.
Group HPSC. (2007). Randomized trial of the effects of cholesterol-lowering with simvastatin on peripheral vascular and other major vascular outcomes in 20,536 people with peripheral arterial disease and other high-risk conditions. J Vasc Surg.
Guclu F, Ozmen B, Hekimsoy Z, et al. (2004). Effects of a statin group drug, pravastatin, on the insulin resistance in patients with metabolic syndrome. Biomed Pharmacother.
Gupta R, Plantinga LC, Fink NE, et al. (2007). Statin use and sepsis events [corrected] in patients with chronic kidney disease. JAMA.
Gutierrez J, Ramirez G, Rundek T, et al. (2012). Statin therapy in the prevention of recurrent cardiovascular events: a sex-based meta-analysis. Arch Intern Med.
Guyton JR, Bays HE, Grundy SM, et al. (2014). An assessment by the Statin Intolerance Panel: 2014 update. J Clin Lipidol.
Hackam DG. (2004). Should a statin be routinely prescribed for primary prevention of cardiovascular disease in diabetes mellitus?. CMAJ.
Han Y. (2011). Multicenter randomized controlled study of rosuvastatin for prevention of contrast induced acute kidney injury in patients with diabetes and slight to moderate renal insufficiency (TRACK-D).
Han Y, Zhu G, Han L, et al. (2014). Short-term rosuvastatin therapy for prevention of contrast-induced acute kidney injury in patients with diabetes and chronic kidney disease. J Am Coll Cardiol.
Hayashi T, Kubota K, Kawashima S, et al. (2014). Efficacy of HMG-CoA reductase inhibitors in the prevention of cerebrovascular attack in 1016 patients older than 75 years among 4014 type 2 diabetic individuals. Int J Cardiol.
Heart Protection Study Collaborative G. (2002). MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet.
Heart Protection Study Collaborative Group. (2005). The effects of cholesterol lowering with simvastatin on cause-specific mortality and on cancer incidence in 20,536 high-risk people: a randomised placebo-controlled trial [ISRCTN48489393]. BMC Med.
Hedblad B, Wikstrand J, Janzon L, et al. (2001). Low-dose metoprolol CR/XL and fluvastatin slow progression of carotid intima-media thickness: Main results from the Beta-Blocker Cholesterol-Lowering Asymptomatic Plaque Study (BCAPS). Circulation.
Herd JA, Ballantyne CM, Farmer JA, et al. (1997). Effects of fluvastatin on coronary atherosclerosis in patients with mild to moderate cholesterol elevations (Lipoprotein and Coronary Atherosclerosis Study [LCAS]). Am J Cardiol.
Herrington DM, Vittinghoff E, Lin F, et al. (2002). Statin therapy, cardiovascular events, and total mortality in the Heart and Estrogen/Progestin Replacement Study (HERS). Circulation.
Hippisley-Cox J, Coupland C. (2010). Unintended effects of statins in men and women in England and Wales: population based cohort study using the QResearch database. BMJ.
Hitman GA, Colhoun H, Newman C, et al. (2007). Stroke prediction and stroke prevention with atorvastatin in the Collaborative Atorvastatin Diabetes Study (CARDS). Diabet Med.
Hlatky M. (2011). The cost-effectiveness of rosuvastatin therapy JUPITER (justification for the use of statins in prevention: an intervention trial evaluating rosuvastatin). J Am Coll Cardiol.
Holdaas H, Fellstrom B, Holme I, et al. (2001). Effects of fluvastatin on cardiac events in renal transplant patients: ALERT (Assessment of Lescol in Renal Transplantation) study design and baseline data. J Cardiovasc Risk.
Holmberg B, Brannstrom M, Bucht B, et al. (2005). Safety and efficacy of atorvastatin in patients with severe renal dysfunction. Scand J Urol Nephrol.
Hong SJ, Chang HJ, Park S, et al. (2013). Impact of atorvastatin treatment in first-degree relatives of patients with premature coronary artery disease with endothelial dysfunction: a double-blind, randomized, placebo-controlled crossover trial. Clin Cardiol.
Huang CC, Chan WL, Chen YC, et al. (2011). Statin use and hospitalization in patients with chronic obstructive pulmonary disease: a nationwide population-based cohort study in Taiwan. Clin Ther.
Huerta C, Johansson S, Wallander MA, et al. (2007). Risk factors and short-term mortality of venous thromboembolism diagnosed in the primary care setting in the United Kingdom. Arch Intern Med.
Ito MK. (2012). Dyslipidemia: management using optimal lipid-lowering therapy. Ann Pharmacother.
Izzo R, de Simone G, Trimarco V, et al. (2013). Primary prevention with statins and incident diabetes in hypertensive patients at high cardiovascular risk. Nutr Metab Cardiovasc Dis.
Jonathan E, Derrick B, Emma L, et al. (2011). C-reactive protein concentration and the vascular benefits of statin therapy: an analysis of 20,536 patients in the Heart Protection Study. Lancet.
Jukema JW, Bruschke AV, van Boven AJ, et al. (1995). Effects of lipid lowering by pravastatin on progression and regression of coronary artery disease in symptomatic men with normal to moderately elevated serum cholesterol levels. The Regression Growth Evaluation Statin Study (REGRESS). Circulation.
Karas RH, Kashyap ML, Knopp RH, et al. (2008). Long-term safety and efficacy of a combination of niacin extended release and simvastatin in patients with dyslipidemia: the OCEANS study. Am J Cardiovasc Drugs.
Karimi S, Hough A, Beckey C, et al. (2010). Results of a safety initiative for patients on concomitant amiodarone and simvastatin therapy in a Veterans Affairs medical center. J Manage Care Pharm.
Kaur N, Pandey A, Negi H, et al. (2014). Effect of HDL-raising drugs on cardiovascular outcomes: a systematic review and meta-regression. PLoS ONE.
Kim J, McEvoy JW, Nasir K, et al. (2014). Critical review of high-sensitivity C-reactive protein and coronary artery calcium for the guidance of statin allocation: head-to-head comparison of the JUPITER and St. Francis Heart Trials. Circ Cardiovasc Qual Outcomes.
Kinsella A, Raza A, Kennedy S, et al. (2011). The impact of high-dose statin therapy on transendothelial neutrophil migration and serum cholesterol levels in healthy male volunteers. Eur J Clin Pharmacol.
Kitzmiller JP, Sullivan DM, Phelps MA, et al. (2013). CYP3A4/5 combined genotype analysis for predicting statin dose requirement for optimal lipid control. Drug Metabol Drug Interact.
Kizer JR, Madias C, Wilner B, et al. (2010). Relation of different measures of low-density lipoprotein cholesterol to risk of coronary artery disease and death in a meta-regression analysis of large-scale trials of statin therapy. Am J Cardiol.
Koizumi J, Shimizu M, Miyamoto S, et al. (2002). Effect of pravastatin-induced LDL-cholesterol reduction on coronary heart disease and cerebrovascular disease in Japanese: Hokuriku lipid coronary heart disease study-pravastatin atherosclerosis trial (Holicos-PAT). J Atheroscler Thromb.
Kokudai M, Inui N, Takeuchi K, et al. (2009). Effects of statins on the pharmacokinetics of midazolam in healthy volunteers. J Clin Pharmacol.
Kostis WJ, Cheng JQ, Dobrzynski JM, et al. (2012). Meta-analysis of statin effects in women versus men. J Am Coll Cardiol.
Kriekard P, Gharacholou SM, Peterson ED. (2009). Primary and secondary prevention of cardiovascular disease in older adults: a status report. Clin Geriatr Med.
Lacut K, Le Gal G, Abalain JH, et al. (2008). Differential associations between lipid-lowering drugs, statins and fibrates, and venous thromboembolism: role of drug induced homocysteinemia?. Thromb Res.
Lauer MS. (2007). Primary prevention of atherosclerotic cardiovascular disease: the high public burden of low individual risk. JAMA.
Lee DH, Markwardt S, Goeres L, et al. (2014). Statins and physical activity in older men: the osteoporotic fractures in men study. JAMA Intern Med.
Lee JD, Morrissey JR, Mikhailidis DP, et al. (2005). CARDS on the table: should everybody with type 2 diabetes take a statin?. CuRR, Med Res Opin.
Lemaitre RN, Psaty BM, Heckbert SR, et al. (2002). Therapy with hydroxymethylglutaryl coenzyme a reductase inhibitors (statins) and associated risk of incident cardiovascular events in older adults: evidence from the Cardiovascular Health Study. Arch Intern Med.
Leuschen J, Mortensen EM, Frei CR, et al. (2013). Association of statin use with cataracts: a propensity score-matched analysis. JAMA Ophthalmol.
Lewis JH, Mortensen ME, Zweig S, et al. (2007). Efficacy and safety of high-dose pravastatin in hypercholesterolemic patients with well-compensated chronic liver disease: Results of a prospective, randomized, double-blind, placebo-controlled, multicenter trial. Hepatology.
Li L, Sun T, Zhang P, et al. (2011). Statins for primary prevention of venous thromboembolism. Cochrane Database Syst Rev.
Li L, Zhang P, Tian JH, et al. (2014). Statins for primary prevention of venous thromboembolism. Cochrane Database Syst Rev.
Logue J, Murray HM, Welsh P, et al. (2011). Obesity is associated with fatal coronary heart disease independently of traditional risk factors and deprivation. Heart.
Lv HL, Jin DM, Liu M, et al. (2014). Long-term efficacy and safety of statin treatment beyond six years: a meta-analysis of randomized controlled trials with extended follow-up. Pharmacol Res.
Lye M, Valacio R, Reckless JP, et al. (1998). Elderly patients with hypercholesterolaemia: a double-blind study of the efficacy, safety and tolerability of fluvastatin. Coron Artery Dis.
Mabuchi H, Kita T, Matsuzaki M, et al. (2002). Large scale cohort study of the relationship between serum cholesterol concentration and coronary events with low-dose simvastatin therapy in Japanese patients with hypercholesterolemia and coronary heart disease: secondary prevention cohort study of the Japan Lipid Intervention Trial (J-LIT). Circ J.
Maitland-van der Zee AH, Boerwinkle E, Arnett DK, et al. (2007). Absence of an interaction between the angiotensin-converting enzyme insertion-deletion polymorphism and pravastatin on cardiovascular disease in high-risk hypertensive patients: the Genetics of Hypertension-Associated Treatment (GenHAT) study. Am Heart J.
Maitland-van der Zee AH, Lynch A, Boerwinkle E, et al. (2008). Interactions between the single nucleotide polymorphisms in the homocysteine pathway (MTHFR 677C>T, MTHFR 1298 A>C, and CBSins) and the efficacy of HMG-CoA reductase inhibitors in preventing cardiovascular disease in high-risk patients of hypertension: the GenHAT study. Pharmacogenet Genomics.
Maitland-van der Zee AH, Peters BJ, Lynch AI, et al. (2009). The effect of nine common polymorphisms in coagulation factor genes (F2, F5, F7, F12 and F13 ) on the effectiveness of statins: the GenHAT study. Pharmacogenet Genomics.
Maitland-van der Zee AH, Stricker BH, Klungel OH, et al. (2002). The effectiveness of hydroxy-methylglutaryl coenzyme A reductase inhibitors (statins) in the elderly is not influenced by apolipoprotein E genotype. Pharmacogenetics.
Mancini GB. (1995). Rev Esp Cardiol.
Manktelow BN, Potter JF. (2009). Interventions in the management of serum lipids for preventing stroke recurrence. Cochrane Database Syst Rev.
Mansi IA, Mortensen EM, Pugh MJ, et al. (2013). Incidence of musculoskeletal and neoplastic diseases in patients on statin therapy: results of a retrospective cohort analysis. Am J Med Sci.
Margolis KL, Davis BR, Baimbridge C, et al. (2013). Long-term follow-up of moderately hypercholesterolemic hypertensive patients following randomization to pravastatin vs usual care: the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT-LLT). J Clin Hypertens (Greenwich).
Margolis KL, Dunn K, Simpson LM, et al. (2009). Coronary heart disease in moderately hypercholesterolemic, hypertensive black and non-black patients randomized to pravastatin versus usual care: the antihypertensive and lipid lowering to prevent heart attack trial (ALLHAT-LLT). Am Heart J.
Martinez C, Legrand V, Kulbertus H. (1995). Rev Med Liege.
Matsushima T, Nakaya N, Mizuno K, et al. (2012). The effect of low-dose pravastatin in metabolic syndrome for primary prevention of cardiovascular disease in Japan: a post hoc analysis of the MEGA study. J Cardiovasc Pharmacol Ther.
Matsushita Y, Sugihara M, Kaburagi J, et al. (2010). Pravastatin use and cancer risk: a meta-analysis of individual patient data from long-term prospective controlled trials in Japan. Pharmacoepidemiol Drug Saf.
Matsuzaki M, Kita T, Mabuchi H, et al. (2002). Large scale cohort study of the relationship between serum cholesterol concentration and coronary events with low-dose simvastatin therapy in Japanese patients with hypercholesterolemia. Circ J.
McAlister FA, Majumdar SR, Lin M, et al. (2014). Cholesterol end points predict outcome in patients with coronary disease: quality improvement metrics from the enhancing secondary prevention in coronary artery disease (ESP-CAD) trial. Can J Cardiol.
McConnachie A, Walker A, Robertson M, et al. (2014). Long-term impact on healthcare resource utilization of statin treatment, and its cost effectiveness in the primary prevention of cardiovascular disease: a record linkage study. Eur Heart J.
McElduff P, Jaefarnezhad M, Durrington PN. (2006). American, British and European recommendations for statins in the primary prevention of cardiovascular disease applied to British men studied prospectively. Heart.
Mikus CR, Boyle LJ, Borengasser SJ, et al. (2013). Simvastatin impairs exercise training adaptations. J Am Coll Cardiol.
Mills EJ, O'Regan C, Eyawo O, et al. (2011). Intensive statin therapy compared with moderate dosing for prevention of cardiovascular events: a meta-analysis of >40,000 patients. Eur Heart J.
Mills EJ, Rachlis B, Wu P, et al. (2008). Primary prevention of cardiovascular mortality and events with statin treatments: a network meta-analysis involving more than 65,000 patients. J Am Coll Cardiol.
Mizuno K, Nakaya N, Teramoto T, et al. (2012). Usefulness of LDL-C-related parameters to predict cardiovascular risk and effect of pravastatin in mild-to-moderate hypercholesterolemia. J Atheroscler Thromb.
Mohler ER, Hiatt WR, Creager MA. (2003). Cholesterol reduction with atorvastatin improves walking distance in patients with peripheral arterial disease. Circulation.
Mora S, Glynn RJ, Ridker PM. (2013). High-density lipoprotein cholesterol, size, particle number, and residual vascular risk after potent statin therapy. Circulation.
Morishita R, Itakura H, Nakaya N, et al. (2012). Risk factors for cardiovascular events in Japanese patients treated with fluvastatin from the long-term event monitoring (LEM) study. CuRR, Vasc Pharmacol.
Mulders TA, Sivapalaratnam S, Stroes ES, et al. (2012). Asymptomatic individuals with a positive family history for premature coronary artery disease and elevated coronary calcium scores benefit from statin treatment: a post hoc analysis from the St. Francis Heart Study. JACC Cardiovasc Imaging.
Naci H, Brugts JJ, Fleurence R, et al. (2013). Comparative effects of statins on major cerebrovascular events: a multiple-treatments meta-analysis of placebo-controlled and active-comparator trials. QJM.
Naci H, Brugts JJ, Fleurence R, et al. (2013). Comparative benefits of statins in the primary and secondary prevention of major coronary events and all-cause mortality: a network meta-analysis of placebo-controlled and active-comparator trials. Eur J Prev Cardiolog.
Nakamura H. (2000). The design and background characteristics of the study on the primary prevention of coronary events with pravastatin among Japanese with mildly elevated cholesterol levels. (Japanese Mega Study). Atherosclerosis.
Nakamura H. (2009). Jpn J Geriatr.
Nakamura H, Group MS. (2007). Primary prevention of cardiovascular diseases among hypercholesterolemic Japanese with a low dose of pravastatin. Atheroscler Suppl.
Nash DT. (1996). Meeting national cholesterol education goals in clinical practice--a comparison of lovastatin and fluvastatin in primary prevention. Am J Cardiol.
Neil A, Cooper J, Betteridge J, et al. (2008). Reductions in all-cause, cancer, and coronary mortality in statin-treated patients with heterozygous familial hypercholesterolaemia: a prospective registry study. Eur Heart J.
Nissen SE. (2009). The Jupiter trial: key findings, controversies, and implications. CuRR, Cardiol Rep.
Nomura S, Shouzu A, Omoto S, et al. (2004). Losartan and simvastatin inhibit platelet activation in hypertensive patients. J Thromb Thrombolysis.
Oliver MF. (1995). Statins prevent coronary heart disease. Lancet.
O'Regan C, Wu P, Arora P, et al. (2008). Statin therapy in stroke prevention: a meta-analysis involving 121,000 patients. Am J Med.
Owen OG. (2005). The collaborative atorvastatin diabetes study: preliminary results. Int J Clin Pract.
Packard CJ, Ford I, Robertson M, et al. (2005). Plasma lipoproteins and apolipoproteins as predictors of cardiovascular risk and treatment benefit in the PROspective Study of Pravastatin in the Elderly at Risk (PROSPER). Circulation.
Panichi V, Mantuano E, Paoletti S, et al. (2008). Effect of simvastatin on plasma asymmetric dimethylarginine concentration in patients with chronic kidney disease. J Nephrol.
Papademetriou V, Piller LB, Ford CE, et al. (2003). Characteristics and lipid distribution of a large, high-risk, hypertensive population: the lipid-lowering component of the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). J Clin Hypertens (Greenwich).
Paradisi G, Bracaglia M, Basile F, et al. (2012). Effect of pravastatin on endothelial function and endothelial progenitor cells in healthy postmenopausal women. Clin Exp Obstet Gynecol.
Park WJ, Jo SH, Kim SA, et al. (2011). Rationale and design of STOP DVT study: rosuvastatin for the prevention of deep vein thrombosis in patients undergoing total knee replacement arthroplasty--a prospective randomized open-label controlled trial. Contemp Clin Trials.
Parra A, Kreiter KT, Williams S, et al. (2005). Effect of prior statin use on functional outcome and delayed vasospasm after acute aneurysmal subarachnoid hemorrhage: a matched controlled cohort study. Neurosurgery.
Patel JM, Snaith C, Thickett DR, et al. (2012). Randomized double-blind placebo-controlled trial of 40 mg/day of atorvastatin in reducing the severity of sepsis in ward patients (ASEPSIS Trial). Crit Care.
Paulsen L, Matthesen SK, Bech JN, et al. (2010). Acute effects of atorvastatin on glomerular filtration rate, tubular function, blood pressure, and vasoactive hormones in patients with type 2 diabetes. J Clin Pharmacol.
Pedersen TR. (1998). Prevention of cardiovascular disease: the Scandinavian experience. Aging Clin Exp Res.
Peeters G, Tett SE, Conaghan PG, et al. (2015). Is statin use associated with new joint-related symptoms, physical function, and quality of life? Results from two population-based cohorts of women. Arthritis Care Res (Hoboken).
Pehlivanidis AN, Athyros VG, Demitriadis DS, et al. (2001). Heart rate variability after long-term treatment with atorvastatin in hypercholesterolaemic patients with or without coronary artery disease. Atherosclerosis.
Pena JM, Aspberg S, MacFadyen J, et al. (2015). Statin therapy and risk of fracture: results from the JUPITER randomized clinical trial. JAMA Intern Med.
Perreault S, Dragomir A, Blais L, et al. (2008). Impact of adherence to statins on chronic heart failure in primary prevention. Br J Clin Pharmacol.
Perreault S, Dragomir A, Blais L, et al. (2009). Impact of better adherence to statin agents in the primary prevention of coronary artery disease. Eur J Clin Pharmacol.
Perreault S, Ellia L, Dragomir A, et al. (2009). Effect of statin adherence on cerebrovascular disease in primary prevention. Am J Med.
Peters TK, Muratti EN, Mehra M. (1994). Fluvastatin in primary hypercholesterolemia: efficacy and safety in patients at high risk. An analysis of a clinical trial database. Am J Med.
Petretta M, Costanzo P, Perrone-Filardi P, et al. (2010). Impact of gender in primary prevention of coronary heart disease with statin therapy: a meta-analysis. Int J Cardiol.
Petri MA, Kiani AN, Post W, et al. (2011). Lupus Atherosclerosis Prevention Study (LAPS). Ann Rheum Dis.
Pitt B, Mancini GB, Ellis SG, et al. (1995). Pravastatin limitation of atherosclerosis in the coronary arteries (PLAC I): reduction in atherosclerosis progression and clinical events. PLAC I investigation. J Am Coll Cardiol.
Poluzzi E, Piccinni C, Carta P, et al. (2011). Cardiovascular events in statin recipients: impact of adherence to treatment in a 3-year record linkage study. Eur J Clin Pharmacol.
Pons-Rejraji H, Brugnon F, Sion B, et al. (2014). Evaluation of atorvastatin efficacy and toxicity on spermatozoa, accessory glands and gonadal hormones of healthy men: a pilot prospective clinical trial. Reprod Biol Endocrinol.
Rabinowich L, Steinvil A, Leshem-Rubinow E, et al. (2012). Adherence to statins is associated with reduced incidence of idiopathic venous thromboembolism: real-life data from a large healthcare maintenance organisation. Heart.
Raikou M, McGuire A, Colhoun HM, et al. (2007). Cost-effectiveness of primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes: results from the Collaborative Atorvastatin Diabetes Study (CARDS). Diabetologia.
Rajpathak SN, Kumbhani DJ, Crandall J, et al. (2009). Statin therapy and risk of developing type 2 diabetes: a meta-analysis. Diabetes Care.
Ramcharan AS, Van Stralen KJ, Snoep JD, et al. (2009). HMG-CoA reductase inhibitors, other lipid-lowering medication, antiplatelet therapy, and the risk of venous thrombosis. J Thromb Haemost.
Ramsey SD, Clarke LD, Roberts CS, et al. (2008). An economic evaluation of atorvastatin for primary prevention of cardiovascular events in type 2 diabetes. Pharmacoeconomics.
Rapezzi C, Biagini E, Bellis P, et al. (2008). Exploring the gap between National Cholesterol Education Program guidelines and clinical practice in secondary care: results of a cross-sectional study involving over 10,000 patients followed in different specialty settings across Italy. J Cardiovasc Med (Hagerstown).
Ray K. (2013). Statin diabetogenicity: guidance for clinicians. Cardiovasc.
Ray KK, Seshasai SR, Erqou S, et al. (2010). Statins and all-cause mortality in high-risk primary prevention: a meta-analysis of 11 randomized controlled trials involving 65,229 participants. Arch Intern Med.
Rejnmark L, Buus NH, Vestergaard P, et al. (2004). Effects of simvastatin on bone turnover and BMD: a 1-year randomized controlled trial in postmenopausal osteopenic women. J Bone Miner Res.
Ridker PM, Genest J, Boekholdt SM, et al. (2010). HDL cholesterol and residual risk of first cardiovascular events after treatment with potent statin therapy: an analysis from the JUPITER trial. Lancet.
Ridker PM, Glynn RJ. (2010). The JUPITER Trial: responding to the critics. Am J Cardiol.
Ridker PM, MacFadyen J, Cressman M, et al. (2010). Efficacy of rosuvastatin among men and women with moderate chronic kidney disease and elevated high-sensitivity C-reactive protein: a secondary analysis from the JUPITER (Justification for the Use of Statins in Prevention-an Intervention Trial Evaluating Rosuvastatin) trial. J Am Coll Cardiol.
Rizzo M, Rini GB. (2006). Statins, fracture risk, and bone remodeling: What is true?. Am J Med Sci.
Robinson JG, Wang S, Smith BJ, et al. (2009). Meta-analysis of the relationship between non-high-density lipoprotein cholesterol reduction and coronary heart disease risk. J Am Coll Cardiol.
Rosenson RS, Baker SK, Jacobson TA, et al. (2014). An assessment by the Statin Muscle Safety Task Force: 2014 update. J Clin Lipidol.
Ruggenenti P, Perna A, Tonelli M, et al. (2010). Effects of add-on fluvastatin therapy in patients with chronic proteinuric nephropathy on dual renin-angiotensin system blockade: the ESPLANADE trial. Clin J Am Soc Nephrol.
Sasaki M, Gan WL, Kawasaki R, et al. (2013). Effect of simvastatin on retinal vascular caliber: the Age-Related Maculopathy Statin Study. Acta Ophthalmol.
Sattar N, Preiss D, Murray HM, et al. (2010). Statins and risk of incident diabetes: a collaborative meta-analysis of randomised statin trials. Lancet.
Savarese G, Gotto AM, Paolillo S, et al. (2013). Benefits of statins in elderly subjects without established cardiovascular disease: a meta-analysis. J Am Coll Cardiol.
Sawayama Y, Shimizu C, Maeda N, et al. (2002). Effects of probucol and pravastatin on common carotid atherosclerosis in patients with asymptomatic hypercholesterolemia. Fukuoka Atherosclerosis Trial (FAST). J Am Coll Cardiol.
Scarpioni R, Ricardi M, Melfa L, et al. (2010). Dyslipidemia in chronic kidney disease: are statins still indicated in reduction cardiovascular risk in patients on dialysis treatment?. Cardiovasc Ther.
Segura J, Ruilope LM. (2009). Rosuvastatin, C-reactive protein, LDL cholesterol, and the JUPITER trial. Lancet.
Serebruany VL. (2011). Extreme all-cause mortality in JUPITER requires reexamination of vital records. Cardiology.
Sever P, Dahlof B, Poulter N, et al. (2006). Potential synergy between lipid-lowering and blood-pressure-lowering in the Anglo-Scandinavian Cardiac Outcomes Trial. Eur Heart J.
Sever PS. (2005). Lipid-lowering therapy and the patient with multiple risk factors: what have we learned from the Anglo-Scandinavian Cardiac Outcomes Trial (ASCOT)?. Am J Med.
Sever PS, Dahlof B, Poulter NR, et al. (2004). Prevention of coronary and stroke events with atorvastatin in hypertensive patients who have average or lower-than-average cholesterol concentrations, in the Anglo-Scandinavian Cardiac Outcomes Trial--Lipid Lowering Arm (ASCOT-LLA): a multicentre randomised controlled trial. Drugs.
Sgueglia GA, Crea F. (2011). The risks of a new hypothesis: why did JUPITER patients have almost twice the predicted event rate of reduction?. J Cardiovasc Med (Hagerstown).
Sheng X, Murphy MJ, MacDonald TM, et al. (2012). Effect of statins on total cholesterol concentrations, cardiovascular morbidity, and all-cause mortality in chronic obstructive pulmonary disease: a population-based cohort study. Clin Ther.
Sheng X, Murphy MJ, MacDonald TM, et al. (2012). The comparative effectiveness of statin therapy in selected chronic diseases compared with the remaining population. BMC Public Health.
Sheng X, Murphy MJ, MacDonald TM, et al. (2012). Effect of statins on total cholesterol concentrations and cardiovascular outcomes in patients with diabetes mellitus: a population-based cohort study. Eur J Clin Pharmacol.
Sheng X, Murphy MJ, Macdonald TM, et al. (2012). Effectiveness of statins in chronic kidney disease. QJM.
Sheng X, Murphy MJ, Macdonald TM, et al. (2012). Effectiveness of statins on total cholesterol and cardiovascular disease and all-cause mortality in osteoarthritis and rheumatoid arthritis. J Rheumatol.
Sheng X, Wei L, Murphy MJ, et al. (2009). Statins and total (not LDL) cholesterol concentration and outcome of myocardial infarction: results from a meta-analysis and an observational study. Eur J Clin Pharmacol.
Shepherd J. (1998). Pravastatin event reduction analysis. Am J Manag Care.
Shepherd J. (2004). Statins for primary prevention: strategic options to save lives and money. J R Soc Med.
Shepherd J, Blauw GJ, Murphy MB, et al. (2002). Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet.
Shepherd J, Cobbe SM, Ford I, et al. (1996). Preventing coronary heart disease with pravastatin. Natl Med J India.
Shepherd J, Gaw A, West of Scotland Coronary Prevention Study Group. (2002). The anatomy of a clinical trial. The West of Scotland Coronary Prevention Study. Med Princ Pract.
Shepherd J, Kastelein JP, Bittner VA, et al. (2008). Intensive lipid lowering with atorvastatin in patients with coronary artery disease, diabetes, and chronic kidney disease. Mayo Clin Proc.
Shiba T, Sakamoto K, Ito C, et al. (2014). Beneficial effect of pitavastatin on the incidence of diabetes in women with impaired glucose tolerance: sub-analysis of j-predict. Diabetes.
Simoons ML, Saelman JP. (1994). Effect of simvastatin on coronary atheroma: the Multicentre Anti-Atheroma Study (MAAS). Lancet.
Skerrett PJ, Pasternak RC. (2004). ALLHAT-LLT: questions, questions, and more questions (and some answers). CuRR, Atheroscler Rep.
Smeeth L, Douglas I, Hall AJ, et al. (2009). Effect of statins on a wide range of health outcomes: a cohort study validated by comparison with randomized trials. Br J Clin Pharmacol.
Sondermeijer BM, Boekholdt SM, Rana JS, et al. (2013). Clinical implications of JUPITER in a contemporary European population: the EPIC-Norfolk prospective population study. Eur Heart J.
Sorensen HT, Horvath-Puho E, Sogaard KK, et al. (2009). Arterial cardiovascular events, statins, low-dose aspirin and subsequent risk of venous thromboembolism: a population-based case-control study. J Thromb Haemost.
Steg PG, Tissot C-M. (2010). Statins in the elderly: what evidence of their benefit in prevention?. Arch Cardiovasc Dis.
Stegmayr BG, Brannstrom M, Bucht S, et al. (2005). Low-dose atorvastatin in severe chronic kidney disease patients: a randomized, controlled endpoint study. Scand J Urol Nephrol.
Strippoli GF, Navaneethan SD, Johnson DW, et al. (2008). Effects of statins in patients with chronic kidney disease: meta-analysis and meta-regression of randomised controlled trials. BMJ.
Taylor F, Huffman MD, Macedo AF, et al. (2013). Statins for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev.
Taylor FC, Huffman M, Ebrahim S. (2013). Statin therapy for primary prevention of cardiovascular disease. JAMA.
Teo KK, Burton JR, Buller CE, et al. (2000). Long-term effects of cholesterol lowering and angiotensin-converting enzyme inhibition on coronary atherosclerosis: the Simvastatin/Enalapril Coronary Atherosclerosis Trial (SCAT). Circulation.
Teramoto T, Kitagawa Y, Daida H, et al. (2011). APPROACH-J study: design, rationale, and baseline data of the affirmation primary prevention with pravastatin in reduction of occlusive atherosclerotic complications in hypercholesterolemia--Japan study. J Atheroscler Thromb.
Teramoto T, Nakaya N, Yokoyama S, et al. (2010). Association between lowering low-density lipoprotein cholesterol with pravastatin and primary prevention of cardiovascular disease in mild to moderate hypercholesterolemic Japanese. J Atheroscler Thromb.
Ting RZ, Yang X, Yu LW, et al. (2010). Lipid control and use of lipid-regulating drugs for prevention of cardiovascular events in Chinese type 2 diabetic patients: a prospective cohort study. Cardiovasc.
Tonelli M, Lloyd A, Clement F, et al. (2011). Efficacy of statins for primary prevention in people at low cardiovascular risk: a meta-analysis. CMAJ.
Trompet S, van Vliet P, de Craen AJ, et al. (2010). Pravastatin and cognitive function in the elderly. Results of the PROSPER study. J Neurol.
Vaucher J, Marques-Vidal P, Preisig M, et al. (2014). Population and economic impact of the 2013 ACC/AHA guidelines compared with European guidelines to prevent cardiovascular disease. Eur Heart J.
Wang W, Zhang B. (2014). Statins for the prevention of stroke: a meta-analysis of randomized controlled trials. PLoS ONE.
Wang Z, Ge J. (2014). Managing hypercholesterolemia and preventing cardiovascular events in elderly and younger Chinese adults: focus on rosuvastatin. Clin Interv Aging.
Wanner C, Krane V, Marz W, et al. (2005). Atorvastatin in patients with type 2 diabetes mellitus undergoing hemodialysis. N Engl J Med.
Weng TC, Yang YH, Lin SJ, et al. (2010). A systematic review and meta-analysis on the therapeutic equivalence of statins. J Clin Pharm Ther.
Wu XD, Zeng K, Xue FQ, et al. (2013). Statins are associated with reduced risk of gastric cancer: a meta-analysis. Eur J Clin Pharmacol.
Yang CC, Jick SS, Jick H. (2002). Statins and the risk of idiopathic venous thromboembolism. Br J Clin Pharmacol.
Yang Q, Qi X, Li Y. (2014). The preventive effect of atorvastatin on atrial fibrillation: a meta-analysis of randomized controlled trials. BMC Cardiovasc Disord.
Yu O, Eberg M, Benayoun S, et al. (2014). Use of statins and the risk of death in patients with prostate cancer. J Clin Oncol.
Yue J, Zhang X, Dong B, et al. (2010). Statins and bone health in postmenopausal women: a systematic review of randomized controlled trials. Menopause.
Yun KH, Shin I, Park EM, et al. (2008). Effect of additional statin therapy on endothelial function and prognosis in patients with vasospastic angina. Korean Circ J.
Yusuf S, Lonn E, Bosch J. (2009). Lipid lowering for primary prevention. Lancet.
Zanchetti A, Crepaldi G, Bond MG, et al. (2004). Different effects of antihypertensive regimens based on fosinopril or hydrochlorothiazide with or without lipid lowering by pravastatin on progression of asymptomatic carotid atherosclerosis: principal results of PHYLLIS--a randomized double-blind trial. Stroke.
Zellweger MJ, Maraun M, Osterhues HH, et al. (2014). Progression to overt or silent CAD in asymptomatic patients with diabetes mellitus at high coronary risk: main findings of the prospective multicenter Bardot trial with a pilot randomized treatment substudy. JACC Cardiovasc Imaging.
Zoungas S, Curtis A, Tonkin A, et al. (2014). Statins in the elderly: an answered question?. CuRR, Opin Cardiol.

## Appendix A5 USPSTF Quality Rating Criteria

### Criteria for Assessing Internal Validity of Individual Studies

The Methods Work Group for the US Preventive Services Task Force (USPSTF) developed a set of criteria by which the internal validity of individual studies could be evaluated. The USPSTF accepted the criteria, and the associated definitions of quality categories, that relate to internal validity at its September 1999 meeting.

This appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments.

All topic teams use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for primary care practice may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

Presented below are a set of minimal criteria for each study design and then a general definition of three categories: “good,” “fair,” and “poor,” based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general, a “good” study is one that meets all criteria well. A “fair” study is one that does not meet (or it is not clear that it meets) at least one criterion but has no known “fatal flaw.” “Poor” studies have at least one fatal flaw.

### Randomized Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  ○ For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Important differential loss to follow-up or overall high loss to follow-up.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment).
- Clear definition of interventions.
- All important outcomes considered.
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.

Poor: Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

Source: U.S. Preventive Services Task Force Procedure Manual. Available at: http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm

## Appendix A6 Reviewers of the Draft Report

- Conrad B. Blum, MD
  Professor of Medicine, Columbia University Medical Center
- John R. Downs, MD (Federal Reviewer)
  Veterans Health Care System
- Scott Grundy, MD, PhD
  Professor of Internal Medicine, Assistant Chief of Medical Service, University of Texas Southwestern; VA Medical Center, Dallas
- Rita Redberg, FACC, MSC, MD
  Professor of Medicine, Director of Women's Cardiovascular Services, University of California, San Francisco
- Paul M. Ridker, MD, MPH
  Professor of Medicine, Harvard Medical School; Director, Center for Cardiovascular Disease Prevention, Brigham and Women's Hospital
- Neil J. Stone, MD
  Professor of Medicine-Cardiology, Feinberg School of Medicine, Northwestern University
- Federal Partner
  Veterans Health Administration