# References

1 Helfand M, Carson S. (2008). Screening for Lipid Disorders in Adults: Selective Update of 2001 US Preventive Services Task Force Review.
2 Pignone MP, Phillips CJ, Atkins D, et al. (2001). Screening and treating adults for lipid disorders. Am J Prev Med.
3 Pignone MP, Phillips CJ, Lannon CM, et al. (2001). Screening for Lipid Disorders.
4 U.S. Preventive Services Task Force. (2008). Screening for Lipid Disorders in Adults: Recomendation Statement.
5 Goff DC, Lloyd-Jones DM, Bennett G, et al. (2014). 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol.
6 Chou R, Dana T, Blazina I, et al. (2016). Statin Use for the Prevention of Cardiovascular Disease in Adults: A Systematic Review for the U.S. Preventive Services Task Force.
7 National Institutes of Health. (2002). Detection, Evaluation and Treatment of High Blook Cholesterol in Adults (Adult Treatment Panel III).
8 Toth PP, Potter D, Ming EE. (2012). Prevalence of lipid abnormalities in the United States: the National Health and Nutrition Examination Survey 2003-2006. J Clin Lipidol.
9 Ghandehari H, Kamal-Bahl S, Wong ND. (2008). Prevalence and extent of dyslipidemia and recommended lipid levels in US adults with and without cardiovascular comorbidities: the National Health and Nutrition Examination Survey 2003-2004. Am Heart J.
10 Centers for Disease Control and Prevention. (2011). Prevalence of coronary heart disease--United States, 2006-2010. MMWR.
11 Lloyd-Jones D, Adams RJ, Brown TM, et al. (2010). Heart disease and stroke statistics—2010 update A report from the American Heart Association. Circulation.
12 Hoyert DL. (2012). 75 years of mortality in the United States, 1935-2010. NCHS Data Brief.
13 Minino AM. (2013). Death in the United States, 2011. NCHS Data Brief.
14 Go AS, Mozaffarian D, Roger VL, et al. (2013). Heart disease and stroke statistics—2013 update a report from the American Heart Association. Circulation.
15 Lloyd-Jones DM, Wilson PW, Larson MG, et al. (2003). Lifetime risk of coronary heart disease by cholesterol levels at selected ages. Arch Intern Med.
16 National Center for Health Statistics. (2013). Health, United States, 2012: Table 21. Years of potential life lost before age 75 for selected causes of death, by sex, race, and Hispanic origin: United States, selected years 1980-2010.
17 Berry JD, Lloyd-Jones DM, Garside DB, et al. (2007). Framingham risk score and prediction of coronary heart disease death in young men. Am Heart J.
18 Roger VL, Go AS, Lloyd-Jones DM, et al. (2012). Heart disease and stroke statistics--2012 update: a report from the American Heart Association. Circulation.
19 Lecerf JM, de Lorgeril M. (2011). Dietary cholesterol: from physiology to cardiovascular risk. Br J Nutr.
20 Davies MJ. (2000). The pathophysiology of acute coronary syndromes. Heart.
21 Pletcher MJ, Bibbins-Domingo K, Liu K, et al. (2010). Nonoptimal lipids commonly present in young adults and coronary calcium later in life: the CARDIA (Coronary Artery Risk Development in Young Adults) study. Ann Intern Med.
22 Knowles JW, O'Brien EC, Greendale K, et al. (2014). Reducing the burden of disease and death from familial hypercholesterolemia: a call to action. Am Heart J.
23 Sibley C, Stone NJ. (2006). Familial hypercholesterolemia: a challenge of diagnosis and therapy. Cleve Clin J Med.
24 Sniderman AD, Tsimikas S, Fazio S. (2014). The severe hypercholesterolemia phenotype: clinical diagnosis, management, and emerging therapies. J Am Coll Cardiol.
25 Ziajka PE. (2013). Management of patients with homozygous familial hypercholesterolemia. Am J Manag Care.
26 Rader DJ, Cohen J, Hobbs HH. (2003). Monogenic hypercholesterolemia: new insights in pathogenesis and treatment. J Clin Invest.
27 Stone NJ, Robinson J, Lichtenstein AH, et al. (2013). 2013 ACC/AHA Guideline on the Treatment of Blood Cholesterol to Reduce Atherosclerotic Cardiovascular Risk in Adults: A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol.
28 Stone NJ, Levy RI, Fredrickson DS, et al. (1974). Coronary artery disease in 116 kindred with familial type II hyperlipoproteinemia. Circulation.
29 Slack J. (1969). Risks of ischaemic heart-disease in familial hyperlipoproteinaemic states. Lancet.
30 Coffey S. Dyslipidemia. Clinical Guide: Comorbidities and Complications.
31 Stein JH. (2003). Dyslipidemia in the era of HIV protease inhibitors. Prog Cardiovasc Dis.
32 Di Angelantonio E, Sarwar N, Perry P, et al. (2009). Major lipids, apolipoproteins, and risk of vascular disease. JAMA.
33 Saari K, Koponen H, Laitinen J, et al. (2004). Hyperlipidemia in persons using antipsychotic medication: a general population-based birth cohort study. J Clin Psychiatry.
34 Sniderman AD, Williams K, Contois JH, et al. (2011). A meta-analysis of low-density lipoprotein cholesterol, non-high-density lipoprotein cholesterol, and apolipoprotein B as markers of cardiovascular risk. Circ Cardiovasc Qual Outcomes.
35 Robinson JG, Wang S, Smith BJ, et al. (2009). Meta-analysis of the relationship between non-high-density lipoprotein cholesterol reduction and coronary heart disease risk. J Am Coll Cardiol.
36 Ramjee V, Sperling LS, Jacobson TA. (2011). Non-high-density lipoprotein cholesterol versus apolipoprotein B in cardiovascular risk stratification: do the math. J Am Coll Cardiol.
37 Boekholdt SM, Arsenault BJ, Mora S, et al. (2012). Association of LDL cholesterol, non-HDL cholesterol, and apolipoprotein B levels with risk of cardiovascular events among patients treated with statins: a meta-analysis. JAMA.
38 Mora S, Otvos JD, Rifai N, et al. (2009). Lipoprotein particle profiles by nuclear magnetic resonance compared with standard lipids and apolipoproteins in predicting incident cardiovascular disease in women. Circulation.
39 Robinson JG. (2012). What is the role of advanced lipoprotein analysis in practice?. J Am Coll Cardiol.
40 Helfand M, Buckley DI, Freeman M, et al. (2009). Emerging risk factors for coronary heart disease: a summary of systematic reviews conducted for the U.S. Preventive Services Task Force. Ann Intern Med.
41 Ito MK, McGowan MP, Moriarty PM. (2011). Management of familial hypercholesterolemias in adult patients: recommendations from the National Lipid Association Expert Panel on Familial Hypercholesterolemia. J Clin Lipidol.
42 Centers for Disease Control and Prevention. Heart Disease and Stroke.
43 Kuklina EV, Yoon PW, Keenan NL. (2010). Prevalence of coronary heart disease risk factors and screening for high cholesterol levels among young adults, United States, 1999-2006. Ann Fam Med.
44 Willson MN, Neumiller JJ, Sclar DA, et al. (2010). Ethnicity/race, use of pharmacotherapy, scope of physician-ordered cholesterol screening, and provision of diet/nutrition or exercise counseling during US office-based visits by patients with hyperlipidemia. Am J Cardiovasc Drugs.
45 U.S. Department of Health and Human Services. Heart disease and stroke.
46 American Diabetes Association. Diabetes Management Guidelines 2013.
47 The Task Force for the Management of Dyslipidaemias of the European Society of Cardiology and the European Atherosclerosis Society. (2011). ESC/EAS Guidelines for the management of dyslipidaemias. Eur Heart J.
48 Genest J, Frohlich J, Fodor G, et al. (2003). Recommendations for the management of dyslipidemia and the prevention of cardiovascular disease: 2003 update. CMAJ.
49 American Academy of Family Physicians. Lipid Disorders.
50 (1996). Clinical Guideline, part 1: guidelines for using serum cholesterol, high-density lipoprotein cholesterol, and triglyceride levels as screening tests for preventing coronary heart disease in adults. Ann Intern Med.
51 U.S. Preventive Services Task Force. Procedure Manual.
52 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
53 Asselbergs FW, Diercks GF, Hillege HL, et al. (2004). Effects of fosinopril and pravastatin on cardiovascular events in subjects with microalbuminuria. Circulation.
54 Chan KL, Teo K, Dumesnil JG, et al. (2010). Effect of lipid lowering with rosuvastatin on progression of aortic stenosis: results of the aortic stenosis progression observation: measuring effects of rosuvastatin (ASTRONOMER) trial. Circulation.
55 Beishuizen ED, van de Ree MA, Jukema JW, et al. (2004). Two-year statin therapy does not alter the progression of intima-media thickness in patients with type 2 diabetes without manifest cardiovascular disease. Diabetes Care.
56 Muldoon MF, Ryan CM, Sereika SM, et al. (2004). Randomized trial of the effects of simvastatin on cognitive functioning in hypercholesterolemic adults. Am J Med.
57 Versmissen J, Oosterveer DM, Yazdanpanah M, et al. (2008). Efficacy of statins in familial hypercholesterolaemia: a long term cohort study. BMJ.
58 Kreger BE, Odell PM, D'Agostino RB, et al. (1994). Long-term intraindividual cholesterol variability: natural course and adverse impact on morbidity and mortality--the Framingham Study. Am Heart J.
59 Iribarren C, Jacobs DR, Slattery ML, et al. (1997). Epidemiology of low total plasma cholesterol concentration among young adults: the CARDIA study. Coronary Artery Risk Development in Young Adults. Prev Med.
60 Bakx JC, van den Hoogen HJ, Deurenberg P, et al. (2000). Changes in serum total cholesterol levels over 18 years in a cohort of men and women: The Nijmegen Cohort Study. Prev Med.
61 Wilsgaard T, Jacobsen BK, Schirmer H, et al. (2001). Tracking of cardiovascular risk factors: the Tromso study, 1979-1995. Am J Epidemiol.
62 Ulmer H, Kelleher C, Diem G, et al. (2003). Long-term tracking of cardiovascular risk factors among men and women in a large population-based health system: the Vorarlberg Health Monitoring & Promotion Programme. Eur Heart J.
63 Laclaustra-Gimeno M, Gonzalez-Garcia MP, Casasnovas-Lenguas JA, et al. (2006). Cardiovascular Risk Factor Progression in Young Males at 15-Year Follow-Up in the General Military Academy of Zaragoza (AGEMZA) Study. Rev Esp Cardiol (Engl Ed).
64 Baigent C, Keech A, Kearney PM, et al. (2005). Efficacy and safety of cholesterol-lowering treatment: prospective meta-analysis of data from 90,056 participants in 14 randomised trials of statins. Lancet.
65 O'Brien EC, Roe MT, Fraulo ES, et al. (2014). Rationale and design of the familial hypercholesterolemia foundation CAscade SCreening for Awareness and DEtection of Familial Hypercholesterolemia registry. Am Heart J.