# 4 Discussion

## Summary of Review Findings

As shown in Table 1, no study has evaluated the effects of screening versus no screening or treatment versus no treatment on clinical outcomes. In addition, no study has evaluated the diagnostic yield of alternative screening strategies in younger adults (e.g., targeted screening of persons with a family history of hyperlipidemia vs. general screening). Although some primary prevention trials have enrolled younger adults,^53-56^ they comprised a small part of the population and results were not reported separately for this age group. In addition, because of the small numbers of cardiovascular events expected in this age group, even if the data were reported, the trials were probably underpowered to detect effects on clinical outcomes. Therefore, estimates of benefits of lipid-lowering therapies or lifestyle changes for the treatment of dyslipidemia in younger adults require extrapolation from trials conducted in older populations. Even assuming that the relative benefits are the same for statins or other therapies in younger and older adults, the absolute benefits in the short term (e.g., 5 to 10 years) would generally be lower in younger adults because of the lower incidence of CHD events. An exception may be young adults with familial hypercholesterolemia, who are at increased risk of CHD events at a younger age. However, the only study that compared effects of statins versus no statins for the treatment of familial hypercholesterolemia enrolled persons with a mean age of 44 years and did not meet inclusion criteria.^57^

Table 1 Summary of Evidence

Main findings from prior USPSTF reports^*^ | Number and type of studies identified for update | Limitations | Consistency | Applicability | Summary of findings | Overall quality^†^
Key Question 1. What are the benefits of screening for dyslipidemia in asymptomatic adults ages 21 to 39 years on CHD- or CVA-related morbidity or mortality or all-cause mortality?
No studies | No studies | - | - | - | - | -
Key Question 2. What are the harms of screening for dyslipidemia in asymptomatic adults ages 21 to 39 years?
No studies | No studies | - | - | - | - | -
Key Question 3. What is the diagnostic yield of alternative screening strategies for dyslipidemia in asymptomatic adults ages 21 to 39 years?
No studies | No studies | - | - | - | - | -
Key Question 4. What are the benefits of treatment of dyslipidemia in adults ages 21 to 39 years on CHD- or CVA-related morbidity or mortality or all-cause mortality?
No studies | No studies | - | - | - | Although 4 trials of statins for primary prevention enrolled patients age <40 years, results were not reported separately for this subgroup and they comprised a small part of the population. One cohort study evaluated efficacy of statins in patients with familial hypercholesterolemia, but the mean age at enrollment was 44 years. | -
Key Question 5. What are the benefits of delayed vs. immediate treatment in adults ages 21 to 39 years with dyslipidemia on CHD- or CVA-related morbidity or mortality or all-cause mortality?
No studies | No studies | - | - | - | - | -
Key Question 6. What are the harms of drug treatment of dyslipidemia in asymptomatic adults ages 21 to 39 years?
No studies | No studies | - | - | - | - | -

* A difference between this update and prior USPSTF reviews on lipid screening is that this review focuses on screening in younger adults (defined as adults ages 21 to 39 years).

† “Overall quality” is based on new evidence plus previously reviewed evidence.

Abbreviations: CHD=coronary heart disease; CVA=cerebrovascular accident (stroke).

We also found no evidence on the incremental benefit of delayed versus earlier treatment. Earlier initiation of therapy might reduce risk of CHD events that occur later in life if the primary mechanism of lipid-lowering therapy is regression of atherosclerosis. However, in trials of middle-aged and older populations, prevention of CHD events appears to start within 1 to 2 years of statin initiation,^64^ suggesting that long-term therapy started during early adulthood may not be required to experience benefits from treatment, which might be related in part to early plaque stabilization or other shorter-term effects.

Our findings are in accordance with prior USPSTF reviews,^1,3^ which also found no direct evidence on the benefits or harms of screening or subsequent treatment in younger adults. Although persons with familial hypercholesterolemia are at increased risk for early-onset cardiovascular events, a factor limiting the potential benefits of screening for this condition is that familial hypercholesterolemia is a low-prevalence condition (estimated at 1 in 500 persons), and that even among this population, the majority (85% to 90%) do not experience a CHD event before age 40 years.^28,29^

Longitudinal studies suggest that lipid levels have a tendency to increase over time in younger adults,^58,60^ although no study has evaluated how lipid levels change according to different intervals between repeat testing, or the proportion of patients who would move from one risk category to another.

## Limitations

The major limitation of this review is the lack of direct evidence in younger adults.

## Emerging Issues/Next Steps

Statins have become the mainstay of lipid-lowering therapy. Although use of statins in middle-aged and older adults appears to be relatively safe, the long-term adverse effects of statin therapy (e.g., risk of developing diabetes) started in younger adulthood and lasting for decades have not been well studied.

## Relevance for Priority Populations

No evidence was identified for priority populations on the benefits and harms of screening for or treatment of dyslipidemia

## Future Research

Research is needed to understand the effects of screening for and treatment of dyslipidemia in younger adults. As very large, long-term trials would be required to evaluate screening in younger adults in the general population and may not be feasible, initial screening trials might target persons with a family history of familial hypercholesterolemia or early-onset CHD, and initial treatment trials might target persons with highly elevated lipid levels (e.g., due to familial hypercholesterolemia). A recently established registry of persons with familial hyperlipidemia could be useful for understanding effects of treatment.^65^ Trials of delayed versus immediate lipid-lowering therapy in younger adults found to have dyslipidemia would also be helpful for understanding the effectiveness of earlier treatment, and studies are needed to understand the harms associated with very long-term statin therapy.

## Conclusions

Direct evidence on the benefits and harms of screening for or treatment of dyslipidemia in younger adults remains unavailable.