# 3 Results

## Key Question 1 What Are the Benefits of Screening for Dyslipidemia in Asymptomatic Adults Ages 21 to 39 Years on CHD- or CVA-Related Morbidity or Mortality or All-Cause Mortality?

We identified no studies on the benefits of screening versus no screening for dyslipidemia in asymptomatic adults ages 21 to 39 years on cardiovascular outcomes.

## Key Question 2 What Are the Harms of Screening for Dyslipidemia in Asymptomatic Adults Ages 21 to 39 Years?

We identified no studies on the harms of screening versus no screening for dyslipidemia in asymptomatic adults ages 21 to 39 years that evaluated clinical outcomes.

## Key Question 3 What Is the Diagnostic Yield of Alternative Screening Strategies for Dyslipidemia in Asymptomatic Adults Ages 21 to 39 Years?

We identified no studies on the diagnostic yield of alternative screening strategies for dyslipidemia in asymptomatic adults ages 21 to 39 years.

## Key Question 4 What Are the Benefits of Treatment in Adults Ages 21 to 39 Years on CHD- or CVA-Related Morbidity or Mortality or All-Cause Mortality?

### Summary

We identified no studies on the benefits of treatment versus no treatment in adults ages 21 to 39 years on cardiovascular outcomes.

### Evidence

We identified no studies on the benefits of treatment versus no treatment in adults ages 21 to 39 years on cardiovascular outcomes. Although four trials of statins for primary prevention enrolled patients younger than age 40 years, results were not reported separately for this subgroup and they comprised a small part of the population.^53-56^ One cohort study evaluated efficacy of statins in patients with familial hypercholesterolemia, but the mean age at enrollment was 44 years.^57^

## Key Question 5 What Are the Benefits of Delayed Versus Immediate Treatment in Adults Ages 21 to 39 Years With Dyslipidemia on CHD- or CVA-Related Morbidity or Mortality or All-Cause Mortality?

We identified no studies on the benefit of delayed versus immediate treatment of dyslipidemia in adults ages 21 to 39 years.

## Key Question 6 What Are the Harms of Drug Treatment of Dyslipidemia in Asymptomatic Adults Ages 21 to 39 Years?

We identified no studies on the harms of treatment of dyslipidemia versus no treatment in adults ages 21 to 39 years.

## Contextual Question 1 What Are the Benefits of Drug Treatment in Adults Ages 21 to 39 Years on Intermediate Outcomes?

We identified no randomized trials, cohort studies, or case-control studies on the effects of drug treatment in adults ages 21 to 39 years on intermediate outcomes, such as lipid levels or atherosclerosis.

## Contextual Question 2 How Do Lipid Levels Change Over Time in Adults Ages 21 to 39 Years?

Few longitudinal studies have assessed how lipid levels change over time in adults ages 21 to 39 years. In the Framingham Heart Study, the average biennial difference among serial cholesterol measurements among persons younger than age 45 years at enrollment was 4.4 ± 6.9 mg/dL in men and 7.5 ± 7.2 mg/dL in women.^58^ Including all adults, the rate of change was higher in persons with lower TC levels (6.7 ± 5.6 mg/dL in men and 9.2 ± 6.6 mg/dL in women with initial TC levels <200 mg/dL vs. 0.6 ± 7.4 mg/dL in men and 3.7 ± 11.2 mg/dL in women with initial TC levels ≥240 mg/dL). Some evidence also suggests that young adults with low lipid levels often do not maintain them as they age. The Coronary Artery Risk Development in Young Adults Study, which enrolled persons in the United States ages 18 to 30 years, found that between 44 and 52 percent of those with TC levels below the 10th percentile remained below the same percentile 7 years later.^59^

Several European studies have also evaluated stability of lipid levels over time in young adults. In general, lipid levels in young adults increased over time, though the magnitude of change varied depending on baseline age and sex. In the Nijmegen Cohort Study (the Netherlands), the increase over a period of 18 years was largest for younger men, with TC levels increasing an average of 20 percent in men ages 20 to 24 years at baseline and 9.1 percent in men ages 35 to 39 years at baseline.^60^ In women, the pattern was in the opposite direction, at 9.8 percent in those ages 20 to 24 years at baseline and 16 percent in those ages 35 to 39 years at baseline. The proportion with TC levels of 251 mg/dL or greater increased from 3 to 26 percent in men ages 20 to 24 years at baseline and from 6 to 16 percent in women ages 20 to 24 years at baseline after 18 years; TC levels increased from 23 percent in men and 12 percent in women ages 35 to 39 years to 36 and 43 percent, respectively, after followup. In the Tromsø Study (Norway), the tracking coefficient (a measure of the tendency of individuals to maintain their rank or position in a group over time) for HDL-C levels in men ages 20 to 38 years ranged from 0.52 to 0.56, and for women ranged from 0.51 to 0.62.^61^ The tracking coefficient was higher for TC levels (0.70 to 0.74 in men and 0.62 to 0.69 in women) and was lower for triglycerides (0.30 to 0.49 in men and 0.33 to 0.39 in women). Tracking coefficients were also higher for TC levels than triglycerides in younger adults in the Vorarlberg Health Monitoring and Promotion Programme (Austria).^62^ A Spanish study of military recruits age 20 years found that after 15 years, TC levels increased an average of 68 mg/dL, LDL-C levels by 58 mg/dL, and HDL-C levels by -5.2 mg/dL.^63^