# 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^51,52^ the USPSTF and the Agency for Healthcare Research and Quality determined the scope and Key Questions for this review. In conjunction with the USPSTF, investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes reviewed (Figure 1).

Figure 1 Analytic Framework

Note: Numbers correspond to the Key Questions.

Abbreviations: CHD=coronary heart disease; CVA=cerebrovascular accident (stroke).

This figure depicts the analytic framework, which outlines the evidence areas covered in the review, including the population, screening, treatment, outcomes, and harms. The population includes asymptomatic adults ages 21 to 39 years. An overarching arrow directly assesses screening for dyslipidemia in this population and its effects on CHD- and CVA-related morbidity and mortality and all-cause mortality (Key Question 1). An arrow from the population also indicates identification of asymptomatic persons with dyslipidemia via screening strategies (Key Question 3), followed by the effect of treatment on health outcomes (Key Questions 4 and 5). Additional arrows from the screening and treatment areas of the framework represent the assessment of associated harms (Key Questions 2 and 6).

### Key Questions

1. What are the benefits of screening for dyslipidemia in asymptomatic adults ages 21 to 39 years on CHD- or CVA-related morbidity or mortality or all-cause mortality?
2. What are the harms of screening for dyslipidemia in asymptomatic adults ages 21 to 39 years?
3. What is the diagnostic yield of alternative screening strategies (e.g., universal versus risk-based screening) for dyslipidemia in asymptomatic adults ages 21 to 39 years?
4. What are the benefits of treatment (e.g., drug or lifestyle interventions) of dyslipidemia in adults ages 21 to 39 years on CHD- or CVA-related morbidity or mortality or all-cause mortality?
5. What are the benefits of delayed versus immediate treatment in adults ages 21 to 39 years with dyslipidemia on CHD- or CVA- related morbidity or mortality or all-cause mortality?
6. What are the harms of drug treatment of dyslipidemia in asymptomatic adults ages 21 to 39 years?

Two Contextual Questions were also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology. Rather, the approach to Contextual Questions is to focus on evidence from key high-quality studies.

### Contextual Questions

1. What are the benefits of drug treatment in adults ages 21 to 39 years on intermediate outcomes (e.g., lipid levels, atherosclerosis)?
2. How do lipid levels change over time in adults ages 21 to 39 years?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through May 2016) and Ovid MEDLINE (2008 through May 2016) for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles, and searched ClinicalTrials.gov for ongoing studies.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. Studies were reviewed on the basis of inclusion and exclusion criteria developed for each Key Question (Appendix A2). Eligible studies were randomized trials, cohort studies, and case-control studies of lipid screening versus no screening, treatment of dyslipidemia versus no treatment, and delayed versus immediate treatment of dyslipidemia in asymptomatic adults ages 21 to 39 years that evaluated mortality, cardiovascular outcomes (CHD- or CVA-related morbidity or mortality), or harms of screening or treatment. Studies that reported the diagnostic yield (number of true positives per number tested) of lipid screening in adults ages 21 to 39 years were also included. Studies that enrolled older adults would be included if results were reported separately for the subgroup of patients younger than age 40 years or if the mean age of the population was younger than 40 years. Included interventions were drug and lifestyle interventions (e.g., exercise and diet changes).

Effects of treatment on intermediate outcomes (such as changes in markers of atherosclerosis or lipid levels) were evaluated for one of the Contextual Questions. Studies of individuals with prior cardiovascular events were excluded. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

We planned to have one investigator abstract details about each article's study design, patient population, setting, screening method, treatment regimen, analysis, followup, and results; a second investigator review data abstraction for accuracy; and two investigators independently apply criteria developed by the USPSTF^51^ to rate the quality of each study as good, fair, or poor (Appendix A5), with discrepancies resolved through consensus; however, no studies met inclusion criteria.

## Data Synthesis

We planned to assess the aggregate internal validity (quality) of the body of evidence for each key question (“good,” “fair,” or “poor”) using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results among studies, and directness of evidence;^51^ however, no studies met inclusion criteria.

## External Review

The draft report was reviewed by content experts (Appendix A6), USPSTF members, Agency for Healthcare Research and Quality Project Officers, and collaborative partners.