# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Screening

#### Database: Ovid MEDLINE(R) without Revisions and Cochrane Central Register of Controlled Trials

1. exp Dyslipidemias/
2. Cholesterol/bl
3. Mass Screening/
4. (1 or 2) and 3
5. limit 4 to yr=“2008 - 2016”
6. limit 5 to humans
7. limit 6 to English language
8. limit 6 to abstracts
9. 7 or 8

### Treatment

#### Randomized, Controlled Trials and Controlled Observational Studies

##### Database: Ovid MEDLINE(R) without Revisions

1. exp Dyslipidemias/
2. Cholesterol, HDL/bl
3. Cholesterol, LDL/bl
4. Lipids/bl
5. Triglycerides/bl
6. or/2-5
7. Cardiovascular Diseases/pc
8. or/1-7
9. Hypolipidemic Agents/
10. Anticholesteremic Agents/
11. Hydroxymethylglutaryl-CoA Reductase Inhibitors/
12. (atorvastatin or fluvastatin or lovastatin or pitavastatin or pravastatin or rosuvastatin or simvastatin).mp.
13. (lipitor or lescol or mevacor or livalo or pravachol or crestor or zocor).mp.
14. Gemfibrozil/
15. Fenofibrate/
16. Niacin/
17. or/9-16
18. Diet/ or Diet, Reducing/
19. Exercise Therapy/
20. Weight Loss/
21. (diet or exercise or lifestyle).ti,ab.
22. or/18-21
23. 8 and (17 or 22)
24. 23 and (random$ or control$ or cohort).ti,ab.
25. 24 not (child$ or pediatric$ or adolescen$ or teen$).mp.
26. limit 25 to (English language and humans)
27. limit 26 to yr=“2008 - 2016”

##### Database: Cochrane Central Register of Controlled Trials

1. exp Dyslipidemias/
2. Cholesterol, HDL/bl
3. Cholesterol, LDL/bl
4. Lipids/bl
5. Triglycerides/bl
6. or/2-5
7. Cardiovascular Diseases/pc
8. or/1-7
9. Hypolipidemic Agents/
10. Anticholesteremic Agents/
11. Hydroxymethylglutaryl-CoA Reductase Inhibitors/
12. (atorvastatin or fluvastatin or lovastatin or pitavastatin or pravastatin or rosuvastatin or simvastatin).mp.
13. (lipitor or lescol or mevacor or livalo or pravachol or crestor or zocor).mp.
14. Gemfibrozil/
15. Fenofibrate/
16. Niacin/
17. or/9-16
18. Diet/ or Diet, Reducing/
19. Exercise Therapy/
20. Weight Loss/
21. (diet or exercise or lifestyle).ti,ab.
22. or/18-21
23. 8 and (17 or 22)
24. limit 23 to yr=“2008 - 2016”

#### Systematic Reviews

##### Database: Ovid MEDLINE(R) without Revisions

1. exp Dyslipidemias/
2. Cholesterol, HDL/bl
3. Cholesterol, LDL/bl
4. Lipids/bl
5. Triglycerides/bl
6. or/2-5
7. Cardiovascular Diseases/pc
8. or/1-7
9. Hypolipidemic Agents/
10. Anticholesteremic Agents/
11. Hydroxymethylglutaryl-CoA Reductase Inhibitors/
12. (atorvastatin or fluvastatin or lovastatin or pitavastatin or pravastatin or rosuvastatin or simvastatin).mp.
13. (lipitor or lescol or mevacor or livalo or pravachol or crestor or zocor).mp.
14. Gemfibrozil/
15. Fenofibrate/
16. Niacin/
17. or/9-16
18. Diet/ or Diet, Reducing/
19. Exercise Therapy/
20. Weight Loss/
21. (diet or exercise or lifestyle).ti,ab.
22. or/18-21
23. 8 and (17 or 22)
24. limit 23 to evidence based medicine reviews
25. limit 24 to (English language and humans)
26. limit 25 to yr=“2008 - 2016”

##### Database: Cochrane Database of Systematic Reviews

1. (lipid$ or cholesterol).ti,ab.
2. 1 not (child$ or pediatric$ or adolescen$ or teen$).mp.
3. limit 2 to full systematic reviews

## Appendix A2 Inclusion and Exclusion Criteria per Key Question

| Include | Exclude
Population | KQs 1–3: Asymptomatic adults ages 21 to 39 years KQs 4–6: Adults ages 21 to 39 years with dyslipidemia | KQs 1–3: Adults with known dyslipidemia (primary or secondary) or prior CVD events KQs 4–6: Adults with prior CVD events
Diseases | Dyslipidemia (as defined according to clinical practice guidelines, lipid levels >90th percentile for lipid components positively associated with CHD risk, or other specified criteria) | Lipid levels not meeting thresholds for dyslipidemia
Screening Interventions | Lipid panel (fasting or nonfasting lipid measurement: total or LDL cholesterol alone or in combination with HDL cholesterol, with or without measurement of other lipid markers) | - Screening with family history only; - Genetic screening only
Screening Comparator | No screening or usual care delivered in a universal or selective screening strategy | Other comparators not listed as included
Treatment Interventions | Drug (e.g., statins) and lifestyle interventions (e.g., exercise and diet changes) | Other types of treatments not listed as included
Treatment Comparator | No treatment or usual care | Other comparators not listed
Outcomes | KQs 1, 4, 5: CHD- and/or CVA-related morbidity or mortality; all-cause mortality KQ 2: Harms associated with the screening process (e.g., false positives, false negatives, psychosocial consequences such as anxiety, overdiagnosis, and others as identified in the literature) KQ 3: Diagnostic yield (true positives/number screened) KQ 6: Harms associated with drug treatment (e.g., myopathy, rhabdomyolysis, myalgia, cognitive loss, diabetes, elevations in liver enzyme or creatine phosphokinase levels, and others as identified in the literature) | KQs 1, 4, 5: Outcomes not listed as included KQ 2: Adverse outcomes not associated with screening KQ 3: Outcomes not listed as included KQ 6: Other adverse outcomes not associated with drug treatment
Study Design | Randomized, controlled trials; cohort studies; case-control studies; high-quality systematic reviews | Other study designs
Settings | - Publication date of 2008 to present; studies included in prior USPSTF reports; - Primary care or primary care–relevant settings | Settings not generalizable to primary care; studies outside the stated timeframe

Abbreviations: CHD=coronary heart disease, CVA=cerebrovascular accident (stroke); CVD=cardiovascular disease, HDL=high-density lipoprotein, KQ=key question; LDL=low-density lipoprotein; USPSTF=U.S. Preventive Services Task Force.

## Appendix A3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

Appendix A3 is a literature flow diagram depicting the search and selection of articles. The diagram shows that 6,068 abstracts of potentially relevant articles were identified through MEDLINE and Cochrane databases. 352 articles were reviewed at the full-text level after excluding 5,716 nonrelevant abstracts and background articles. From the articles reviewed for inclusion, all were excluded for the following reasons: wrong population (59), wrong intervention (10), wrong outcome (46), wrong study design for Key Question (20), not a study (13), wrong population, age older than 40 years (188), or wrong comparison (16).

## Appendix A4 Excluded Studies With Reasons for Exclusion

Key to Exclusion Codes

Code 3 | Wrong population
Code 4 | Wrong intervention
Code 5 | Wrong outcome
Code 6 | Wrong study design for Key Question
Code 7 | Not a study (letter, editorial, nonsystematic review article)
Code 9 | Wrong population (age >40 years)
Code 13 | Wrong comparison

(1984). The Lipid Research Clinics Coronary Primary Prevention Trial results. I. Reduction in incidence of coronary heart disease. JAMA.
(1996). Clinical Guideline, Part 1: guidelines for using serum cholesterol, high-density lipoprotein cholesterol, and triglyceride levels as screening tests for preventing coronary heart disease in adults. Ann Intern Med.
(1999). MRC/BHF Heart Protection Study of cholesterol-lowering therapy and of antioxidant vitamin supplementation in a wide range of patients at increased risk of coronary heart disease death: early safety and efficacy experience. Eur Heart J.
Abourbih S, Filion KB, Joseph L, et al. (2009). Effect of fibrates on lipid profiles and cardiovascular outcomes: a systematic review. Am J Med.
Accord Study Group, Ginsberg HN, Elam MB, et al. (2010). Effects of combination lipid therapy in type 2 diabetes mellitus. N Engl J Med.
Adams SP, Tsang M, Wright JM. (2012). Lipid lowering efficacy of atorvastatin. Cochrane Database Syst Rev.
Adamsson V, Reumark A, Fredriksson IB, et al. (2011). Effects of a healthy Nordic diet on cardiovascular risk factors in hypercholesterolaemic subjects: a randomized controlled trial (NORDIET). J Intern Med.
Ai M, Otokozawa S, Asztalos BF, et al. (2008). Effects of maximal doses of atorvastatin versus rosuvastatin on small dense low-density lipoprotein cholesterol levels. Am J Cardiol.
Alberton M, Wu P, Druyts E, et al. (2012). Adverse events associated with individual statin treatments for cardiovascular disease: an indirect comparison meta-analysis. QJM.
ALLHAT Officers and Coordinators for the ALLHAT Collaborative Research Group. (2002). Major outcomes in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin vs usual care: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT-LLT). JAMA.
Alsheikh-Ali AA, Trikalinos TA, Kent DM, et al. (2008). Statins, low-density lipoprotein cholesterol, and risk of cancer. J Am Coll Cardiol.
Amarenco P, Benavente O, Goldstein LB, et al. (2009). Results of the Stroke Prevention by Aggressive Reduction in Cholesterol Levels (SPARCL) trial by stroke subtypes. Stroke.
Amarenco P, Bogousslavsky J, Callahan Ar, et al. (2006). High-dose atorvastatin after stroke or transient ischemic attack. N Engl J Med.
Amarenco P, Goldstein LB, Callahan A, et al. (2009). Baseline blood pressure, low- and high-density lipoproteins, and triglycerides and the risk of vascular events in the Stroke Prevention by Aggressive Reduction in Cholesterol Levels (SPARCL) trial. Atherosclerosis.
Amarenco P, Goldstein LB, Messig M, et al. (2009). Relative and cumulative effects of lipid and blood pressure control in the Stroke Prevention by Aggressive Reduction in Cholesterol Levels trial. Stroke.
Amarenco P, Labreuche J. (2009). Lipid management in the prevention of stroke: review and updated meta-analysis of statins for stroke prevention. Lancet Neurol.
Angermayr L, Melchart D, Linde K. (2010). Multifactorial lifestyle interventions in the primary and secondary prevention of cardiovascular disease and type 2 diabetes mellitus--a systematic review of randomized controlled trials. Ann Behav Med.
Ara R, Tumur I, Pandor A, et al. (2008). Ezetimibe for the treatment of hypercholesterolaemia: a systematic review and economic evaluation. Health Technol Assess.
Ashen MD, Foody JM. (2009). Evidence-based guidelines for cardiovascular risk reduction: the safety and efficacy of high-dose statin therapy. J Cardiovasc Nurs.
Asselbergs FW, Diercks GF, Hillege HL, et al. (2004). Effects of fosinopril and pravastatin on cardiovascular events in subjects with microalbuminuria. Circulation.
Assmann G, Cullen P, Schulte H. (2002). Simple scoring scheme for calculating the risk of acute coronary events based on the 10-year follow-up of the prospective cardiovascular Munster (PROCAM) study. Circulation.
Assmann G, Schulte H, Funke H, et al. (1998). The emergence of triglycerides as a significant independent risk factor in coronary artery disease. Eur Heart J.
Aung MN, Yuasa M, Moolphate S, et al. (2012). Reducing salt intake for prevention of cardiovascular diseases in high-risk patients by advanced health education intervention (RESIP-CVD study), Northern Thailand: study protocol for a cluster randomized trial. Trials.
Azzarito C, Boiardi L, Vergoni W, et al. (1996). Testicular function in hypercholesterolemic male patients during prolonged simvastatin treatment. Horm Metab Res.
Badheka AO, Rathod A, Kizilbash MA, et al. (2010). Impact of lipid-lowering therapy on outcomes in atrial fibrillation. Am J Cardiol.
Baigent C, Landray MJ, Reith C, et al. (2011). The effects of lowering LDL cholesterol with simvastatin plus ezetimibe in patients with chronic kidney disease (Study of Heart and Renal Protection): a randomised placebo-controlled trial. Lancet.
Baik I, Cho NH, Kim SH, et al. (2013). Dietary information improves cardiovascular disease risk prediction models. Eur J Clin Nutr.
Barylski M, Nikfar S, Mikhailidis DP, et al. (2013). Statins decrease all-cause mortality only in CKD patients not requiring dialysis therapy--a meta-analysis of 11 randomized controlled trials involving 21,295 participants. Pharmacol Res.
Bazzano LA, Thompson AM, Tees MT, et al. (2011). Non-soy legume consumption lowers cholesterol levels: a meta-analysis of randomized controlled trials. Nutr Metab Cardiovasc Dis.
Beishuizen ED, van de Ree MA, Jukema JW, et al. (2004). Two-year statin therapy does not alter the progression of intima-media thickness in patients with type 2 diabetes without manifest cardiovascular disease. Diabetes Care.
Berard E, Bongard V, Dallongeville J, et al. (2011). Cancer mortality according to lipid-lowering drugs and lipoproteins in a general population. Curr Med Res Opin.
Bertoni AG, Bonds DE, Chen H, et al. (2009). Impact of a multifaceted intervention on cholesterol management in primary care practices: guideline adherence for heart health randomized trial. Arch Intern Med.
Blankstein R, Budoff MJ, Shaw LJ, et al. (2011). Predictors of coronary heart disease events among asymptomatic persons with low low-density lipoprotein cholesterol MESA (Multi-Ethnic Study of Atherosclerosis). J Am Coll Cardiol.
Boumendil E, Tubert-Bitter P. (1995). Depression-induced absenteeism in relation to antihyperlipidemic treatment: a study using GAZEL cohort data. Epidemiology.
Broekhuizen K, van Poppel MN, Koppes LL, et al. (2012). No significant improvement of cardiovascular disease risk indicators by a lifestyle intervention in people with familial hypercholesterolemia compared to usual care: results of a randomised controlled trial. BMC Res Notes.
Broekhuizen K, van Poppel MN, Koppes LL, et al. (2010). A tailored lifestyle intervention to reduce the cardiovascular disease risk of individuals with familial hypercholesterolemia (FH): design of the PRO-FIT randomised controlled trial. BMC Public Health.
Bruckert E, Giral P, Paillard F, et al. (2008). Effect of an educational program (PEGASE) on cardiovascular risk in hypercholesterolaemic patients. Cardiovasc Drugs Ther.
Brugts JJ, Yetgin T, Hoeks SE, et al. (2009). The benefits of statins in people without established cardiovascular disease but with cardiovascular risk factors: meta-analysis of randomised controlled trials. BMJ.
Bulbulia R, Armitage J. (2013). Does the benefit from statin therapy extend beyond 5 years?. Curr Atheroscler Rep.
Burgess DC, Hunt D, Li L, et al. (2010). Incidence and predictors of silent myocardial infarction in type 2 diabetes and the effect of fenofibrate: an analysis from the Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study. Eur Heart J.
Burillo E, Andres EM, Mateo-Gallego R, et al. (2010). High-density lipoprotein cholesterol increase and non-cardiovascular mortality: a meta-analysis. Heart.
Chan DK, O'Rourke F, Shen Q, et al. (2011). Meta-analysis of the cardiovascular benefits of intensive lipid lowering with statins. Acta Neurol Scand.
Chan KL, Teo K, Dumesnil JG, et al. (2010). Effect of lipid lowering with rosuvastatin on progression of aortic stenosis: results of the aortic stenosis progression observation: measuring effects of rosuvastatin (ASTRONOMER) trial. Circulation.
Chen YH, Feng B, Chen ZW. (2012). Statins for primary prevention of cardiovascular and cerebrovascular events in diabetic patients without established cardiovascular diseases: a meta-analysis. Exp Clin Endocrinol Diabetes.
Cholesterol Treatment Trialists Collaborators, Kearney PM, Blackwell L, et al. (2008). Efficacy of cholesterol-lowering therapy in 18,686 people with diabetes in 14 randomised trials of statins: a meta-analysis. Lancet.
Chu PH, Chen WJ, Chiang CW, et al. (1997). Rhabdomyolysis, acute renal failure and hepatopathy induced by lovastatin monotherapy. Jpn Heart J.
Claes N, Jacobs N, Clays E, et al. (2013). Comparing the effectiveness of two cardiovascular prevention programmes for highly educated professionals in general practice: a randomised clinical trial. BMC Cardiovasc Disord.
Colhoun HM, Betteridge DJ, Durrington PN, et al. (2004). Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the Collaborative Atorvastatin Diabetes Study (CARDS): multicentre randomised placebo-controlled trial. Lancet.
Colhoun HM, Betteridge DJ, Durrington PN, et al. (2009). Effects of atorvastatin on kidney outcomes and cardiovascular disease in patients with diabetes: an analysis from the Collaborative Atorvastatin Diabetes Study (CARDS). Am J Kidney Dis.
Collier DJ, Poulter NR, Dahlof B, et al. (2011). Impact of atorvastatin among older and younger patients in the Anglo-Scandinavian Cardiac Outcomes Trial Lipid-Lowering Arm. J Hypertens.
Collins R, Armitage J, Parish S, et al. (2003). MRC/BHF Heart Protection Study of cholesterol-lowering with simvastatin in 5963 people with diabetes: a randomised placebo-controlled trial. Lancet.
Conroy RM, Pyorala K, Fitzgerald AP, et al. (2003). Estimation of ten-year risk of fatal cardiovascular disease in Europe: the SCORE project. Eur Heart J.
Contermans J, Smit JW, Bar PR, et al. (1995). A comparison of the effects of simvastatin and pravastatin monotherapy on muscle histology and permeability in hypercholesterolaemic patients. Br J Clin Pharmacol.
Cooney MT, Dudina A, Whincup P, et al. (2009). Re-evaluating the Rose approach: comparative benefits of the population and high-risk preventive strategies. Eur J Cardiovasc Prev Rehabil.
Cushman M, McClure LA, Lakoski SG, et al. (2010). Eligibility for statin therapy by the JUPITER trial criteria and subsequent mortality. Am J Cardiol.
Cutler N, Sramek J, Veroff A, et al. (1995). Effects of treatment with simvastatin and pravastatin on cognitive function in patients with hypercholesterolaemia. Br J Clin Pharmacol.
D'Agostino RB, Vasan RS, Pencina MJ, et al. (2008). General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation.
Dansky HM, Bloomfield D, Gibbons P, et al. (2011). Efficacy and safety after cessation of treatment with the cholesteryl ester transfer protein inhibitor anacetrapib (MK-0859) in patients with primary hypercholesterolemia or mixed hyperlipidemia. Am Heart J.
Davidson MH, Rooney MW, Drucker J, et al. (2009). Efficacy and tolerability of atorvastatin/fenofibrate fixed-dose combination tablet compared with atorvastatin and fenofibrate monotherapies in patients with dyslipidemia: a 12-week, multicenter, double-blind, randomized, parallel-group study. Clin Ther.
de Jong A, Plat J, Lutjohann D, et al. (2008). Effects of long-term plant sterol or stanol ester consumption on lipid and lipoprotein metabolism in subjects on statin treatment. Br J Nutr.
De Lorenzo F. (2008). UK screening plans. Lancet.
de Vries FM, Denig P, Pouwels KB, et al. (2012). Primary prevention of major cardiovascular and cerebrovascular events with statins in diabetic patients: a meta-analysis. Drugs.
DeGorter MK, Tirona RG, Schwarz UI, et al. (2013). Clinical and pharmacogenetic predictors of circulating atorvastatin and rosuvastatin concentrations in routine clinical care. Circulation.
Delahoy PJ, Magliano DJ, Webb K, et al. (2009). The relationship between reduction in low-density lipoprotein cholesterol by statins and reduction in risk of cardiovascular outcomes: an updated meta-analysis. Clin Ther.
Delluc A, Malecot JM, Kerspern H, et al. (2012). Lipid parameters, lipid lowering drugs and the risk of venous thromboembolism. Atherosclerosis.
Devaraj S, Hirany S, Jialal I. (2000). Ratio of remnant-like particle cholesterol to serum total triglycerides is a reliable screening test for type III dyslipidaemia. Ann Clin Biochem.
Di Angelantonio E, Sarwar N, Perry P, et al. (2009). Major lipids, apolipoproteins, and risk of vascular disease. JAMA.
Diercks DB, Kirk JD, Turnipseed SD, et al. (2002). Cholesterol screening in an ED-based chest pain unit. Am J Emerg Med.
Dunkley AJ, Charles K, Gray LJ, et al. (2012). Effectiveness of interventions for reducing diabetes and cardiovascular disease risk in people with metabolic syndrome: systematic review and mixed treatment comparison meta-analysis. Diabetes Obes Metab.
Durand G, Tsismenakis AJ, Jahnke SA, et al. (2011). Firefighters' physical activity: relation to fitness and cardiovascular disease risk. Med Sci Sports Exerc.
Eaton CB, Parker DR, Borkan J, et al. (2011). Translating cholesterol guidelines into primary care practice: a multimodal cluster randomized trial. Ann Fam Med.
Ebrahimpour P, Fakhrzadeh H, Heshmat R, et al. (2008). Serum uric acid levels and risk of metabolic syndrome in healthy adults. Endocr Pract.
Edo A, Adediran OS. (2011). Dyslipidaemia among Nigerian oil workers with type 2 diabetes mellitus. West Afr J Med.
Edwards JB, Tudiver F. (2008). Women's preventive screening in rural health clinics. Women Health Iss.
Egede R, Jensen LO, Hansen HS, et al. (2012). Effect of intensive lipid-lowering treatment compared to moderate lipid-lowering treatment with rosuvastatin on endothelial function in high risk patients. Int J Cardiol.
Egert S, Bosy-Westphal A, Seiberl J, et al. (2009). Quercetin reduces systolic blood pressure and plasma oxidised low-density lipoprotein concentrations in overweight subjects with a high-cardiovascular disease risk phenotype: a double-blinded, placebo-controlled cross-over study. Br J Nutr.
Einvik G, Ekeberg O, Lavik JG, et al. (2010). The influence of long-term awareness of hyperlipidemia and of 3 years of dietary counseling on depression, anxiety, and quality of life. J Psychosom Res.
Ejtahed HS, Mohtadi-Nia J, Homayouni-Rad A, et al. (2011). Effect of probiotic yogurt containing Lactobacillus acidophilus and Bifidobacterium lactis on lipid profile in individuals with type 2 diabetes mellitus. J Dairy Sci.
Elbarasi EA, Goodman SG, Yan RT, et al. (2013). Management of risk factors among ambulatory patients at high cardiovascular risk in Canada: a follow-up study. Can J Cardiol.
Eliasson B, Moller-Goede D, Eeg-Olofsson K, et al. (2012). Lowering of postprandial lipids in individuals with type 2 diabetes treated with alogliptin and/or pioglitazone: a randomised double-blind placebo-controlled study. Diabetologia.
Elis A, Pereg D, Tirosh A, et al. (2008). Family history of cardiovascular disease does not predict risk-reducing behavior. Eur J Cardiovasc Prev Rehabil.
Enger C, Gately R, Ming EE, et al. (2010). Pharmacoepidemiology safety study of fibrate and statin concomitant therapy. Am J Cardiol.
Enright KA, Krzyzanowska MK. (2010). Control of cardiovascular risk factors among adult cancer survivors: a population-based survey. Cancer Causes Control.
Eriksson M, Budinski D, Hounslow N. (2011). Long-term efficacy of pitavastatin versus simvastatin. Adv Ther.
Eriksson M, Budinski D, Hounslow N. (2011). Comparative efficacy of pitavastatin and simvastatin in high-risk patients: a randomized controlled trial. Adv Ther.
Ersoy C, Kiyici S, Budak F, et al. (2008). The effect of metformin treatment on VEGF and PAI-1 levels in obese type 2 diabetic patients. Diabetes Res Clin Pract.
Estoppey D, Paccaud F, Vollenweider P, et al. (2011). Trends in self-reported prevalence and management of hypertension, hypercholesterolemia and diabetes in Swiss adults, 1997-2007. BMC Public Health.
Everett BM, Glynn RJ, MacFadyen JG, et al. (2010). Rosuvastatin in the prevention of stroke among men and women with elevated levels of C-reactive protein: justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER). Circulation.
Faatoese AF, Pitama SG, Gillies TW, et al. (2011). Community screening for cardiovascular risk factors and levels of treatment in a rural Maori cohort. Aust N Z J Public Health.
Faergeman O, Hill L, Windler E, et al. (2008). Efficacy and tolerability of rosuvastatin and atorvastatin when force-titrated in patients with primary hypercholesterolemia: results from the ECLIPSE study. Cardiology.
Faghihimani E, Adibi P, Amini M. (2009). Dyslipidaemia and its management in diabetic patients in an academic centre in Iran. Endokrynol Pol.
Fallon KE. (2008). The clinical utility of screening of biochemical parameters in elite athletes: analysis of 100 cases. BJSM Online.
Farmer JA. (2009). Simvastatin with or without ezetimibe in familial hypercholesterolemia (the ENHANCE trial). Curr Atheroscler Rep.
Farnier M, Averna M, Missault L, et al. (2009). Lipid-altering efficacy of ezetimibe/simvastatin 10/20 mg compared with rosuvastatin 10 mg in high-risk hypercholesterolaemic patients inadequately controlled with prior statin monotherapy: the IN-CROSS study. Int J Clin Pract.
Farnier M, Ducobu J, Bryniarski L. (2011). Long-term safety and efficacy of fenofibrate/pravastatin combination therapy in high risk patients with mixed hyperlipidemia not controlled by pravastatin monotherapy. Curr Med Res Opin.
Farnier M, Marcereuil D, De Niet S, et al. (2012). Safety of a fixed-dose combination of fenofibrate/pravastatin 160 mg/40 mg in patients with mixed hyperlipidaemia: a pooled analysis from a database of clinical trials. Clin Drug Invest.
Farnier M, Perevozskaya I, Taggart WV, et al. (2008). VAP II analysis of lipoprotein subclasses in mixed hyperlipidemic patients on treatment with ezetimibe/simvastatin and fenofibrate. J Lipid Res.
Fazio S, Guyton JR, Polis AB, et al. (2010). Long-term safety and efficacy of triple combination ezetimibe/simvastatin plus extended-release niacin in patients with hyperlipidemia. Am J Cardiol.
Felix-Redondo FJ, Fernandez-Berges D, Grau M, et al. (2012). Prevalence and clinical characteristics of peripheral arterial disease in the study population Hermex. Rev Esp Cardiol (Engl).
Feresu SA, Zhang W, Puumala SE, et al. (2008). The frequency and distribution of cardiovascular disease risk factors among Nebraska women enrolled in the WISEWOMAN screening program. J Womens Health (Larchmt).
Filip RS, Panasiuk L, Haratym-Maj A, et al. (2006). Serum lipid profile and metabolic syndrome occurrence among obese rural women from Lublin Region (Eastern Poland). Ann Agric Environ Med.
Firmann M, Marques-Vidal P, Paccaud F, et al. (2010). Prevalence, treatment and control of dyslipidaemia in Switzerland: still a long way to go. Eur J Cardiovasc Prev Rehabil.
Fitzgerald KC, Chiuve SE, Buring JE, et al. (2012). Comparison of associations of adherence to a Dietary Approaches to Stop Hypertension (DASH)-style diet with risks of cardiovascular disease and venous thromboembolism. J Thromb Haemost.
Flack JM, Victor R, Watson K, et al. (2008). Improved attainment of blood pressure and cholesterol goals using single-pill amlodipine/atorvastatin in African Americans: the CAPABLE trial. Mayo Clin Proc.
Florentin M, Liberopoulos EN, Moutzouri E, et al. (2011). The effect of simvastatin alone versus simvastatin plus ezetimibe on the concentration of small dense low-density lipoprotein cholesterol in subjects with primary hypercholesterolemia. Curr Med Res Opin.
Fonseca FA, Izar MC. (2009). Primary prevention of vascular events in patients with high levels of C-reactive protein: the JUPITER study. Expert Rev Cardiovasc Ther.
Fontbonne A, Diouf I, Baccara-Dinet M, et al. (2009). Effects of 1-year treatment with metformin on metabolic and cardiovascular risk factors in non-diabetic upper-body obese subjects with mild glucose anomalies: a post-hoc analysis of the BIGPRO1 trial. Diabetes Metab.
Foody JM, Joyce AT, Rudolph AE, et al. (2008). Cardiovascular outcomes among patients newly initiating atorvastatin or simvastatin therapy: a large database analysis of managed care plans in the United States. Clin Ther.
Foucan L, Hanley J, Deloumeaux J, et al. (2002). Body mass index (BMI) and waist circumference (WC) as screening tools for cardiovascular risk factors in Guadeloupean women. J Clin Epidemiol.
Fouchier SW, Defesche JC, Kastelein JJ, et al. (2004). Familial defective apolipoprotein B versus familial hypercholesterolemia: an assessment of risk. Semin.
Frantz ID, Dawson EA, Ashman PL, et al. (1989). Test of effect of lipid lowering by diet on cardiovascular risk. The Minnesota Coronary Survey. Arteriosclerosis.
Friedman HS, Rajagopalan S, Barnes JP, et al. (2011). Combination therapy with ezetimibe/simvastatin versus statin monotherapy for low-density lipoprotein cholesterol reduction and goal attainment in a real-world clinical setting. Clin Ther.
Gaede P, Lund-Andersen H, Parving HH, et al. (2008). Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med.
Gasevic D, Frohlich J, Mancini GB, et al. (2012). The association between triglyceride to high-density-lipoprotein cholesterol ratio and insulin resistance in a multiethnic primary prevention cohort. Metabolism.
Ge CJ, Lu SZ, Chen YD, et al. (2008). Synergistic effect of amlodipine and atorvastatin on blood pressure, left ventricular remodeling, and C-reactive protein in hypertensive patients with primary hypercholesterolemia. Heart Vessels.
Geng Q, Ren J, Chen H, et al. (2013). Adverse events of statin-fenofibric acid versus statin monotherapy: a meta-analysis of randomized controlled trials. Curr Med Res Opin.
Geng Q, Ren J, Chen H, et al. (2013). Adverse events following statin-fenofibrate therapy versus statin alone: a meta-analysis of randomized controlled trials. Clin Exp Pharmacol Physiol.
Genser B, Grammer TB, Stojakovic T, et al. (2008). Effect of HMG CoA reductase inhibitors on low-density lipoprotein cholesterol and C-reactive protein: systematic review and meta-analysis. Int J Clin Pharmacol Ther.
Genuth S, Ismail-Beigi F. (2012). Clinical implications of the ACCORD trial. J Clin Endocrinol Metab.
Gheith O, Sheashaa H, Abdelsalam M, et al. (2009). Efficacy and safety of Monascus purpureus Went rice in children and young adults with secondary hyperlipidemia: a preliminary report. Eur J Intern Med.
Giraldez RR, Giugliano RP, Mohanavelu S, et al. (2008). Baseline low-density lipoprotein cholesterol is an important predictor of the benefit of intensive lipid-lowering therapy: a PROVE IT-TIMI 22 (Pravastatin or Atorvastatin Evaluation and Infection Therapy-Thrombolysis In Myocardial Infarction 22) analysis. J Am Coll Cardiol.
Glynn RJ, Danielson E, Fonseca FA, et al. (2009). A randomized trial of rosuvastatin in the prevention of venous thromboembolism. N Engl J Med.
Glynn RJ, MacFadyen JG, Ridker PM. (2009). Tracking of high-sensitivity C-reactive protein after an initially elevated concentration: the JUPITER Study. Clin Chem.
Goldberg AC, Bays HE, Ballantyne CM, et al. (2009). Efficacy and safety of ABT-335 (fenofibric acid) in combination with atorvastatin in patients with mixed dyslipidemia. Am J Cardiol.
Goldberg AC, Bittner V, Pepine CJ, et al. (2011). Efficacy of fenofibric acid plus statins on multiple lipid parameters and its safety in women with mixed dyslipidemia. Am J Cardiol.
Goldberg RB, Rosenson RS, Hernandez-Triana E, et al. (2013). Colesevelam improved lipoprotein particle subclasses in patients with prediabetes and primary hyperlipidaemia. Diab Vasc Dis Res.
Goldberg RB, Sabharwal AK. (2008). Fish oil in the treatment of dyslipidemia. Curr Opin Endocrionl Diabetes Obes.
Goldstein MR, Mascitelli L, Pezzetta F, et al. (2009). Use of statins and incidence of dementia and cognitive impairment without dementia in a cohort study. Neurology.
Golomb BA, Dimsdale JE, White HL, et al. (2008). Reduction in blood pressure with statins: results from the UCSD Statin Study, a randomized trial. Arch Intern Med.
Gomez-Huelgas R, Mancera-Romero J, Bernal-Lopez MR, et al. (2011). Prevalence of cardiovascular risk factors in an urban adult population from southern Spain. IMAP Study. Int J Clin Pract.
Grau M, Subirana I, Elosua R, et al. (2010). Why should population attributable fractions be periodically recalculated? An example from cardiovascular risk estimation in southern Europe. Prev Med.
Gray J, Edwards SJ, Lip GY. (2010). Comparison of sequential rosuvastatin doses in hypercholesterolaemia: a meta-analysis of randomised controlled trials. Curr Med Res Opin.
Grover S, Coupal L, Kouache M, et al. (2011). Estimating the benefits of patient and physician adherence to cardiovascular prevention guidelines: the MyHealthCheckup Survey. Can J Cardiol.
Grover SA, Dorais M, Paradis G, et al. (2000). Lipid screening to prevent coronary artery disease: a quantitative evaluation of evolving guidelines. CMAJ.
Grover SA, Levinton C, Paquet S. (1999). Identifying adults at low risk for significant hyperlipidemia: a validated clinical index. J Clin Epidemiol.
Grundy SM, Vega GL, Tomassini JE, et al. (2011). Comparisons of apolipoprotein B levels estimated by immunoassay, nuclear magnetic resonance, vertical auto profile, and non-high-density lipoprotein cholesterol in subjects with hypertriglyceridemia (SAFARI Trial). Am J Cardiol.
Gu Y, Warren J, Walker N, et al. (2013). Gender differences in cardiovascular disease risk management for Pacific Islanders in primary care. Qual Prim Care.
Guibert R, Leduc N, Fournier P, et al. (1999). What factors determine whether individuals found to have hypercholesterolaemia at mass screening accept advice to visit their physician. Public Health.
Gumprecht J, Gosho M, Budinski D, et al. (2011). Comparative long-term efficacy and tolerability of pitavastatin 4 mg and atorvastatin 20-40 mg in patients with type 2 diabetes mellitus and combined (mixed) dyslipidaemia. Diabetes Obes Metab.
Guo J, Meng F, Ma N, et al. (2012). Meta-analysis of safety of the coadministration of statin with fenofibrate in patients with combined hyperlipidemia. Am J Cardiol.
Guo Z, Liu XM, Zhang QX, et al. (2011). Influence of consumption of probiotics on the plasma lipid profile: a meta-analysis of randomised controlled trials. Nutr Metab Cardiovasc Dis.
Gutierrez J, Ramirez G, Rundek T, et al. (2012). Statin therapy in the prevention of recurrent cardiovascular events: a sex-based meta-analysis. Arch Intern Med.
Guyton JR, Brown BG, Fazio S, et al. (2008). Lipid-altering efficacy and safety of ezetimibe/simvastatin coadministered with extended-release niacin in patients with type IIa or type IIb hyperlipidemia. J Am Coll Cardiol.
Haag MD, Hofman A, Koudstaal PJ, et al. (2009). Statins are associated with a reduced risk of Alzheimer disease regardless of lipophilicity. The Rotterdam Study. J Neurol Neurosurg Psychiatry.
Haglin L, Lundstrom S, Kaati G, et al. (2011). All-cause mortality of patients with dyslipidemia up to 19 years after a multidisciplinary lifestyle modification programme: a randomized trial. Eur J Cardiovasc Prev Rehabil.
Halbert SC, French B, Gordon RY, et al. (2010). Tolerability of red yeast rice (2,400 mg twice daily) versus pravastatin (20 mg twice daily) in patients with previous statin intolerance. Am J Cardiology.
Helfand M, Buckley DI, Freeman M, et al. (2009). Emerging risk factors for coronary heart disease: a summary of systematic reviews conducted for the U.S. Preventive Services Task Force. Ann Intern Med.
Hellenius ML, de Faire U, Berglund B, et al. (1993). Diet and exercise are equally effective in reducing risk for cardiovascular disease: results of a randomized controlled study in men with slightly to moderately raised cardiovascular risk factors. Atherosclerosis.
Hippisley-Cox J, Coupland C. (2010). Unintended effects of statins in men and women in England and Wales: population based cohort study using the QResearch database. BMJ.
Hoffmann MM, Marz W, Genser B, et al. (2011). Lack of association between the Trp719Arg polymorphism in kinesin-like protein-6 and cardiovascular risk and efficacy of atorvastatin among subjects with diabetes on dialysis: the 4D study. Atherosclerosis.
Hooper L, Summerbell CD, Thompson R, et al. (2011). Reduced or modified dietary fat for preventing cardiovascular disease. Cochrane Database Syst Rev.
Hooper L, Summerbell CD, Thompson R, et al. (2012). Reduced or modified dietary fat for preventing cardiovascular disease. Cochrane Database Syst Rev.
Hou W, Lv J, Perkovic V, et al. (2013). Effect of statin therapy on cardiovascular and renal outcomes in patients with chronic kidney disease: a systematic review and meta-analysis. Eur Heart J.
Hsia J, MacFadyen JG, Monyak J, et al. (2011). Cardiovascular event reduction and adverse events among subjects attaining low-density lipoprotein cholesterol <50 mg/dL with rosuvastatin. The JUPITER trial (Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin). J Am Coll Cardiol.
Iseki K, Tozawa M, Ikemiya Y, et al. (2005). Relationship between dyslipidemia and the risk of developing end-stage renal disease in a screened cohort. Clin Exp Nephrol.
Itakura H, Kita T, Mabuchi H, et al. (2008). Relationship between coronary events and serum cholesterol during 10 years of low-dose simvastatin therapy: long-term efficacy and safety in Japanese patients with hypercholesterolemia in the Japan Lipid Intervention Trial (J-LIT) Extension 10 Study, a prospective large-scale observational cohort study. Circ J.
Ito MK. (2012). Dyslipidemia: management using optimal lipid-lowering therapy. Ann Pharmacother.
Jorgensen T, Ladelund S, Borch-Johnsen K, et al. (2009). Screening for risk of cardiovascular disease is not associated with mental distress: the Inter99 study. Prev Med.
Josan K, Majumdar SR, McAlister FA. (2008). The efficacy and safety of intensive statin therapy: a meta-analysis of randomized trials. CMAJ.
Jun M, Foote C, Lv J, et al. (2010). Effects of fibrates on cardiovascular outcomes: a systematic review and meta-analysis. Lancet.
Kadoglou NP, Sailer N, Moumtzouoglou A, et al. (2010). Aggressive lipid-lowering is more effective than moderate lipid-lowering treatment in carotid plaque stabilization. J Vasc Surg.
Karlson BW, Nicholls SJ, Lundman P, et al. (2013). Achievement of 2011 European low-density lipoprotein cholesterol (LDL-C) goals of either <70 mg/dL or >50% reduction in high-risk patients: results from VOYAGER. Atherosclerosis.
Keenan JM. (2013). Wax-matrix extended-release niacin vs inositol hexanicotinate: a comparison of wax-matrix, extended-release niacin to inositol hexanicotinate “no-flush” niacin in persons with mild to moderate dyslipidemia. J Clin Lipidol.
Kelishadi R, Ardalan G, Gheiratmand R, et al. (2006). Is family history of premature cardiovascular diseases appropriate for detection of dyslipidemic children in population-based preventive medicine programs? CASPIAN study. Pediatr Cardiol.
Kesse-Guyot E, Touvier M, Henegar A, et al. (2011). Higher adherence to French dietary guidelines and chronic diseases in the prospective SU.VI.MAX cohort. Eur J Clin Nutr.
Khemasuwan D, Divietro ML, Tangdhanakanond K, et al. (2010). Statins decrease the occurrence of venous thromboembolism in patients with cancer. Am J Med.
Kim C, Kerr EA, Bernstein SJ, et al. (2006). Gender disparities in lipid management: the presence of disparities depends on the quality measure. Am J Manag Care.
Kizer JR, Madias C, Wilner B, et al. (2010). Relation of different measures of low-density lipoprotein cholesterol to risk of coronary artery disease and death in a meta-regression analysis of large-scale trials of statin therapy. Am J Cardiol.
Kojima S, Sakamoto T, Ogawa H, et al. (2010). Standard-dose statin therapy provides incremental clinical benefits in normocholesterolemic diabetic patients. Circ J.
Kokkinos PF, Faselis C, Myers J, et al. (2013). Interactive effects of fitness and statin treatment on mortality risk in veterans with dyslipidaemia: a cohort study. Lancet.
Kostis JB, Breazna A, Deedwania PC, et al. (2008). The benefits of intensive lipid lowering in patients with stable coronary heart disease with normal or high systolic blood pressure: an analysis of the Treating to New Targets (TNT) study. J Clin Hypertens (Greenwich).
Kostis WJ, Cheng JQ, Dobrzynski JM, et al. (2012). Meta-analysis of statin effects in women versus men. J Am Coll Cardiol.
Krane V, Winkler K, Drechsler C, et al. (2009). Association of LDL cholesterol and inflammation with cardiovascular events and mortality in hemodialysis patients with type 2 diabetes mellitus. Am J Kidney Dis.
Kruger P, Bailey M, Bellomo R, et al. (2013). A multicenter randomized trial of atorvastatin therapy in intensive care patients with severe sepsis. Am J Respir Crit Care Med.
Kruse LG, Ogletree RL. (2013). Omega-3 fatty acids and cardiovascular risk. J Miss State Med Assoc.
Ku E, Campese V. (2013). Is lipid management effective for all stages of CKD?. Blood Purif.
Kushiro T, Mizuno K, Nakaya N, et al. (2009). Pravastatin for cardiovascular event primary prevention in patients with mild-to-moderate hypertension in the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) study. Hypertension.
Kushiro T, Mizuno K, Nakaya N, et al. (2012). Blood pressure control status and effects of pravastatin on cardiovascular events occurrence in patients with dyslipidaemia. J Hum Hypertens.
Labreuche J, Deplanque D, Touboul PJ, et al. (2010). Association between change in plasma triglyceride levels and risk of stroke and carotid atherosclerosis: systematic review and meta-regression analysis. Atherosclerosis.
Lafeber M, Spiering W, van der Graaf Y, et al. (2013). The combined use of aspirin, a statin, and blood pressure-lowering agents (polypill components) and the risk of vascular morbidity and mortality in patients with coronary artery disease. Am Heart J.
Lagiou P, Sandin S, Lof M, et al. (2012). Low carbohydrate-high protein diet and incidence of cardiovascular diseases in Swedish women: prospective cohort study. BMJ.
Lavigne PM, Karas RH. (2013). The current state of niacin in cardiovascular disease prevention: a systematic review and meta-regression. J Am Coll Cardiol.
Lee M, Saver JL, Towfighi A, et al. (2011). Efficacy of fibrates for cardiovascular risk reduction in persons with atherogenic dyslipidemia: a meta-analysis. Atherosclerosis.
Leuschen J, Mortensen EM, Frei CR, et al. (2013). Association of statin use with cataracts: a propensity score-matched analysis. JAMA Ophthalmol.
Li TY, Brennan AM, Wedick NM, et al. (2009). Regular consumption of nuts is associated with a lower risk of cardiovascular disease in women with type 2 diabetes. J Nutr.
Lindblad B, Borner G, Gottsater A. (2005). Factors associated with development of large abdominal aortic aneurysm in middle-aged men. Eur J Vasc Endovasc Surg.
Liu ZL, Li GQ, Bensoussan A, et al. (2013). Chinese herbal medicines for hypertriglyceridaemia. Cochrane Database Syst Rev.
Livschitz S, Sharabi Y, Yushin J, et al. (2000). Limited clinical value of exercise stress test for the screening of coronary artery disease in young, asymptomatic adult men. Am J Cardiol.
Look AR, Wing RR, Bolin P, et al. (2013). Cardiovascular effects of intensive lifestyle intervention in type 2 diabetes. N Engl J Med.
Ma T, Tien L, Fang CL, et al. (2012). Statins and new-onset diabetes: a retrospective longitudinal cohort study. Clin Ther.
Maharjan N, Bedi U, Arora R, et al. (2011). Impact of statins on cardiovascular outcomes in renal transplant recipients: a systematic review. Am J Ther.
Margolis KL, Dunn K, Simpson LM, et al. (2009). Coronary heart disease in moderately hypercholesterolemic, hypertensive black and non-black patients randomized to pravastatin versus usual care: the Antihypertensive and Lipid Lowering to prevent Heart Attack Trial (ALLHAT-LLT). Am Heart J.
Marks D, Thorogood M, Neil SM, et al. (2006). Cascade screening for familial hypercholesterolaemia: implications of a pilot study for national screening programmes. J Med Screen.
Marks D, Wonderling D, Thorogood M, et al. (2000). Screening for hypercholesterolaemia versus case finding for familial hypercholesterolaemia: a systematic review and cost-effectiveness analysis. Health Technol Assess.
Martinez-Gonzalez MA, Garcia-Lopez M, Bes-Rastrollo M, et al. (2011). Mediterranean diet and the incidence of cardiovascular disease: a Spanish cohort. Nutr Metab Cardiovasc Dis.
McGrath ER, Glynn LG, Murphy AW, et al. (2012). Preventing cardiovascular disease in primary care: role of a national risk factor management program. Am Heart J.
Meuwese MC, de Groot E, Duivenvoorden R, et al. (2009). ACAT inhibition and progression of carotid atherosclerosis in patients with familial hypercholesterolemia: the CAPTIVATE randomized trial. JAMA.
Mihaylova B, Emberson J, Blackwell L, et al. (2012). The effects of lowering LDL cholesterol with statin therapy in people at low risk of vascular disease: meta-analysis of individual data from 27 randomised trials. Lancet.
Mills EJ, O'Regan C, Eyawo O, et al. (2011). Intensive statin therapy compared with moderate dosing for prevention of cardiovascular events: a meta-analysis of >40,000 patients. Eur Heart J.
Mills EJ, Rachlis B, Wu P, et al. (2008). Primary prevention of cardiovascular mortality and events with statin treatments: a network meta-analysis involving more than 65,000 patients. J Am Coll Cardiol.
Mills EJ, Wu P, Chong G, et al. (2011). Efficacy and safety of statin treatment for cardiovascular disease: a network meta-analysis of 170,255 patients from 76 randomized trials. QJM.
Mizuno K, Nakaya N, Ohashi Y, et al. (2008). Usefulness of pravastatin in primary prevention of cardiovascular events in women: analysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA study). Circulation.
Mizuno K, Nakaya N, Teramoto T, et al. (2012). Usefulness of LDL-C-related parameters to predict cardiovascular risk and effect of pravastatin in mild-to-moderate hypercholesterolemia. J Atheroscler Thromb.
Mora S, Glynn RJ, Boekholdt SM, et al. (2012). On-treatment non-high-density lipoprotein cholesterol, apolipoprotein B, triglycerides, and lipid ratios in relation to residual vascular risk after treatment with potent statin therapy: JUPITER (Justification for the Use of Statins in Prevention: An Intervention Trial Evaluating Rosuvastatin). J Am Coll Cardiol.
Mora S, Glynn RJ, Hsia J, et al. (2010). Statins for the primary prevention of cardiovascular events in women with elevated high-sensitivity C-reactive protein or dyslipidemia: results from the Justification for the Use of Statins in Prevention: An Intervention Trial Evaluating Rosuvastatin (JUPITER) and meta-analysis of women from primary prevention trials. Circulation.
Mora S, Glynn RJ, Ridker PM. (2013). High-density lipoprotein cholesterol, size, particle number, and residual vascular risk after potent statin therapy. Circulation.
Mora S, Musunuru K, Blumenthal RS. (2009). The clinical utility of high-sensitivity C-reactive protein in cardiovascular disease and the potential implication of JUPITER on current practice guidelines. Clin Chem.
Mora S, Wenger NK, Demicco DA, et al. (2012). Determinants of residual risk in secondary prevention patients treated with high- versus low-dose statin therapy: the Treating to New Targets (TNT) study. Circulation.
Mori Y, Kuriyama G, Tanaka T, et al. (2009). Usefulness of aggressive lipid-lowering therapy with rosuvastatin in hypercholesterolemic patients with concomitant type 2 diabetes. Endocrine.
Morishita R, Itakura H, Nakaya N, et al. (2012). Risk factors for cardiovascular events in Japanese patients treated with fluvastatin from the Long-term Event Monitoring (LEM) study. Curr Vasc Pharmacol.
Motsko SP, Russmann S, Ming EE, et al. (2009). Effectiveness of rosuvastatin compared to other statins for the prevention of cardiovascular events-a cohort study in 395,039 patients from clinical practice. Pharmacoepidemiol Drug Saf.
Muldoon MF, Ryan CM, Sereika SM, et al. (2004). Randomized trial of the effects of simvastatin on cognitive functioning in hypercholesterolemic adults. Am J Med.
Murphy AW, Cupples ME, Smith SM, et al. Effect of tailored practice and patient care plans on secondary prevention of heart disease in general practice: cluster randomised controlled trial. BMJ.
Naci H, Brugts J, Ades T. (2013). Comparative tolerability and harms of individual statins: a study-level network meta-analysis of 246,955 participants from 135 randomized, controlled trials. Circulation.
Naci H, Brugts JJ, Fleurence R, et al. (2013). Comparative benefits of statins in the primary and secondary prevention of major coronary events and all-cause mortality: a network meta-analysis of placebo-controlled and active-comparator trials. Eur J Prev Cardiolog.
Nakamura H, Mizuno K, Ohashi Y, et al. (2009). Pravastatin and cardiovascular risk in moderate chronic kidney disease. Atherosclerosis.
Nakamura Y, Ueshima H, Okamura T, et al. (2009). A Japanese diet and 19-year mortality: national integrated project for prospective observation of non-communicable diseases and its trends in the aged, 1980. Br J Nutr.
Nakaya N, Mizuno K, Ohashi Y, et al. (2011). Low-dose pravastatin and age-related differences in risk factors for cardiovascular disease in hypercholesterolaemic Japanese: analysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA study). Drugs Aging.
Navaneethan SD, Nigwekar SU, Perkovic V, et al. (2009). HMG CoA reductase inhibitors (statins) for dialysis patients. Cochrane Database Syst Rev.
Navaneethan SD, Pansini F, Perkovic V, et al. (2009). HMG CoA reductase inhibitors (statins) for people with chronic kidney disease not requiring dialysis. Cochrane Database Syst Rev.
Navaneethan SD, Perkovic V, Johnson DW, et al. (2009). HMG CoA reductase inhibitors (statins) for kidney transplant recipients. Cochrane Database Syst Rev.
Navigator Study Group, Holman RR, Haffner SM, et al. (2010). Effect of nateglinide on the incidence of diabetes and cardiovascular events. N Engl J Med.
Newman CB, Szarek M, Colhoun HM, et al. (2008). The safety and tolerability of atorvastatin 10 mg in the Collaborative Atorvastatin Diabetes Study (CARDS). Diab Vasc Dis Res.
Norby GE, Holme I, Fellstrom B, et al. (2009). Effect of fluvastatin on cardiac outcomes in kidney transplant patients with systemic lupus erythematosus: a randomized placebo-controlled study. Arthritis Rheum.
Ong HT, Cheah JS. (2008). Statin alternatives or just placebo: an objective review of omega-3, red yeast rice and garlic in cardiovascular therapeutics. Chin Med J.
Oren A, Vos LE, Uiterwaal CS, et al. (2003). The Atherosclerosis Risk in Young Adults (ARYA) study: rationale and design. Eur J Epidemiol.
Owen CG, Carey IM, Shah S, et al. (2010). Hypotensive medication, statins, and the risk of glaucoma. Invest Ophthalmol Vis Sci.
Palmer SC, Craig JC, Navaneethan SD, et al. (2012). Benefits and harms of statin therapy for persons with chronic kidney disease: a systematic review and meta-analysis. Ann Intern Med.
Pan A, Chen M, Chowdhury R, et al. (2012). Alpha-linolenic acid and risk of cardiovascular disease: a systematic review and meta-analysis. Am J Clin Nutr.
Parish S, Offer A, Clarke R, et al. (2012). Lipids and lipoproteins and risk of different vascular events in the MRC/BHF Heart Protection Study. Circulation.
Peters BJ, Maitland-van der Zee AH, Stricker BH, et al. (2008). Effectiveness of statins in the reduction of the risk of myocardial infarction is modified by the GNB3 C825T variant. Pharmacogenet Genomics.
Peters BJ, Pett H, Klungel OH, et al. (2011). Genetic variability within the cholesterol lowering pathway and the effectiveness of statins in reducing the risk of MI. Atherosclerosis.
Petretta M, Costanzo P, Perrone-Filardi P, et al. (2010). Impact of gender in primary prevention of coronary heart disease with statin therapy: a meta-analysis. Int J Cardiol.
Preiss D, Tikkanen MJ, Welsh P, et al. (2012). Lipid-modifying therapies and risk of pancreatitis: a meta-analysis. JAMA.
Price HC, Coleman RL, Stevens RJ, et al. (2009). Impact of using a non-diabetes-specific risk calculator on eligibility for statin therapy in type 2 diabetes. Diabetologia.
Rahilly-Tierney CR, Lawler EV, Scranton RE, et al. (2009). Cardiovascular benefit of magnitude of low-density lipoprotein cholesterol reduction: a comparison of subgroups by age. Circulation.
Rahimi K, Majoni W, Merhi A, et al. (2012). Effect of statins on ventricular tachyarrhythmia, cardiac arrest, and sudden cardiac death: a meta-analysis of published and unpublished evidence from randomized trials. Eur Heart J.
Rahman M, Baimbridge C, Davis BR, et al. (2013). Pravastatin and cardiovascular outcomes stratified by baseline eGFR in the lipid-lowering component of ALLHAT. Clin Nephrol.
Razzolini R, Tarantini G, Ossena G, et al. (2008). Non-cardiovascular mortality, low-density lipoprotein cholesterol and statins: a meta-regression analysis. Cardiology.
Ridker PM, Danielson E, Fonseca FA, et al. (2008). Rosuvastatin to prevent vascular events in men and women with elevated C-reactive protein. N Engl J Med.
Robins SJ, Collins D, Nelson JJ, et al. (2008). Cardiovascular events with increased lipoprotein-associated phospholipase A(2) and low high-density lipoprotein-cholesterol: the Veterans Affairs HDL Intervention Trial. Arterioscler Thromb Vasc Biol.
Rodondi N, Auer R, de Bosset Sulzer V, et al. (2012). Atherosclerosis screening by noninvasive imaging for cardiovascular prevention: a systematic review. J Gen Intern Med.
Saito Y, Yokoyama M, Origasa H, et al. (2008). Effects of EPA on coronary artery disease in hypercholesterolemic patients with multiple risk factors: sub-analysis of primary prevention cases from the Japan EPA Lipid Intervention Study (JELIS). Atherosclerosis.
Scott R, O'Brien R, Fulcher G, et al. (2009). Effects of fenofibrate treatment on cardiovascular disease risk in 9,795 individuals with type 2 diabetes and various components of the metabolic syndrome: the Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study. Diabetes Care.
Sheng X, Murphy MJ, MacDonald TM, et al. (2012). Effect of statins on total cholesterol concentrations and cardiovascular outcomes in patients with diabetes mellitus: a population-based cohort study. Eur J Clin Pharmacol.
Sialvera TE, Pounis GD, Koutelidakis AE, et al. (2012). Phytosterols supplementation decreases plasma small and dense LDL levels in metabolic syndrome patients on a westernized type diet. Nutr Metab Cardiovasc Dis.
Silva H, Hernandez-Hernandez R, Vinueza R, et al. (2010). Cardiovascular risk awareness, treatment, and control in urban Latin America. Am J Ther.
Silverberg MJ, Leyden W, Hurley L, et al. (2009). Response to newly prescribed lipid-lowering therapy in patients with and without HIV infection. Ann Intern Med.
Singh RB, Dubnov G, Niaz MA, et al. (2002). Effect of an Indo-Mediterranean diet on progression of coronary artery disease in high risk patients (Indo-Mediterranean Diet Heart Study): a randomised single-blind trial. Lancet.
Sjouke B, Langslet G, Ceska R, et al. (2014). Eprotirome in patients with familial hypercholesterolaemia (the AKKA trial): a randomised, double-blind, placebo-controlled phase 3 study. Lancet Diabetes Endocrinol.
Snehalatha C, Mary S, Joshi VV, et al. (2008). Beneficial effects of strategies for primary prevention of diabetes on cardiovascular risk factors: results of the Indian Diabetes Prevention Programme. Diab Vasc Dis Res.
Sofi F, Whittaker A, Cesari F, et al. (2013). Characterization of Khorasan wheat (Kamut) and impact of a replacement diet on cardiovascular risk factors: cross-over dietary intervention study. Eur J Clin Nutr.
Song S, Lee JE, Song WO, et al. (2014). Carbohydrate intake and refined-grain consumption are associated with metabolic syndrome in the Korean adult population. J Acad Nutr Diet.
Song SH, Gray TA. (2012). Early-onset type 2 diabetes: higher burden of atherogenic apolipoprotein particles during statin treatment. QJM.
Sood A, Arora R. (2010). Vitamin D deficiency and its correlations with increased cardiovascular incidences. Am J Ther.
Soran H, Durrington P. (2008). Rosuvastatin: efficacy, safety and clinical effectiveness. Expert Opin Pharmacother.
Sorensen SV, Frick KD, Wade A, et al. (2009). Model-based simulation to explore the cost-effectiveness of following practice guidelines for triglyceride and low-density lipoprotein cholesterol control among patients with diabetes mellitus and mixed dyslipidemia. Clin Ther.
Soriguer F, Rojo-Martinez G, Goday A, et al. (2013). Olive oil has a beneficial effect on impaired glucose regulation and other cardiometabolic risk factors. Di@bet.es study. Eur J Clin Nutr.
Soveri I, Abedini S, Holdaas H, et al. (2009). Metabolic syndrome and cardiovascular risk in renal transplant recipients: effects of statin treatment. Clin Transplant.
Stefanick ML, Mackey S, Sheehan M, et al. (1998). Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med.
Steg PG, Verdier JC, Carre F, et al. (2008). A randomised trial of three counselling strategies for lifestyle changes in patients with hypercholesterolemia treated with ezetimibe on top of statin therapy (TWICE). Arch Cardiovasc Dis.
Stein EA, Ballantyne CM, Windler E, et al. (2008). Efficacy and tolerability of fluvastatin XL 80 mg alone, ezetimibe alone, and the combination of fluvastatin XL 80 mg with ezetimibe in patients with a history of muscle-related side effects with other statins. Am J Cardiol.
Stein EA, Bays H, O'Brien D, et al. (2011). Lapaquistat acetate: development of a squalene synthase inhibitor for the treatment of hypercholesterolemia. Circulation.
Stein EA, Vidt DG, Shepherd J, et al. (2012). Renal safety of intensive cholesterol-lowering treatment with rosuvastatin: a retrospective analysis of renal adverse events among 40,600 participants in the rosuvastatin clinical development program. Atherosclerosis.
Strippoli GF, Navaneethan SD, Johnson DW, et al. (2008). Effects of statins in patients with chronic kidney disease: meta-analysis and meta-regression of randomised controlled trials. BMJ.
Strony J, Yang B, Hanson ME, et al. (2008). Long-term safety and tolerability of ezetimibe coadministered with simvastatin in hypercholesterolemic patients: a randomized, 12-month double-blind extension study. Curr Med Res Opin.
Sudhop T, Reber M, Tribble D, et al. (2009). Changes in cholesterol absorption and cholesterol synthesis caused by ezetimibe and/or simvastatin in men. J Lipid Res.
Suh HS, Hay JW, Johnson KA, et al. (2012). Comparative effectiveness of statin plus fibrate combination therapy and statin monotherapy in patients with type 2 diabetes: use of propensity-score and instrumental variable methods to adjust for treatment-selection bias. Pharmacoepidemiol Drug Saf.
Sullivan MD, Katon WJ, Lovato LC, et al. (2013). Association of depression with accelerated cognitive decline among patients with type 2 diabetes in the ACCORD-MIND trial. JAMA Psychiatry.
Sutton D, Davey T, Venkatraman G, et al. (2009). Can a functional food exert a cholesterol lowering effect in renal transplant patients?. J Ren Care.
Suzuki T, Oba K, Igari Y, et al. (2012). Effects of bile-acid-binding resin (colestimide) on blood glucose and visceral fat in Japanese patients with type 2 diabetes mellitus and hypercholesterolemia: an open-label, randomized, case-control, crossover study. J Diabetes Complications.
Sviridov D, Hoang A, Ooi E, et al. (2008). Indices of reverse cholesterol transport in subjects with metabolic syndrome after treatment with rosuvastatin. Atherosclerosis.
Szkodzinski J, Romanowski W, Hudzik B, et al. (2009). Effect of HMG-CoA (3-hydroxy-3-methylglutaryl-CoA) reductase inhibitors on the concentration of insulin-like growth factor-1 (IGF-1) in hypercholesterolemic patients. Pharmacol Rep.
Tabuchi M, Kitayama J, Nagawa H. (2008). Hyperglycemia and hypertriglyceridemia may associate with the adenoma-carcinoma transition in colorectal epithelial cells. J Gastroenterol Hepatol.
Tahaineh L, Albsoul-Younes A, Al-Ashqar E, et al. (2011). The role of clinical pharmacist on lipid control in dyslipidemic patients in North of Jordan. Int J Clin Pharm.
Takagi H, Umemoto T. (2012). Atorvastatin decreases lipoprotein(a): a meta-analysis of randomized trials. Int J Cardiol.
Takahashi O, Glasziou PP, Perera R, et al. (2010). Lipid re-screening: what is the best measure and interval?. Heart.
Takeshita M, Katsuragi Y, Kusuhara M, et al. (2008). Phytosterols dissolved in diacylglycerol oil reinforce the cholesterol-lowering effect of low-dose pravastatin treatment. Nutr Metab Cardiovasc Dis.
Talati R, Sobieraj DM, Makanji SS, et al. (2010). The comparative efficacy of plant sterols and stanols on serum lipids: a systematic review and meta-analysis. J Am Diet Assoc.
Talavera JO, Martinez G, Cervantes JL, et al. (2013). A double-blind, double-dummy, randomized, placebo-controlled trial to evaluate the effect of statin therapy on triglyceride levels in Mexican hypertriglyceridemic patients. Curr Med Res Opin.
Talirevic E, Jelena S. (2012). Quercetin in the treatment of dyslipidemia. Med Arh.
Tanumihardjo SA, Valentine AR, Zhang Z, et al. (2009). Strategies to increase vegetable or reduce energy and fat intake induce weight loss in adults. Exp Biol Med (Maywood).
Tapsell L, Batterham M, Huang XF, et al. (2010). Short term effects of energy restriction and dietary fat sub-type on weight loss and disease risk factors. Nutr Metab Cardiovasc Dis.
Taskinen MR, Barter PJ, Ehnholm C, et al. (2010). Ability of traditional lipid ratios and apolipoprotein ratios to predict cardiovascular risk in people with type 2 diabetes. Diabetologia.
Taskinen MR, Sullivan DR, Ehnholm C, et al. (2009). Relationships of HDL cholesterol, ApoA-I, and ApoA-II with homocysteine and creatinine in patients with type 2 diabetes treated with fenofibrate. Arterioscler Thromb Vasc Biol.
Tatsuno I, Saito Y, Kudou K, et al. (2013). Efficacy and safety of TAK-085 compared with eicosapentaenoic acid in Japanese subjects with hypertriglyceridemia undergoing lifestyle modification: the Omega-3 Fatty Acids Randomized Double-Blind (ORD) study. J Clin Lipidol.
Taylor F, Huffman MD, Macedo AF, et al. (2013). Statins for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev.
Taylor F, Ward K, Moore TH, et al. (2011). Statins for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev.
Taylor JR, Dietrich E, Powell JG. (2013). New and emerging pharmacologic therapies for type 2 diabetes, dyslipidemia, and obesity. Clin Ther.
Tehrani S, Mobarrez F, Antovic A, et al. (2010). Atorvastatin has antithrombotic effects in patients with type 1 diabetes and dyslipidemia. Thromb Res.
Tekin A, Tekin G, Sezgin AT, et al. (2008). Short- and long-term effect of simvastatin therapy on the heterogeneity of cardiac repolarization in diabetic patients. Pharmacol Res.
Teng KT, Voon PT, Cheng HM, et al. (2010). Effects of partially hydrogenated, semi-saturated, and high oleate vegetable oils on inflammatory markers and lipids. Lipids.
Teramoto T. (2012). The clinical impact of pitavastatin: comparative studies with other statins on LDL-C and HDL-C. Expert Opin Pharmacother.
Teramoto T, Kitagawa Y, Daida H, et al. (2011). APPROACH-J study: design, rationale, and baseline data of the affirmation primary prevention with pravastatin in reduction of occlusive atherosclerotic complications in hypercholesterolemia--Japan study. J Atheroscler Thromb.
Teramoto T, Shirai K, Daida H, et al. (2012). Effects of bezafibrate on lipid and glucose metabolism in dyslipidemic patients with diabetes: the J-BENEFIT study. Cardiovascular Diabetology.
Teramoto T, Shirakawa M, Kikuchi M, et al. (2013). Efficacy and safety of the cholesteryl ester transfer protein inhibitor anacetrapib in Japanese patients with dyslipidemia. Atherosclerosis.
Tey SL, Brown RC, Chisholm AW, et al. (2011). Effects of different forms of hazelnuts on blood lipids and alpha-tocopherol concentrations in mildly hypercholesterolemic individuals. Eur J Clin Nutr.
Thakkar RB, Kashyap ML, Lewin AJ, et al. (2009). Acetylsalicylic acid reduces niacin extended-release-induced flushing in patients with dyslipidemia. Am J Cardiovasc Drugs.
Thakur G, Mitra A, Pal K, et al. (2009). Effect of flaxseed gum on reduction of blood glucose and cholesterol in type 2 diabetic patients. Int J Food Sci Nutr.
Theytaz F, Noguchi Y, Egli L, et al. (2012). Effects of supplementation with essential amino acids on intrahepatic lipid concentrations during fructose overfeeding in humans. Am J Clin Nutr.
Thomas GS, Cromwell WC, Ali S, et al. (2013). Mipomersen, an apolipoprotein B synthesis inhibitor, reduces atherogenic lipoproteins in patients with severe hypercholesterolemia at high cardiovascular risk: a randomized, double-blind, placebo-controlled trial. J Am Coll Cardiol.
Thongtang N, Ai M, Otokozawa S, et al. (2011). Effects of maximal atorvastatin and rosuvastatin treatment on markers of glucose homeostasis and inflammation. Am J Cardiol.
Tiessen AH, Smit AJ, Broer J, et al. (2013). Which patient and treatment factors are related to successful cardiovascular risk score reduction in general practice? Results from a randomized controlled trial. BMC Fam Pract.
Tomasik T, Jozwiak J, Windak A, et al. (2011). Prevention of coronary heart disease in primary medical care in Poland: results from the LIPIDOGRAM study. Eur J Cardiovasc Prev Rehabil.
Tonkin AM, Chen L. (2010). Effects of combination lipid therapy in the management of patients with type 2 diabetes mellitus in the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial. Circulation.
Toth PP, Potter D, Ming EE. (2012). Prevalence of lipid abnormalities in the United States: the National Health and Nutrition Examination Survey 2003-2006. J Clin Lipidol.
Turfaner N, Uzun H, Balci H, et al. (2010). Ezetimibe therapy and its influence on oxidative stress and fibrinolytic activity. South Med J.
Tyerman PF, Tyerman GV. (2002). Another way of screening for familial hypercholesterolaemia. BMJ.
Umans-Eckenhausen MA, Defesche JC, Sijbrands EJ, et al. (2001). Review of first 5 years of screening for familial hypercholesterolaemia in the Netherlands. Lancet.
Ur E, Langer A, Rabkin SW, et al. (2010). Achieving cholesterol targets by individualizing starting doses of statin according to baseline low-density lipoprotein cholesterol and coronary artery disease risk category: the CANadians Achieve Cholesterol Targets Fast with Atorvastatin Stratified Titration (CanACTFAST) study. C Journal Cardiol.
Valente AM, Newburger JW, Lauer RM. (2001). Hyperlipidemia in children and adolescents. Am Heart J.
van de Woestijne AP, van der Graaf Y, Liem AH, et al. (2013). Low high-density lipoprotein cholesterol is not a risk factor for recurrent vascular events in patients with vascular disease on intensive lipid-lowering medication. J Am Coll Cardiol.
van Duijnhoven FJ, Bueno-De-Mesquita HB, Calligaro M, et al. (2011). Blood lipid and lipoprotein concentrations and colorectal cancer risk in the European Prospective Investigation into Cancer and Nutrition. Gut.
Van Gaal L, Pi-Sunyer X, Despres JP, et al. (2008). Efficacy and safety of rimonabant for improvement of multiple cardiometabolic risk factors in overweight/obese patients: pooled 1-year data from the Rimonabant in Obesity (RIO) program. Diabetes Care.
van Wyk JT, van Wijk MA, Sturkenboom MC, et al. (2008). Electronic alerts versus on-demand decision support to improve dyslipidemia treatment: a cluster randomized controlled trial. Circulation.
van Zuilen AD, Bots ML, Dulger A, et al. (2012). Multifactorial intervention with nurse practitioners does not change cardiovascular outcomes in patients with chronic kidney disease. Kidney Int.
Versmissen J, Oosterveer DM, Yazdanpanah M, et al. (2008). Efficacy of statins in familial hypercholesterolaemia: a long term cohort study. BMJ.
Versmissen J, Oosterveer DM, Yazdanpanah M, et al. (2011). A frequent variant in the ABCA1 gene is associated with increased coronary heart disease risk and a better response to statin treatment in familial hypercholesterolemia patients. Eur Heart J.
Vimalananda VG, Miller DR, Palnati M, et al. (2011). Gender disparities in lipid-lowering therapy among veterans with diabetes. Women Health Iss.
Visser ME, Wagener G, Baker BF, et al. (2012). Mipomersen, an apolipoprotein B synthesis inhibitor, lowers low-density lipoprotein cholesterol in high-risk statin-intolerant patients: a randomized, double-blind, placebo-controlled trial. Eur Heart J.
Vladimirova-Kitova LG, Deneva TI, Nikolov FP. (2011). Effect of moderate and high dose simvastatin on adhesion molecules in severe hypercholesterolemia after targeting the LDL-cholesterol--a randomised, placebo-controlled study. Folia Med (Plovdiv).
Vlassara H, Uribarri J, Cai W, et al. (2012). Effects of sevelamer on HbA1c, inflammation, and advanced glycation end products in diabetic kidney disease. Clin J Am Soc Nephrol.
Vuksan V, Jenkins AL, Rogovik AL, et al. (2011). Viscosity rather than quantity of dietary fibre predicts cholesterol-lowering effect in healthy individuals. Br J Nutr.
Wallach-Kildemoes H, Diderichsen F, Krasnik A, et al. (2012). Is the high-risk strategy to prevent cardiovascular disease equitable? A pharmacoepidemiological cohort study. BMC Public Health.
Walsh JA, Ilkhanoff L, Soliman EZ, et al. (2013). Natural history of the early repolarization pattern in a biracial cohort: CARDIA (Coronary Artery Risk Development in Young Adults) study. J Am Coll Cardiol.
Wang CJ, Li YQ, Wang L, et al. (2012). Development and evaluation of a simple and effective prediction approach for identifying those at high risk of dyslipidemia in rural adult residents. PLoS ONE.
Wang JS, Carson EC, Lapane KL, et al. (1999). The effect of physician office visits on CHD risk factor modification as part of a worksite cholesterol screening program. Prev Med.
Wang W, Ma L, Zhang Y, et al. (2011). The combination of amlodipine and angiotensin receptor blocker or diuretics in high-risk hypertensive patients: rationale, design and baseline characteristics. J Hum Hypertens.
Wani TA, Samad A, Tandon M, et al. (2010). The effects of rosuvastatin on the serum cortisol, serum lipid, and serum mevalonic acid levels in the healthy Indian male population. AAPS PharmSciTech.
Webber LS, Srinivasan SR, Wattigney WA, et al. (1991). Tracking of serum lipids and lipoproteins from childhood to adulthood. The Bogalusa Heart Study. Am J Epidemiol.
West AM, Anderson JD, Meyer CH, et al. (2011). The effect of ezetimibe on peripheral arterial atherosclerosis depends upon statin use at baseline. Atherosclerosis.
Westerink J, Deanfield JE, Imholz BP, et al. (2013). High-dose statin monotherapy versus low-dose statin/ezetimibe combination on fasting and postprandial lipids and endothelial function in obese patients with the metabolic syndrome: the PANACEA study. Atherosclerosis.
Wierzbicki AS, Pendleton S, McMahon Z, et al. (2011). Rimonabant improves cholesterol, insulin resistance and markers of non-alcoholic fatty liver in morbidly obese patients: a retrospective cohort study. Int J Clin Pract.
Wiesbauer F, Heinze G, Mitterbauer C, et al. (2008). Statin use is associated with prolonged survival of renal transplant recipients. J Am Soc Nephrol.
Williams B, Lacy PS, Cruickshank JK, et al. (2009). Impact of statin therapy on central aortic pressures and hemodynamics: principal results of the Conduit Artery Function Evaluation-Lipid-Lowering Arm (CAFE-LLA) study. Circulation.
Winters P, Tancredi D, Fiscella K. (2010). The role of usual source of care in cholesterol treatment. J Am Board Fam Med.
Wong ND, Chuang J, Wong K, et al. (2013). Residual dyslipidemia among United States adults treated with lipid modifying therapy (data from National Health and Nutrition Examination Survey 2009-2010). Am J Cardiol.
Wood DA, Kotseva K, Connolly S, et al. (2008). Nurse-coordinated multidisciplinary, family-based cardiovascular disease prevention programme (EUROACTION) for patients with coronary heart disease and asymptomatic individuals at high risk of cardiovascular disease: a paired, cluster-randomised controlled trial. Lancet.
Woods MN, Wanke CA, Ling PR, et al. (2009). Effect of a dietary intervention and n-3 fatty acid supplementation on measures of serum lipid and insulin sensitivity in persons with HIV. Am J Clin Nutr.
Wright WL. (2009). The management of type 2 diabetes mellitus: a novel approach for addressing glycemic and lipid control with colesevelam HCl. Adv Nurse Pract.
Wu H, Pan A, Yu Z, et al. (2010). Lifestyle counseling and supplementation with flaxseed or walnuts influence the management of metabolic syndrome. J Nutr.
Yokote K, Shimano H, Urashima M, et al. (2011). Efficacy and safety of pitavastatin in Japanese patients with hypercholesterolemia: LIVES study and subanalysis. Expert Rev Cardiovasc Ther.
Zamorano J, Erdine S, Lopez AP, et al. (2010). Design and rationale of a real-life study to compare treatment strategies for cardiovascular risk factors: the CRUCIAL study. Postgrad Med.
Zamorano J, Erdine S, Pavia A, et al. (2011). Proactive multiple cardiovascular risk factor management compared with usual care in patients with hypertension and additional risk factors: the CRUCIAL trial. Curr Med Res Opin.
Zhang B, Miura SI, Yanagi D, et al. (2008). Reduction of charge-modified LDL by statin therapy in patients with CHD or CHD risk factors and elevated LDL-C levels: the SPECIAL Study. Atherosclerosis.
Zhao XQ, Krasuski RA, Baer J, et al. (2009). Effects of combination lipid therapy on coronary stenosis progression and clinical cardiovascular events in coronary disease patients with metabolic syndrome: a combined analysis of the Familial Atherosclerosis Treatment Study (FATS), the HDL-Atherosclerosis Treatment Study (HATS), and the Armed Forces Regression Study (AFREGS). Am J Cardiol.
Zheng J, Huang T, Yu Y, et al. (2012). Fish consumption and CHD mortality: an updated meta-analysis of seventeen cohort studies. Public Health Nutr.
Zhu FS, Liu S, Chen XM, et al. (2008). Effects of n-3 polyunsaturated fatty acids from seal oils on nonalcoholic fatty liver disease associated with hyperlipidemia. World J Gastroenterol.
Zoppini G, Targher G, Chonchol M, et al. (2009). Higher HDL cholesterol levels are associated with a lower incidence of chronic kidney disease in patients with type 2 diabetes. Nutr Metab Cardiovasc Dis.

## Appendix A5 U.S. Preventive Services Quality Rating Criteria

### Criteria for Assessing Internal Validity of Individual Studies

The Methods Work Group for the US Preventive Services Task Force (USPSTF) developed a set of criteria by which the internal validity of individual studies could be evaluated. The USPSTF accepted the criteria, and the associated definitions of quality categories, that relate to internal validity at its September 1999 meeting.

This appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments.

All topic teams use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for primary care practice may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

Presented below are a set of minimal criteria for each study design and then a general definition of three categories: “good,” “fair,” and “poor,” based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general, a “good” study is one that meets all criteria well. A “fair” study is one that does not meet (or it is not clear that it meets) at least one criterion but has no known “fatal flaw.” “Poor” studies have at least one fatal flaw.

### Systematic Reviews

#### Criteria

- Comprehensiveness of sources considered/search strategy used.
- Standard appraisal of included studies.
- Validity of conclusions.
- Recency and relevance are especially important for systematic reviews.

#### Definition of ratings from above criteria

Good: | Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.
Fair: | Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.
Poor: | Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  ○ For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Important differential loss to follow-up or overall high loss to follow-up.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment).
- Clear definition of interventions.
- All important outcomes considered.
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.
Poor: | Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

### Case-Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both.
- Response rate.
- Diagnostic testing procedures applied equally to each group.
- Measurement of exposure accurate and applied equally to each group.
- Appropriate attention to potential confounding variables.

#### Definition of ratings based on criteria above

Good: | Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.
Fair: | Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.
Poor: | Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

Source: U.S. Preventive Services Task Force. Procedure Manual. .

## Appendix A6 Reviewers of the Draft Report

- Conrad B. Blum, MD
  Professor of Medicine, Columbia University Medical Center
- Scott Grundy, MD, PhD
  Professor of Internal Medicine, University of Texas Southwestern Medical Center; Veteran's Administration Medical Center
- Rita Redberg, MD, MSc
  Professor of Medicine, Director of Women's Cardiovascular Services, University of California, San Francisco
- Neil J. Stone, MD
  Professor of Medicine, Feinberg School of Medicine, Northwestern University