# References

1 U. S. Preventive Services Task Force. Screening for skin cancer: recommendations and rationale. Am J Prev Med. 2001;20(3 Suppl):44-6. [pmid: 11306231].
2 Thomas VD, Aasi SZ, Wilson LD, et al. Cancer of the skin. DeVita VT, Lawrence TS, Rosenberg SA, DePinho RA, Weinberg RA, editors. DeVita, Hellman and Rosenberg's Cancer: Principles and Practice of Oncology. 8th ed. Philadelphia. Wolters Kluwer Health/Lippincott Williams & Wilkins. 2008:1863-87.
3 Howlader N, Noone AM, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2011. Bethesda, MD. National Cancer Institute. 2015. April. 1. http://seer.cancer.gov/csr/1975_2011/.
4 Perera E, Sinclair R. An estimation of the prevalence of nonmelanoma skin cancer in the U.S. F1000Research. 2013;2:107. [pmid: 24358841].
5 Harris RB, Griffith K, Moon TE. Trends in the incidence of nonmelanoma skin cancers in southeastern Arizona, 1985-1996. J Am Acad Dermatol. 2001;45(4):528-36. [pmid: 11568742].
6 Karagas MR, Greenberg ER, Spencer SK, et al. Increase in incidence rates of basal cell and squamous cell skin cancer in New Hampshire, USA. New Hampshire Skin Cancer Study Group. Int J Cancer. 1999;81(4):555-9. [pmid: 10225444].
7 Eisemann N, Waldmann A, Geller AC, et al. Non-melanoma skin cancer incidence and impact of skin cancer screening on incidence. J Invest Dermatol. 2014;134(1):43-50. [pmid: 23877569].
8 Rogers HW, Weinstock MA, Harris AR, et al. Incidence estimate of nonmelanoma skin cancer in the United States, 2006. Arch Dermatol. 2010;146(3):283-7. [pmid: 20231499].
9 Christenson LJ, Borrowman TA, Vachon CM, et al. Incidence of basal cell and squamous cell carcinomas in a population younger than 40 years. JAMA. 2005;294(6):681-90. [pmid: 16091570].
10 Karagas MR, Weinstock MA, Nelson HH. Keratinocyte Carcinomas (Basal and Squamous Cell Carcinomas of the Skin). Schottenfeld D, Fraumeni JF, editors. Cancer Epidemiology and Prevention. Third Edition. Oxford. Oxford University Press. 2006:1230-50.
11 Lewis KG, Weinstock MA. Nonmelanoma skin cancer mortality (1988-2000): the Rhode Island follow-back study. Arch Dermatol. 2004;140(7):837-42. [pmid: 15262694].
12 Corona R. Epidemiology of nonmelanoma skin cancer: a review. Ann Ist Super Sanita. 1996;32(1):37-42. [pmid: 8804184].
13 Siegel RL, Miller KD, Jemal A. Cancer statistics, 2015. CA Cancer J Clin. 2015;65(1):5-29. [pmid: 25559415].
14 Welch HG, Woloshin S, Schwartz LM. Skin biopsy rates and incidence of melanoma: population based ecological study. BMJ. 2005;331(7515):481. [pmid: 16081427].
15 Rigel DS, Russak J, Friedman R. The evolution of melanoma diagnosis: 25 years beyond the ABCDs. CA Cancer J Clin. 2010;60(5):301-16. [pmid: 20671054].
16 de Gruijl FR, van Kranen HJ, Mullenders LH. UV-induced DNA damage, repair, mutations and oncogenic pathways in skin cancer. J Photochem Photobiol B. 2001;63(1-3):19-27. [pmid: 11684448].
17 Gruber SB, Armstrong BK. Cutaneous and Ocular Melanoma. Schottenfeld D, Fraumeni JF, editors. Cancer Epidemiology and Prevention. Third Edition. Oxford. Oxford University Press. 2006:1196-229.
18 Slingluff CL Jr, Flaherty KT, Rosenberg SA, et al. Melanoma Section 2 Cutaneous Melanoma. deVita VT, Lawrence TS, Rosenberg SA, dePinho RA, Weinberg RA, editors. DeVita, Hellman, and Rosenberg's Cancer: Priniciples and Practice of Oncology. 8th ed. Philadelphia. Wolters, Kluwer Health/Lippencourt Williams & Wilkins. 2008:1897-951.
19 Gandini S, Sera F, Cattaruzza MS, et al. Meta-analysis of risk factors for cutaneous melanoma: I. Common and atypical naevi. Eur J Cancer. 2005;41(1):28-44. [pmid: 15617989].
20 Gandini S, Sera F, Cattaruzza MS, et al. Meta-analysis of risk factors for cutaneous melanoma: II. Sun exposure. Eur J Cancer. 2005;41(1):45-60. [pmid: 15617990].
21 Gandini S, Sera F, Cattaruzza MS, et al. Meta-analysis of risk factors for cutaneous melanoma: III. Family history, actinic damage and phenotypic factors. Eur J Cancer. 2005;41(14):2040-59. [pmid: 16125929].
22 Colantonio S, Bracken MB, Beecker J. The association of indoor tanning and melanoma in adults: systematic review and meta-analysis. J Am Acad Dermatol. 2014;70(5):847-57 e1-18. [pmid: 24629998].
23 International Agency for Research on Cancer Working Group on artificial ultraviolet light and skin cancer. The association of use of sunbeds with cutaneous malignant melanoma and other skin cancers: A systematic review. Int J Cancer. 2007;120(5):1116-22. [pmid: 17131335].
24 Veierod MB, Couto E, Lund E, et al. Host characteristics, sun exposure, indoor tanning and risk of squamous cell carcinoma of the skin. Int J Cancer. 2013. [pmid: 24408678].
25 Khalesi M, Whiteman DC, Tran B, et al. A meta-analysis of pigmentary characteristics, sun sensitivity, freckling and melanocytic nevi and risk of basal cell carcinoma of the skin. Cancer Epidemiol. 2013;37(5):534-43. [pmid: 23849507].
26 Olsen CM, Carroll HJ, Whiteman DC. Estimating the attributable fraction for melanoma: a meta-analysis of pigmentary characteristics and freckling. Int J Cancer. 2010;127(10):2430-45. [pmid: 20143394].
27 van Dam RM, Huang Z, Rimm EB, et al. Risk factors for basal cell carcinoma of the skin in men: results from the health professionals follow-up study. Am J Epidemiol. 1999;150(5):459-68. [pmid: 10472945].
28 Zhang M, Qureshi AA, Geller AC, et al. Use of tanning beds and incidence of skin cancer. J Clin Oncol. 2012;30(14):1588-93. [pmid: 22370316].
29 Abbasi NR, Shaw HM, Rigel DS, et al. Early diagnosis of cutaneous melanoma: revisiting the ABCD criteria. JAMA. 2004;292(22):2771-6. [pmid: 15585738].
30 Grob JJ, Bonerandi JJ. The ‘ugly duckling’ sign: identification of the common characteristics of nevi in an individual as a basis for melanoma screening. Arch Dermatol. 1998;134(1):103-4. [pmid: 9449921].
31 Rat C, Quereux G, Riviere C, et al. Targeted melanoma prevention intervention: a cluster randomized controlled trial. Ann Fam Med. 2014;12(1):21-8. [pmid: 24445100].
32 Norman GJ, Adams MA, Calfas KJ, et al. A randomized trial of a multicomponent intervention for adolescent sun protection behaviors. Arch Pediatr Adolesc Med. 2007;161(2):146-52. [pmid: 17283299].
33 Pan M, Geller L. Update on indoor tanning legislation in the United States. Clin Dermatol. 2015;33(3):387-92. [pmid: 25889141].
34 Oliveria SA, Heneghan MK, Cushman LF, et al. Skin cancer screening by dermatologists, family practitioners, and internists: barriers and facilitating factors. Arch Dermatol. 2011;147(1):39-44. [pmid: 21242390].
35 Kimball AB, Resneck JS Jr. The US dermatology workforce: a specialty remains in shortage. J Am Acad Dermatol. 2008;59(5):741-5. [pmid: 18723242].
36 Wise E, Singh D, Moore M, et al. Rates of skin cancer screening and prevention counseling by US medical residents. Arch Dermatol. 2009;145(10):1131-6. [pmid: 19841400].
37 Kirsner RS, Muhkerjee S, Federman DG. Skin cancer screening in primary care: prevalence and barriers. J Am Acad Dermatol. 1999;41(4):564-6. [pmid: 10495376].
38 Goulart JM, Quigley EA, Dusza S, et al. Skin cancer education for primary care physicians: a systematic review of published evaluated interventions. J Gen Intern Med. 2011;26(9):1027-35. [pmid: 21472502].
39 American Academy of Family Physicians (AAFP). Skin Cancer. Clinical Preventive Service Recommendation. Leawood, KS. American Academy of Family Physicians (AAFP). 2015. May. 15. http://www.aafp.org/patient-care/clinical-recommendations/all/skin-cancer.html.
40 American College of Preventive Medicine. ACPM Position Statements. Washington DC. American College of Preventive Medicine. 2015. May. 15. http://www.acpm.org/?page=Policy_Statements.
41 American Academy of Dermatology. Clinical Guidelines. Schaumburg, IL. American Academy of Dermatology. 2015. May. 15. https://www.aad.org/education/clinical-guidelines.
42 American College of Physicians. Guidelines: ACP Clinical Recommendations. Philadelphia. American College of Physicians. 2015. May. 22. http://www.acponline.org/clinical_information/guidelines/.
43 U. S. Preventive Services Task Force. Screening for skin cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;150(3):188-93. [pmid: 19189908].
44 American Cancer Society. American Cancer Society Guidelines for the Early Detection of Cancer. Atlanta, GA. American Cancer Society. 2015. May. 15. http://www.cancer.org/healthy/findcancerearly/cancerscreeningguidelines/american-cancer-society-guidelines-for-the-early-detection-of-cancer.
45 Guide to Community Preventive Services. Preventing skin cancer: interventions in outdoor recreational and tourism settings. Washington, DC. Department of Health and Human Services. 2015. Septebmer. 17. http://www.thecommunityguide.org/cancer/skin/education-policy/outdoorrecreation.html.
46 American Academy of Dermatology. SPOTme. Schaumburg, IL. American Academy of Dermatology. 2015. May. 22. https://www.aad.org/spot-skin-cancer/community-programs-events/spotme-skin-cancer-screenings.
47 Wolff T, Tai E, Miller T. Screening for skin cancer: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;150(3):194-8. [pmid: 19189909].
48 United Nations Development Programme. Human Development Reports: Data. Human Development Reports: United Nations. 2015. May. 22. http://hdr.undp.org/en/data.
49 Byrd D, Compton CC, Fritz AG, et al. AJCC cancer staging manual (Vol 649). New York. Springer. 2010.
50 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication Number 08-05118-EF. Rockville, MD. U.S. Preventive Services Task Force. 2008.
51 Dufault B, Klar N. The quality of modern cross-sectional ecologic studies: a bibliometric review. Am J Epidemiol. 2011;174(10):1101-7. [pmid: 21940800].
52 Tu JV, Ko DT. Ecological studies and cardiovascular outcomes research. Circulation. 2008;118(24):2588-93. [pmid: 19064693].
53 Katalinic A, Waldmann A, Weinstock MA, et al. Does skin cancer screening save lives?: an observational study comparing trends in melanoma mortality in regions with and without screening. Cancer. 2012;118(21):5395-402. [pmid: 22517033].
54 Waldmann A, Nolte S, Weinstock MA, et al. Skin cancer screening participation and impact on melanoma incidence in Germany--an observational study on incidence trends in regions with and without population-based screening. Br J Cancer. 2012;106(5):970-4. [pmid: 22294187].
55 Breitbart EW, Waldmann A, Nolte S, et al. Systematic skin cancer screening in Northern Germany. J Am Acad Dermatol. 2012;66(2):201-11. [pmid: 22074699].
56 Aitken JF, Janda M, Elwood M, et al. Clinical outcomes from skin screening clinics within a community-based melanoma screening program. J Am Acad Dermatol. 2006;54(1):105-14. [pmid: 16384764].
57 Fritschi L, Dye SA, Katris P. Validity of melanoma diagnosis in a community-based screening program. Am J Epidemiol. 2006;164(4):385-90. [pmid: 16760225].
58 Waldmann A, Nolte S, Geller AC, et al. Frequency of excisions and yields of malignant skin tumors in a population-based screening intervention of 360,288 whole-body examinations. Arch Dermatol. 2012;148(8):903-10. [pmid: 22911184].
59 Gambichler T, Senger E, Rapp S, et al. Deep shave excision of macular melanocytic nevi with the razor blade biopsy technique. Dermatol Surg. 2000;26(7):662-6. [pmid: 10886275].
60 Rampen RH. Point-counterpoint. Mass population skin cancer screening is not worthwhile. J Cutan Med Surg. 1998;2(3):128-9. [pmid: 9556369].
61 Aitken JF, Elwood M, Baade PD, et al. Clinical whole-body skin examination reduces the incidence of thick melanomas. Int J Cancer. 2010;126(2):450-8. [pmid: 19609948].
62 Aitken JF, Youl PH, Janda M, et al. Validity of self-reported skin screening histories. Am J Epidemiol. 2004;159(11):1098-105. [pmid: 15155295].
63 Reyes-Ortiz CA, Goodwin JS, Freeman JL, et al. Socioeconomic status and survival in older patients with melanoma. J Am Geriatr Soc. 2006;54(11):1758-64. [pmid: 17087705].
64 Zell JA, Cinar P, Mobasher M, et al. Survival for patients with invasive cutaneous melanoma among ethnic groups: the effects of socioeconomic status and treatment. J Clin Oncol. 2008;26(1):66-75. [pmid: 18165642].
65 Pollack LA, Li J, Berkowitz Z, et al. Melanoma survival in the United States, 1992 to 2005. J Am Acad Dermatol. 2011;65(5 Suppl 1):S78-86. [pmid: 22018071].
66 Owen SA, Sanders LL, Edwards LJ, et al. Identification of higher risk thin melanomas should be based on Breslow depth not Clark level IV. Cancer. 2001;91(5):983-91. [pmid: 11251950].
67 Luke CG, Coventry BJ, Foster-Smith EJ, et al. A critical analysis of reasons for improved survival from invasive cutaneous melanoma. Cancer Causes Control. 2003;14(9):871-8. [pmid: 14682444].
68 Marashi-Pour S, Morrell S, Cooke-Yarborough C, et al. Competing risk analysis of mortality from invasive cutaneous melanoma in New South Wales: a population-based study, 1988-2007. Aust N Z J Public Health. 2012;36(5):441-5. [pmid: 23025365].
69 Green AC, Baade P, Coory M, et al. Population-based 20-year survival among people diagnosed with thin melanomas in Queensland, Australia. J Clin Oncol. 2012;30(13):1462-7. [pmid: 22412152].
70 Leiter U, Buettner PG, Eigentler TK, et al. Prognostic factors of thin cutaneous melanoma: an analysis of the central malignant melanoma registry of the german dermatological society. J Clin Oncol. 2004;22(18):3660-7. [pmid: 15302905].
71 Aitken JF, Elwood JM, Lowe JB, et al. A randomised trial of population screening for melanoma. J Med Screen. 2002;9(1):33-7. [pmid: 11943795].
72 Boniol M, Autier P, Gandini S. Melanoma mortality following skin cancer screening in Germany. BMJ Open. 2015;5(9):e008158. [pmid: 26373399].
73 Aitken J, Epidemiology Unit, Queensland Cancer Fund, et al. Personal email to: Wernli KJ, (Group Health Research Institute, Seattle WA). 2015.
74 Youl PH, Baade PD, Janda M, et al. Diagnosing skin cancer in primary care: how do mainstream general practitioners compare with primary care skin cancer clinic doctors?. Med J Aust. 2007;187(4):215-20. [pmid: 17708723].
75 Stell VH, Norton HJ, Smith KS, et al. Method of biopsy and incidence of positive margins in primary melanoma. Ann Surg Oncol. 2007;14(2):893-8. [pmid: 17119869].
76 Welch HG, Black WC. Overdiagnosis in cancer. J Natl Cancer Inst. 2010;102(9):605-13. [pmid: 20413742].
77 Linos E, Schroeder SA, Chren MM. Potential overdiagnosis of basal cell carcinoma in older patients with limited life expectancy. JAMA. 2014;312(10):997-8. [pmid: 25203077].
78 Harlan LC, Lynch CF, Ballard-Barbash R, et al. Trends in the treatment and survival for local and regional cutaneous melanoma in a US population-based study. Melanoma Res. 2011;21(6):547-54. [pmid: 21897302].
79 Wong SL, Balch CM, Hurley P, et al. Sentinel lymph node biopsy for melanoma: American Society of Clinical Oncology and Society of Surgical Oncology joint clinical practice guideline. J Clin Oncol. 2012;30(23):2912-8. [pmid: 22778321].
80 Wong SL, Balch CM, Hurley P, et al. Sentinel lymph node biopsy for melanoma: American Society of Clinical Oncology and Society of Surgical Oncology joint clinical practice guideline. Ann Surg Oncol. 2012;19(11):3313-24. [pmid: 22766987].
81 American Academy of Dermatology, American College of Mohs Surgery, American Society for Dermatologic Surgery Association, et al. AAD/ACMS/ASDSA/ASMS 2012 appropriate use criteria for Mohs micrographic surgery: a report of the American Academy of Dermatology, American College of Mohs Surgery, American Society for Dermatologic Surgery Association, and the American Society for Mohs Surgery. Dermatol Surg. 2012;38(10):1582-603. [pmid: 22958088].
82 Choosing Wisely. American Academy of Dermatology five things physicians and patients should question. Philadelphia. ABIM Foundation. 2015. March. 30. http://www.choosingwisely.org/doctor-patient-lists/american-academy-of-dermatology/.
83 Fears TR, Guerry Dt, Pfeiffer RM, et al. Identifying individuals at high risk of melanoma: a practical predictor of absolute risk. J Clin Oncol. 2006;24(22):3590-6. [pmid: 16728488].
84 Cho E, Rosner BA, Feskanich D, et al. Risk factors and individual probabilities of melanoma for whites. J Clin Oncol. 2005;23(12):2669-75. [pmid: 15837981].
85 Williams LH, Shors AR, Barlow WE, et al. Identifying persons at highest risk of melanoma using self-assessed risk factors. J Clin Exp Dermatol Res. 2011;2(6). [pii: 1000129]. [pmid: 22229112].
86 Davies JR, Chang YM, Bishop DT, et al. Development and validation of a melanoma risk score based on pooled data from 16 case-control studies. Cancer Epidemiol Biomarkers Prev. 2015;24(5):817-24. [pmid: 25713022].
87 Weiss NS, Koepsell TD. Epidemiologic methods. New York. Oxford. 2014.
88 Community Preventive Services Task Force. Cancer Prevention and Control. Publications about the Community Guide. Washington, DC. US Department of Health and Human Services. 2015. May. 22. http://www.thecommunityguide.org/library/pubstopic.htm#cancer.
89 International Agency for Research on Cancer. GLOBOCAN 2012: Estimated cancer incidence, mortality and prevalence worldwide in 2012. Lyon, France. World Health Organization. 2015. May. 22. http://globocan.iarc.fr/Pages/Map.aspx.
90 Collins MK, Secrest AM, Ferris LK. Screening for melanoma. Melanoma Res. 2014;24(5):428-36. [pmid: 24999755].
91 ClinicalTrials.gov. Skin Cancer Screening Education Study (SCSES). Washington, DC: U.S. National Institutes of Health; 2015 [updated February 24, 2015; cited 2015 May 22]; Available from: https://clinicaltrials.gov/ct2/show/NCT02352428?term=%22skin+cancer%22+AND+screening&rank=1.
92 ClinicalTrials.gov. Training Primary Care Physicians to Perform Melanoma Opportunistic Surveillance. Washington, DC: U.S. National Institutes of Health; 2015 [updated March 5, 2015; cited 2015 May 22]; Available from: https://clinicaltrials.gov/ct2/show/NCT02385253?term=%22skin+cancer%22+AND+screening&rank=2.
93 ClinicalTrials.gov. Predictors of Patient Attitudes and Barriers to Skin Cancer Screening. Washington, DC: U.S. National Institutes of Health; 2014 [updated September 8, 2014; cited 2015 May 22]; Available from: https://clinicaltrials.gov/ct2/show/NCT02235116?term=%22skin+cancer%22+AND+screening&rank=5.
94 ClinicalTrials.gov. Skin Cancer Screening and Education at Beaches (SHADE). Washington, DC: U.S. National Institutes of Health; 2014 [updated December 30, 2014; cited 2015 May 22]; Available from: https://clinicaltrials.gov/ct2/show/NCT00894855?term=%22skin+cancer%22+AND+screening&rank=3.
95 National Institutes of Health. Research Portfolio Online Reporting Tools (NIH RePORTer). Washington, DC: U.S. Department of Health and Human Services; 2015 [updated May 22, 2015; cited 2015 May 22]; Available from: http://projectreporter.nih.gov/reporter.cfm.
96 Eide MJ, Asgari MM, Fletcher SW, et al. Effects on skills and practice from a web-based skin cancer course for primary care providers. Journal of the American Board of Family Medicine : JABFM. 2013;26(6):648-657. [pmid: 24204061].