# Discussion

## Summary of Evidence

We conducted this systematic review to assist the USPSTF in updating its previous skin cancer screening recommendation.47 Thirteen unique studies met our inclusion criteria. The prior review did not explicitly evaluate lesion thickness, harms of screening, or the relationship between mortality outcomes and melanoma thickness or stage at diagnosis.

Table 11 Summary of Evidence

Key Question | Population | No. of Studies (k), No. of Observations (n) | Design | Major Limitations | Consistency | Applicability | Overall Quality | Summary of Findings
KQ 1. What is the direct evidence that visual screening for skin cancer by a primary care provider or dermatologist reduces skin cancer morbidity and mortality and all-cause mortality? | Residents of Schleswig-Holstein Germany age ≥20 years with whole-body skin cancer screening exam between July 2003 and June 2004 | k=1 study (3 articles) n=360,288 | Ecologic (1) | In the main study, an ecologic study design permitted only population-level analysis of mortality rates compared to those in the surrounding areas, not individual-level data. 2 related publications using observational designs described skin cancer incidence after the screening program and participation in the program. The physician screening component was part of a multimodal screening program involving physician education, dermatologist referral for screen-detected lesions, public outreach, and access to physician review of patient-identified suspicious lesions. | N/A (1 study included) | The screening program made considerable efforts to be truly population-based and screen the entire adult population in the study area. However, the screened population (19% of total) had a high proportion of younger women screened, who are at low risk for melanoma. | Fair | In the SCREEN study in Germany, melanoma mortality decreased 48% from 1.7 to 0.9 melanoma deaths per 100,000 persons 5 years after the screening program. Absolute reduction was 0.8 melanoma deaths per 100,000 persons. There were no mortality reductions in the surrounding geographic areas.
KQ 2. What are the harms of screening for skin cancer and diagnostic followup? | Routine skin cancer screening outpatients in Germany | k=2 (3 articles) n=360,333 | Cohort (1), Case series (1) | Data from the SCREEN study presented the false-positive rates and number of excisions needed to detect 1 melanoma during the screening program. Overdiagnosis could not be assessed directly. A small study of 45 people assessed the acceptability of cosmetic scars from shave biopsy for suspected NMSC, which is not the major approach to melanomas. | Low (different harms assessed in each study and 1 per outcome) | The SCREEN data suggest potential for very high number of false-positives that could be relevant to other screening programs. Patient-reported data on cosmetic harms is important. | Fair | The number of excisions needed to detect 1 skin cancer varied by age and sex. Fewer excisions were needed to detect a single case in older adults and in men. After shave biopsy for removal of potential NMSC detected through cancer screening, 7% of patients viewed their scar outcomes poorly at 6 months after biopsy
KQ 3. What are the test characteristics of visual screening for skin cancer when performed by primary care providers versus dermatologists? | Australian residents who either participated in a community- based pilot randomized, clinical trial of skin screening program or attended Lions Cancer Institute weekend mobile screening clinics in rural and suburban locations in Western Australia | k=2 (2 articles) n=23,819 | Cohort (2) | An Australian cohort study assessed performance of dermatologists in a mobile screening program. An unrelated cohort study, also Australian, assessed performance of primary care providers. Missed cancers were detected through registry and medical record linkages, but ascertainment bias is likely due to differential followup time periods. | Low (followup times prohibit direct comparison of studies) | These results may not apply to U.S. settings. | Fair | Sensitivity for melanoma detection was 40.2% at 36 months for primary care providers and 49.0% at 24 months for dermatologists. Specificity was 86.1% at 36 months for primary care providers and 97.6% at 24 months for dermatologists. Recall rate was 14.1% for primary care and 2.7% for dermatologists. Melanoma detection rates were <1% in both studies.
KQ 4. Does visual screening for skin cancer lead to earlier detection of skin cancer compared to usual care? | Queensland residents ages 20 to 75 years; cases identified from cancer registry and controls selected through stratified random sampling from Queensland Electoral Roll | k=1 (1 article) n=7,586 | Case control (1) | 1 Australian case-control study compared receipt of physician whole-body skin exam in the previous 3 years and the association of melanoma thickness (in cases) with physician skin exam. Potential for recall bias. | N/A (1 study included) | The ability of physician skin exam to detect lesions earlier than through usual care or self-identification is important to establishing an effect of physician screening in the context of multimodal skin cancer early detection programs. | Fair | 28.3% of controls reported receiving a clinical skin exam in the previous 3 years compared to 35.3% of melanoma cases. Cases with thin melanoma lesions (≤0.75 mm) had 38% higher odds of clinical skin exam than controls. Cases with thicker lesions (>0.75 mm) had 14% reduced odds of recent physician skin exam compared to controls.
KQ 5. What is the association between earlier detection of skin cancer and skin cancer morbidity and mortality and all-cause mortality? | Cases of melanoma identified through registries in Australia, Germany, and the U.S. | k=8 (8 articles) n= 236,485 | Cohort (8) | 3 good- and 5 fair-quality observational studies included >200,000 persons with melanoma in the U.S., Germany, and Australia. The studies examined the association between melanoma-specific mortality and lesion thickness or stage at diagnosis. 1 of the good- quality studies also assessed all-cause mortality and stage at diagnosis. | High | The association of melanoma or all-cause mortality with earlier stage or lesion thickness at detection is relevant to screening programs. | Good | All studies demonstrated a consistent linear increase in risk of melanoma mortality with increasing tumor thickness or stage. Tumor thickness >4.0 mm was associated with a 3.1- to 32.6-fold increased risk of melanoma mortality compared to thinner lesions in multivariate- adjusted models.

Abbreviations: KQ = key question; N/A = not applicable; SCREEN = Skin Cancer Research to Provide Evidence for Effectiveness of Screening in Northern Germany; NMSC = nonmelanoma skin cancer.

No firm conclusions on skin cancer screening and melanoma mortality can be made from the evidence reviewed. Results from a single population-based ecologic study suggested skin cancer screening may be associated with reductions in population-level melanoma mortality rates, based on pre- versus postintervention comparisons in one German region implementing a 1-year multicomponent skin cancer screening program compared to surrounding regions that did not implement the screening program. However, as an ecologic study, the measures of association were drawn from population-level changes in mortality, not individual-level data, which cannot account for confounding or assess comparisons between exposed and nonexposed participants. While data demonstrating unchanged or increased melanoma mortality in control regions are promising, the ecologic study design limits assessment of causal inference. Further, the large relative mortality reduction translated to an absolute mortality reduction of 0.8 melanoma deaths per 100,000 persons, after screening only 19 percent of the target population. The context of the results must also be considered among the following: 1) the high proportion of younger women screened who were at lower risk of melanoma incidence and mortality compared to older men, suggesting a healthy screenee bias; 2) the high proportion of persons with suspicious findings who did not receive followup by a dermatologist; and 3) the impact of the other components of the screening program, including education in the community, which cannot be differentiated from visual skin cancer screening. Nonetheless, the results and challenges from the SCREEN study likely reflect real-world population-based screening programs when implemented.

We found limited data on harms of visual screening examinations, except for biopsy yields and cosmetic harms. The included evidence suggested that cosmetic results of shave biopsy are acceptable to most adults. Most screen-positive lesions, particularly to detect one malignant melanoma, require additional excisional biopsies as diagnostic workup. When the ratio of excisions required per malignant melanoma identified was evaluated by type of lesion, age, and sex, younger adults (age <35 years) required about twice as many excisions of suspicious lesions than older adults (age >64 years). The pretest probability of melanoma is lower in young adults than in older adults. Although these data do not clearly define overdiagnosis, they demonstrate a potential excess burden of excisions for nonmalignant lesions in younger adults participating in community skin cancer screening programs, where the incidence of NMSC and melanoma is lowest.

We were not able to directly compare screening accuracy between dermatologists and primary care clinicians due to differences in time to ascertainment of cancer outcomes that affect screening examination performance measures. Only one study linked participants to cancer registry data, the gold standard for cancer detection and the only way to assess cancer outcomes in screen-negatives within the population. Relying on biopsy or pathology reports could have underestimated the number of melanomas detected in the population rather than through cancer registry rates, and the estimation of false-negative rates could be an overestimate of the number of cancers missed. Nonetheless, whether visual skin cancer examination can detect skin cancer 24 to 36 months from examination might not be a reasonable time frame. Sensitivity is reduced as the length of followup time to observe cancers is extended. Sensitivity was also affected by the inclusion of both incident melanoma and melanoma in situ in the screening examinations conducted by primary care physicians,56 compared to the inclusion of only invasive melanoma cases as positive findings in dermatology and plastic surgery examinations.57 Not affected by cancer ascertainment followup, recall rates were lower for dermatology providers than primary care physicians, consistent with higher specificity as might be expected for a specialist examination.

Self-report of skin cancer screening within the prior 3 years was associated with reduced risk of thicker melanoma lesions compared to controls with melanoma who did not report skin cancer screening.61 In the case-control study, cases may have recalled receipt of a recent screening examination differentially than controls without a melanoma diagnosis. To minimize potential recall bias, the study ascertained history of skin screening examinations using a well-tested and reliable question documented to have high validity compared to medical record review.62 The study did not further validate self-report with medical record review. While cases might have recalled their screening history differently than controls, differences within cases are unlikely to have aligned according to lesion thickness to produce a spurious trend of decreasing risk with increasing lesion thickness. Data from cohort studies will be important to confirm this finding and its magnitude.

There is consistent evidence that later stage or thicker lesions at melanoma detection is highly related to increased risk of melanoma mortality and may be associated with all-cause mortality.64 It is unlikely that future research in this area will change the overall conclusions of this body of current evidence based on lesion thickness alone.

### Challenges in Demonstrating Benefits of Visual Screening for Skin Cancer

Despite efforts to conduct true population-based screening, the challenges faced by other countries attempting such programs may be instructive for the United States. First, for population-based screening, the high proportion of well women who received skin cancer screening and represent a group at lower risk of melanoma compared to older men suggests that healthy screenee bias should be addressed in future skin cancer screening studies. Second, in studies of diagnostic accuracy, the high proportion of persons with several skin cancer risk factors within the screened population suggests that the participating population might not represent an average-risk population.53, 71 The need to increase the pretest probability of melanoma detection is the likely driver of encouraging skin cancer screening participation, but might not reflect the population observed in primary care settings. Hence, further studies should attempt to address inclusion of study populations representing average-risk persons.

Based on the results of the SCREEN study, the German health care system launched a nationwide skin cancer screening program in 2008. However, a recent evaluation comparing age-adjusted mortality data from before the nationwide screening program in 2008 to 5-year followup data found increases in melanoma mortality rates in men and no change in melanoma mortality rates in women.72 Further, the initial decrease in mortality reported from the SCREEN study in the Schleswig-Holstein region appeared to be transient, and melanoma mortality rates returned to preintervention baseline rates. The only randomized, controlled trial to evaluate skin cancer screening began as a pilot study in Queensland, Australia in the early 2000s, but a full trial following the pilot was not able to be conducted. At the time of this report, there are no anticipated results for mortality outcomes from these pilot data.73

Both studies of diagnostic accuracy were conducted in Australia, where overall general knowledge of skin protection habits and sun safety is high and primary care physicians routinely diagnose and manage skin cancer lesions.74 Physician training in detecting and diagnosing skin cancers in primary care was part of both studies and is likely important for improving performance, whether for screening alone or responding to patient concerns. In a different Australian population presenting for both skin cancer screening and due to concern about a skin lesion, sensitivity was statistically significantly different for melanoma detection between general practitioners with and without skin cancer medicine training (60% vs. 29%; p<0.001).74 Specificity was similar for both provider types; however, due to low sensitivity, general practitioners without specific skin cancer training also had lower positive predictive values than those with specialized skin cancer training (18% vs. 25%). Currently, U.S.-based primary care physicians are not confident in their skills to conduct skin cancer screening,36 and could require additional training to achieve skin cancer screening goals.

Potential harms of skin cancer screening include cosmetic harms, overdiagnosis, overtreatment, and psychosocial harms related to diagnostic workup. The evidence on these harms is very limited. Risk for excision-related harms could be greater in younger persons, based on a greater number of excisions required for each melanoma or NMSC case detected.58 For melanoma, excision-related harms are important because initial management with biopsy alone is not sufficient for removing the entire lesion. Subsequent excisions are usually necessary for clear margins, even for small lesions, particularly if the first biopsy is a shave or punch biopsy.75 No identified studies addressed overdiagnosis in a screening setting, but there is potential for overdiagnosis: melanoma incidence has increased 3-fold since 1975 while melanoma mortality has remained stable, suggesting increased detection of clinically insignificant cancers rather than earlier detection of invasive tumors.14, 76 An important consideration for the 2.1 million Medicare enrollees diagnosed with NMSC annually8 is the increase in the detection and treatment of basal cell carcinoma in adults that likely has limited impact on life expectancy.77 Further, patient-relevant definitions and outcomes of melanoma overdiagnosis and overtreatment are not well understood and should be further explored.

The effectiveness of screening depends on effective treatment of identified lesions, and there have been several trends in the surgical treatment of skin cancer. In the late 1990s, clinical practice adopted sentinel lymph node biopsy in the diagnostic workup of melanoma, even in persons diagnosed with thin lesions. Based on SEER data (1995 to 2001), the proportion of thin lesions that received sentinel lymph node biopsy has statistically significantly increased. The proportion of thin melanomas smaller than 0.69 mm and 0.70 to 1.00 mm with sentinel lymph node biopsy increased from 1.6 and 6.3 percent, respectively, in 1995 to 7.8 and 42.4 percent, respectively, in 2001.^78^ More contemporary biopsy data has not yet been reported, and it is unclear whether the proportion of surgeons using lymph node biopsy has changed. In 2012, the clinical guidelines from the American Society for Clinical Oncology and the American College of Surgeons recommended sentinel lymph node biopsy for lesions of 1 to 4 mm, but the organizations felt evidence was insufficient to create guidelines for lesions smaller than 1.0 mm.79, 80

We were unable to describe the proportion of lesions smaller than 1.0 mm detected on the trunk or extremities that were treated with Mohs micrographic surgery, which is currently not recommended for basal cell or squamous cell carcinoma, lentigo maligna, and melanoma in situ on the trunk or extremities. The surgery is only appropriate for particularly large or aggressive types of skin cancer.81 As part of the AAD Choosing Wisely campaign, clinicians are advised not to treat uncomplicated NMSC smaller than 1.0 mm on the trunk and extremities with Mohs micrographic surgery.82 Although data on the use of Mohs micrographic surgery for these types of small skin cancers on the trunk or extremities could indicate potential overtreatment of screen-detected skin cancers, we found no relevant published data at the time of this report.

### Future Directions

The balance in favor of screening for skin cancer is likely to be greatest among subgroups of the population that are the most likely to develop fatal melanoma, which is yet to be distinguished. However, several algorithms use melanoma risk factors to qualify risk of melanoma and could have utility for screening programs in identifying persons who might benefit most from screening.83-86 The algorithms vary by whether ascertainment of the risk factor information is meant to be done by a health care provider, whether the target population includes persons with a family history of melanoma and/or a history of NMSC; and whether the algorithm has been validated. Most existing algorithms have been developed using only information on melanoma risk among persons of white race.83-86

One algorithm intended for use by health care providers during clinical care and developed using data from a large melanoma case-control study estimates 5-year risk of developing melanoma in non-Hispanic white persons ages 20 to 70 years.83 The algorithm includes demographic information (sex, age, and region of residence), history of blistering sunburn (men)/propensity for skin to become tanned (women), and presence of nevi on the back.83 The area under the receiver operating characteristic curve—a measure of the accuracy of the algorithm, where 0.5 indicates inability to predict who will and will not develop melanoma87—ranged from 0.7 to 0.8 depending on sex and age group.83 The algorithm was not validated in an external population.83 There is no evidence to suggest that these algorithms have been adopted in U.S. clinical practice. If externally validated, risk assessment tools might lead to research testing a targeted screening approach. Similar to other cancer risk assessment tools, they may also provide guidance to individuals on their risk of developing melanoma.

### Review Limitations

Our review focused on the clinical skin examination to screen for skin cancer, not the self-detection of skin cancer by an individual. The nature of skin cancer makes this review unique. In contrast to breast, colorectal, or lung cancers, where a provider-administered screening modality and access to specialty followup are essential for early detection, individuals can and do identify concerning lesions on their own skin. Thus, community education about skin cancer and improved access to physician review of suspicious lesions is a critically important part of any skin cancer early detection program. These components have been reviewed by the Community Preventive Services Task Force.88 Further, studies conducted outside of primary care (e.g., the workplace, “screening days,” or “pigmented lesion clinics”) were outside the scope of this review, as were studies of patients referred for diagnostic workup from a source population that could not be defined. For these reasons, the role of physician screening in primary care may appear as isolated in this review.

## Study Limitations and Future Research Needs

The bulk of the literature considered in this review was from international settings, specifically Australia, where skin cancer screening and outcomes have been a research focus and the burden of melanoma is much higher compared to the United States or other countries.89

A main limitation of this review is the lack of rigorous studies on skin cancer screening conducted in the United States with an application in primary care or internal medicine settings. Our focus was on fair- or good-quality studies that met our inclusion criteria. Among U.S. studies, very few had longitudinal followup for cancer outcomes, limiting their applicability. Participants in most screening studies tended to be younger women with a perceived increased risk of skin cancer, even though the incidence of skin cancer is highest in older men.90

Further research on skin cancer screening should:

- Conduct followup of sufficient length to assess individual melanoma mortality in screened and unscreened persons, with ascertainment of cancer outcomes based on registry systems
- Examine the impact of targeted, risk-based screening versus average-risk population screening for clinical effectiveness and clearly document the risk factors of the screened population for potential self-selection
- Study the relative impact of primary care–based screening relative to other components of a screening program, such as public education and improved access to skin examinations
- Advance knowledge about the potential for overtreatment and overdiagnosis, including the psychosocial consequences, of population-based skin cancer screening to help fully understand the benefits of screening in the context of potential harms

## Conclusion

On a population level, with limited evidence on skin cancer screening, a clear statement cannot be made about the benefit of skin cancer screening for melanoma mortality and all-cause mortality or association with thinner lesions. With few studies to confirm these results, the applicability for widespread skin cancer screening could be limited. Later stage at diagnosis of melanoma is associated with strong effect on melanoma mortality within 5 years of diagnosis. Future research on skin cancer screening should focus on targeted screening in persons considered to be at higher risk for skin cancer.