# Results

## Description of Included Studies

Our literature search yielded 12,514 unique abstracts; 453 met the criteria for full-text review (Appendix A Figure 1). We included 13 unique studies (k=13) of fair to good quality reported in 15 articles (n=15) that answered one or more of our five KQs as follows: KQ 1 (n=3 articles, k=1 study), KQ 2 (n=3, k=2), KQ 3 (n=2, k=2), KQ 4 (n=1, k=1) and KQ 5 (n=8, k=8) (Table 1).

Table 1 Description of Included Studies for KQs 1–5

Author, Year Quality | Country | Study Design | N | Population | Mean Age, Years (SD or Range) or Category | % Female | Dates of Data Collection | Length of Followup | KQ
Katalinic, 2012^53^ Fair Waldmann, 2012^58^ Fair Breitbart, 2012^55^ Good SCREEN | Germany | Ecologic53 | 87.46 million | Inhabitants of Germany and Denmark from 1998 to 2009 | NR | 50.9% | 1998–2009 | 5 years after intervention | 1
Katalinic, 2012^53^ Fair Waldmann, 2012^58^ Fair Breitbart, 2012^55^ Good SCREEN | Germany | Cohort55,58 | 360,288 | Residents of Schleswig-Holstein, Germany age ≥20 years with whole-body skin cancer screening exam between July 2003 and June 2004 | 49.7 (16.2) | 73.6% | 2003–2004 | 12 months | 1, 2
Gambichler, 2000^59^ Fair | Germany | Case series | 45 | Routine skin cancer screening outpatients not suspected of melanoma with a shave biopsy | 32 (range, 15–54) | 51.1% | NR | 6 months after biopsy | 2
Aitken, 2006^56^ Fair | Australia | Cohort | 16,383 | Residents in a community-based pilot randomized, clinical trial of skin cancer screening program | 46.5 (16.4) | 51.5% | 1998–2001 | Up to 3 years after the initial screening exam | 3
Fritschi, 2006^57^ Fair | Australia | Cohort | 7,436 | Adults who attended Lions Cancer Institute weekend mobile screening clinics in rural and suburban locations in Western Australia | <40: 26.2% 40–59: 46.2% ≥60: 27.6% | 56.0% | 1994–2002 | 2 years after the initial screening exam | 3
Aitken, 2010^61^ Fair | Australia | Population- based case-control | 3,762 cases 3,824 controls | Queensland residents ages 20 to 75 years; cases identified from cancer registry and controls selected through stratified random sampling from Queensland Electoral Roll | <40: 16.4% 40–69: 69.6% ≥70: 14.0%^*^ | 42.4%^*^ | NR | N/A | 4
Marashi-Pour, 2012^68^ Good | Australia | Retrospective cohort study | 52,330 | Cases of cutaneous melanoma from the New South Wales Central Cancer Registry diagnosed between 1988 and 2007 | <40: 14% 40–69: 54% ≥70: 31 | 42% | 1988–2007 | Followup time was calculated from the date of diagnosis until death or end of the study period (December 31, 2007) | 5
Pollack, 2011^65^ Good | U.S. | Retrospective cohort study | 68,495 | Cases of melanoma (excluding in situ disease) in the 13 SEER registries in persons age >15 years with no previous cancer diagnosis | <40: 19.5% 40–64: 48.9% ≥65: 31.5% | 45.1% | 1992–2006 | First primary melanoma cases diagnosed from 1992 to 2001. Followed up through 2006. | 5
Reyes-Ortiz, 2006^63^ Fair | U.S. | Retrospective cohort study | 23,068 | 23,068 Medicare beneficiaries age ≥65 years residing in 1 of 11 SEER regions, diagnosed with melanoma between 1988 and 1999, and ethnicity information complete | <39: 0% 40–64: 0% ≥65: 100% | 40.0% | 1988–1999 | Survival defined as the period between diagnosis and death from melanoma. Censored at death from other causes or December 31, 2000. Followup through December 31, 2000. | 5
Leiter, 2004^70^ Fair | Germany | Retrospective cohort study | 12,728 | Persons with thin incident primary invasive melanoma between 1976 and 2000 in the German-based Central Malignant Melanoma Registry | 50 (15.7) | 58.6% | 1976–2000 | Data obtained from the Central Malignant Melanoma registry. Patients were examined every 3 to 6 months for 10 years. All included patients had a followup time of at least 3 months and at most 10 years. | 5
Luke, 2003^67^ Fair | Australia | Retrospective cohort study | 9,519 | Residents of the state of South Australia diagnosed with invasive cutaneous melanoma | <39: 21% 40–69: 53% ≥70: 26% | 49.9% | 1980–2000 | 1994 to 2000 diagnostic period identified through cancer registry; dates censored at death from other causes or December 31, 2000 | 5
Zell, 2008^64^ Good | U.S. | Retrospective cohort study | 39,049 | Incident patient cases of cutaneous melanoma reported between 1993 and 2003 in the California Cancer Registry^†^ | 58^‡^ (95% CI, 29.0 to 84.0) | 43.1% | 1993–2003 | Hospital registrars contacted cases annually and Registry staff annually reviewed death certificates. The last date of followup was either date of death or the last date of contact. | 5
Owen, 2001^66^ Fair | U.S. | Retrospective cohort study | 4,560 | Registered patients at the Duke University Melanoma Clinic who began treatment within 3 months before or after excision of a primary melanoma (in situ excluded) | 48.3 (14.2)^§^ | 45.5% | 1970–1995 | Patients registered at Duke University Melanoma clinic between January 1, 1970 and December 31, 1995. Followup was limited to 10 years by censoring all observations for patients still alive at 10 years after surgery (also death from other causes and LTFU resulted in censoring). | 5
Green 2012^69^ Fair | Australia | Retrospective cohort study | 26,736 | Queensland residents with a single thin invasive melanoma (≤1.00 mm) diagnosed between 1982 and 2006 | 52.7 (range, 15 to 89) | 46.4% | 1982–2006 | Minimum 1 year followup (survival assessed up to December 31, 2007). Average length of followup NR. | 5

Numbers in italics represent calculated numbers.

* These data refer to control participants only.

† California Cancer Registry is part of SEER.

‡ Median age.

§ Mean age at surgery.

Abbreviations: SD = standard deviation; KQ = key question; NR = not reported, N/A = not applicable; SEER = Surveillance, Epidemiology, and End Results Program; LTFU = lost to followup.

Of the 13 unique studies, most study designs (k=10) were observational cohort studies. The study designs for the remaining three studies were case-control, ecologic, and case series. The most relevant included study was the Skin Cancer Research to Provide Evidence for the Effectiveness of Screening (SCREEN) study conducted in the Schleswig-Holstein region of Germany. The SCREEN study provided data on outcomes including mortality (KQ 1) and number of excisions needed to detect one case of skin cancer (KQ 2).

## Included Populations

Of the 13 included studies, five were included for screening questions (KQs 1–4) and eight for the association between stage at melanoma detection and skin cancer mortality (KQ 5).

In the five screening studies (Table 2), four evaluated skin cancer screening in populations and one evaluated skin cancer screening as an exposure using a case-control design. Study population size ranged from 45 to 360,288 individuals. The reported mean age ranged from 32 to 58 years. When reported, the prevalence of more than one skin cancer risk factor ranged from 47.7 to 62.4 percent of the populations.

Table 2 Description of Screening Interventions of Included Studies (KQs 1–4)

Author, Year Quality Location | Target Population | N | % Female Mean Age (SD) | Skin Cancer Risk Factors | Provider | Setting and Skin Cancer Screening Program | Followup of Identified Lesions
Katalinic, 2012^53^ Fair (KQ 1) Waldmann, 2012^58^ Fair (KQs 1, 2) Breitbart, 2012^55^ Good (KQs 1, 2) SCREEN study Germany | Residents of Schleswig-Holstein, Germany 1998–2009 | 360,288 | 73.6% 49.7 (16.2) | NR; among people with referral to dermatology, report of skin conditions included: Multiple melanocytic nevi: 9.8% Clinically atypical nevi: 9.0% UV-damaged skin: 4.8% Actinic keratosis: 2.1% | Nondermatologists and dermatologists | 1. Physician education (training of 64.0% nondermatologists and 98.3% dermatologists who practice in this region); 2. Public awareness campaign; 3. Whole-body skin exam conducted by nondermatologist and dermatologists | Referred to dermatologist
Gambichler, 2000^59^ Fair (KQ 2) Germany | Patients undergoing shave excision biopsy for suspicion of NMSC | 45 | 51.1% 32 (15–54) | NR | Dermatologists | Routine outpatient skin cancer screening (not further specified) followed by razor blade shave excision | Assessed by physician after 6 months
Aitken, 2006^56^ Fair (KQ 3) Australia | 9 intervention communities All primary care patients (adult) | 16,383 | 51.5% 46.5 (16.4) | ≥1 risk factor^*^: 47.7% | Primary care physicians | 1. Physician education; 2. Community education program; 3. Free access to screening clinics for whole-body skin exam, excluding areas covered by underwear | Referred to personal primary care physician; those not completing referral sent a reminder at 2 and 5 months
Fritschi, 2006^57^ Fair (KQ 3) Australia | Residents in rural and suburban locations, Western Australia | 7,436 | 56.0% <40: 26.2% 40–59: 46.2% ≥60: 27.6% | 0–2 risk factors^†^: 37.7% 3–5: 55.8% 6–8: 6.6% | Dermatologists and plastic surgeons | 1. Earned media providing education on 8 risk factors and number to call for appointment; 2. Mobile clinic staffed by physician volunteers; 3. Whole-body skin exam | Referred to primary care physician. Cancer outcomes were ascertained from national cancer registry as gold standard.

* Fair skin, a tendency to burn after 1 hour of sun exposure, or >10 moles on the body.

† Risk factors included: family history of melanoma; ≥5 moles on the forearms; previous removal of benign nevi; previous skin cancer; a lesion that is changing in size, color, or shape; a lesion that does not heal; fair skin that burns rather than tans; and episodes of severe sunburn as a child.

Abbreviations: KQ = key question; SD = standard deviation; NR = not reported; UV = ultraviolet; NMSC = nonmelanoma skin cancer.

In the eight studies that included the association between stage at melanoma detection and skin cancer mortality, all had a sample size of more than 4,000 individuals. Mean age ranged from 48.3 to 58 years, when reported, and the majority of populations were between ages 40 and 64 years. One study was conducted in a Medicare only population. Four studies were conducted with data from the United States, three from Australia, and one from Germany.

## Included Screening Programs

Three different screening programs were described by five articles (Table 2).53-57 The screening interventions were aimed at asymptomatic populations and included screening by primary care physicians only, primary care physicians and other nondermatology specialists, or volunteer dermatologists and plastic surgeons. All screening interventions were multicomponent and included physician education; media campaigns or outreach to encourage individuals to participate in screening; and access to visual skin examinations with a medical provider with planned followup for the participants who screen positive. None of the screening programs enouraged biopsy of lesions at the time of the first visual examination.

## Quality

We included four good- and 11 fair-quality articles. In general, the limitations for fair-quality studies included: response rates for followup, study design, outcome assessment, complete data presented, and specifications of model adjustment.

## KQ 1 What Is the Direct Evidence That Visual Screening for Skin Cancer by a Primary Care Provider or Dermatologist Reduces Skin Cancer Morbidity and Mortality and All-Cause Mortality?

### Summary of Results

We identified no trials that assessed skin cancer morbidity or all-cause mortality associated with physician visual skin screening. We identified one fair-quality ecologic study (the SCREEN study) that compared trends in melanoma mortality in the population over 10 years in the Schleswig-Holstein region of Germany, where there was a population-based visual skin cancer screening program, compared to melanoma mortality trends in surrounding regions, where there was no population-based skin cancer screening program (Table 3).

Table 3 Melanoma Mortality Associated With Visual Skin Cancer Screening (KQ 1)

Katalinic, 2012^53^ | Total Population 2009 (Millions) | Prescreening (1998–1999) Melanoma Deaths (n) | Prescreening (1998–1999) WASR (95% CI) | Screening Program (2003–2004) Melanoma Deaths (n) | Screening Program (2003–2004) WASR (95% CI) | Postscreening (2008–2009) Melanoma Deaths (n) | Postscreening (2008–2009) WASR (95% CI) | Absolute Change in WASR From 1998–1999 to 2008–2009 | % Change in Mortality Rate 1998–1999 to 2008–2009
Intervention region
Schleswig-Holstein (360,288 persons screened) | 2.83 | 86 | 1.7 (1.4–2.0) | 82 | 1.4 (1.2–1.6) | 50 | 0.9 (0.7–1.1) | -0.8 | -48%
Comparison regions
South: Hamburg | 1.78 | 41 | 1.2 (0.9–1.5) | 52 | 1.5 (1.2–1.8) | 46 | 1.2 (1.0–1.5) | 0 | +2%
West: Lower-Saxony | 7.94 | 224 | 1.4 (1.3–1.6) | 239 | 1.5 (1.3–1.6) | 253 | 1.5 (1.4–1.7) | +0.1 | +7%
East: Mecklenburg-Vorpommern | 1.66 | 32 | 1.0 (0.8–1.3) | 43 | 1.3 (1.0–1.6) | 50 | 1.3 (1.0–1.6) | +0.3 | +32%
North: Denmark | 5.53 | 203 | 2.3 (2.0–2.5) | 221 | 2.3 (2.0–2.5) | 252 | 2.5 (2.2–2.7) | +0.2 | +4%
Germany^*^ | 79.1 | 1,940 | 1.3 (1.3–1.4) | 2,213 | 1.4 (1.3–1.4) | 2,529 | 1.4 (1.4–1.5) | +0.1 | +10%

* Excludes Schleswig-Holstein region.

Abbreviations: KQ = key question; CI = confidence interval; WASR = world age-standardized morality rate (per 100,000).

The SCREEN study introduced a statewide skin cancer screening program in 2003,^54^ including a multicomponent intervention: 1) training nondermatologists and dermatologists in skin cancer screening, 2) a media campaign to encourage skin cancer screening in adults age 20 years and older, and 3) a followup dermatology referral protocol for nondermatologists to refer adults with either suspicious lesions or multiple risk factors for skin cancer. During the 1-year intervention period (2003 to 2004), nearly 361,000 adults (19% of the age-eligible adults) were screened with a visual skin cancer examination, mainly by nondermatologists. The majority of those screened were women (73.6%), and the mean age was 49.7 years (standard deviation, 16.2 years). Changes in melanoma mortality pre- and postintervention were compared to four surrounding geographic regions and Germany as a whole (excluding the intervention region). Between 1998 and 1999 (prescreening) and 2003 and 2004 (screening program initiation), melanoma mortality remained constant in the intervention region and the five comparison regions. Between 1998 and 1999 (prescreening) and 2008 and 2009 (postscreening), age- and sex-adjusted melanoma mortality decreased from 1.7 to 0.9 deaths per 100,000 persons. The change in melanoma mortality decreased by 48 percent in the SCREEN region, resulting in an overall absolute mortality difference of 0.8 melanoma deaths per 100,000 persons. By comparison, in the other five regions the absolute change in melanoma mortality remained stable or increased by 0.1 to 0.3 deaths due to melanoma per 100,000 persons. Percent change in mortality over 10 years increased from 2 to 32 percent. As an ecologic study, the results do not provide individual-level data about risk reduction associated with screening, and it is not possible to directly compare changes in mortality among those exposed versus not exposed to skin cancer screening and account for confounding. The results should be viewed cautiously.

### Detailed Results

#### The SCREEN Study (Germany)

The SCREEN study was conducted to determine the feasibility of a population-based skin cancer screening program in the German primary care health system. Germany had a nationally mandated but previously unorganized early skin cancer detection program.55 In 1989, analysis of the feasibility of the pilot program and data collection components began. In 2001, pilot intervention activities occurred on a small scale with 200 physicians and 6,000 screened patients in the Schleswig-Holstein region of northern Germany. Pilot activities included physician training sessions, a limited screening program within clinical practice, and public awareness campaigns. The pilot activities helped to draft protocol for full implementation.

Between 2003 and 2004, the SCREEN project implemented population-based skin cancer screening with a component intervention (Table 2), including the following:

1. Provider education and training. From April 2003 to September 2003, nondermatologists (defined as general practitioners in primary care, obstetricians and gynecologists, and urologists) (n=1,673) and dermatologists (n=116) participated in an 8-hour training course. The course focused on detecting all skin cancers and included training in the epidemiology and etiology of skin cancer, training and practice in standardized whole body visual examination, strategies for actively recruiting patients for screening, and program documentation and referral procedures. All providers were evaluated at the end of training for accuracy in visual diagnosis of skin cancer and demonstrated improvement in knowledge.55 Training participation rates were 64 percent for nondermatology providers and 98 percent for dermatologists practicing in the region.
2. Public outreach. The intervention encouraged residents of Schleswig-Holstein age 20 years and older to seek skin cancer screening by a nondermatology physician. Communication channels included health insurers, physicians, and mass media campaigns via print, Internet, and telephone resources. Outreach efforts provided information about the screening procedure, program eligibility criteria, and how to get screened.
3. Screening procedure. Screening examinations were conducted from July 2003 to June 2004. The main screening pathway was a whole-body visual skin examination conducted by a nondermatology provider. Referrals to dermatology were made on identification of a suspicious skin lesion or for patients with risk factors for skin cancer. Alternatively, participants could choose to be initially screened by a dermatologist. Upon documentation of the screening episode using a standardized paper form that included risk factor information, physicians were reimbursed about $20 per screening examination. From dermatology, all tentative clinical diagnoses were followed by biopsy and histopathologic evaluation. All detected cancers were reported to the state tumor registry.

Neither the surrounding German regions to the east, west, and south, nor Denmark, the country sharing Schleswig-Holstein's northern border, implemented population-based skin cancer screening activities during the same time frame. These areas were used as comparison populations for melanoma mortality.

##### Participation

Of a total population of 2.8 million, 1.9 million persons age 20 years and older comprised the eligible screening population. During the project period, 360,288 persons completed visual skin examinations, representing 19.1 percent of the eligible population in the region. Screening participation rates varied by age, with 20 to 22 percent of adults ages 35 to 69 years participating in screening compared to 14.9 percent of adults older than age 70 years. Almost three quarters of screened participants were women (73.6%).

##### Conduct of Screening

Of the initial screening examinations, 77.4 percent were conducted by nondermatology providers and 22.6 percent were conducted by dermatologists. Among the 73,710 persons referred to dermatology after screening by nondermatology providers, 36.8 percent were lost to followup and did not see a dermatology provider for a second clinical examination.

##### Skin Lesion Results

During the SCREEN study period from 2003 to 2004, 1,169 incident melanoma cases were reported to the state cancer registry, 585 of which were detected via the SCREEN study.54, 55 Of the melanomas detected by the SCREEN study, 31 percent were melanoma in situ and 69 percent were invasive melanoma diagnoses. The SCREEN study also detected 1,961 basal cell carcinomas, 392 squamous cell carcinomas (including Bowen carcinoma), and 165 other skin cancers.

As anticipated, incidence of melanoma, basal cell carcinoma, squamous cell carcinoma, and melanoma in situ all increased statistically significantly by 15 to 48 percent during the SCREEN study (Appendix D Table 3). Age-adjusted melanoma incidence rates (per 100,000 persons) in the prescreening (2001 to 2003) versus during-screening period (2003 to 2004) increased 27 percent, from 14.2 (95% CI, 13.3 to 15.1) to 18.0 (95% CI, 16.6 to 19.4) cases, respectively. Age-adjusted melanoma in situ incidence rates (per 100,000 persons) in the prescreening versus during-screening period increased 48 percent, from 5.8 (95% CI, 5.2 to 6.4) to 8.5 (95% CI, 7.5 to 9.5) cases, respectively. Age-adjusted squamous cell carcinoma incidence rates (per 100,000 persons) in the prescreening versus during-screening period increased 15 percent from 11.2 (95% CI, 10.6 to 11.8) to 12.9 (95% CI, 12.0 to 13.8) cases, respectively. Age-adjusted basal cell carcinoma incidence rates (per 100,000 persons) in the prescreening versus during-screening period increased 29 percent, from 60.5 (95% CI, 59.0 to 62.1) to 78.4 (95% CI, 75.9 to 80.8) cases, respectively.

##### Melanoma Mortality

Age- and sex-adjusted melanoma mortality rates in Schleswig-Holstein declined 48 percent in 2008 to 2009, 5 years after the SCREEN study began, compared to 1998 to 1999, 5 years before the SCREEN study (Table 3). From 5 years prescreening (1998 to 1999) to 5 years postscreening (2008 to 2009), melanoma mortality declined by 0.8 melanoma deaths per 100,000 persons within the intervention region. Declines in melanoma mortality were not observed in the same time period in regions to the north, south, east, or west or in Germany overall (excluding Schleswig-Holstein). During the study period, melanoma mortality changes in other regions were: 2 percent increase in Hamburg (south), 7 percent increase in Lower Saxony (west), 32 percent increase in Mecklenburg-Vorpommern (east), 4 percent increase in Denmark (north), and 10 percent increase in Germany (excluding the intervention region). Melanoma mortality reductions in the intervention region were similar for men and women (Appendix D Tables 1 and 2).

As an ecologic study, the results from SCREEN do not provide information about individual risk reduction associated with skin cancer screening to directly compare changes in mortality among persons exposed versus not exposed to skin cancer screening and to account for confounding (through randomization or multivariate adjustment), which limits the ability to infer a causal relationship between the SCREEN program and melanoma mortality. The results should be viewed cautiously.

## KQ 2 What Are the Harms of Screening for Skin Cancer and Diagnostic Followup?

### Summary of Results

We assessed harms due to screening, including overdiagnosis, psychosocial harms, and procedure-related adverse events. We did not identify any studies that directly reported on procedure-related adverse events or psychosocial harms, such as skin infections or scar revisions in screened populations. Further, we did not identify any studies that specifically identified overdiagnosis in screened populations. We identified two fair-quality studies conducted in Germany that assessed the number of excisions needed to detect one melanoma, basal cell carcinoma, or squamous cell carcinoma (the SCREEN study) and cosmetic acceptance of shave biopsy in a screened population (Tables 4 and 5).54, 58

Table 4 Number of Excisions Needed to Detect One Case of Melanoma or Squamous Cell or Basal Cell Carcinoma (KQ 2)

Number of Excisions Needed to Detect 1 Case | Melanoma | Squamous Cell Carcinoma | Basal Cell Carcinoma
Waldmann, 2012^58^ Fair Germany
Overall | 28 | 41 | 9
Female
Age, years
20–34 | 41 | N/A | 138
35–49 | 30 | 579 | 34
50–64 | 24 | 72 | 8
≥65 | 22 | 14 | 4
Total | 28 | 56 | 10
Male
Age, years
20–34 | 52 | 926 | 116
35–49 | 55 | 435 | 35
50–64 | 22 | 48 | 7
≥65 | 20 | 12 | 4
Total | 28 | 28 | 7

Abbreviations: KQ = key question,; N/A = not applicable.

Table 5 Measured Cosmetic Harms From Participating in Screening and Diagnostic Workup (KQ 2)

Study | N | Procedure and Provider Type | Harms Assessment | Reported Harms
Gambichler, 2000^59^ Fair Germany | 45 patients who had been identified by skin cancer screening with 77 nevi and received biopsy | Deep shave excision with razor blade biopsy | Assessed by physician^*^ and patient on a 4-point scale 6 months after excision (1=excellent, 4=poor) | Physician-reported poor: 16.1% (mean score, 2.5) Patient-reported poor: 7.1% (mean score, 1.7)

* Cosmetic harms defined as: erythemia, hyperpigmentation, hypopigmentation, hypertrophic scarring, and hypotrophic scaring.

Abbreviation: KQ = key question.

The number of excisions needed to detect one melanoma, basal cell carcinoma, or squamous cell carcinoma varied by age and sex. For all cancers, fewer excisions were needed to detect a single case in individuals age 65 years or older compared to younger individuals. For example, detecting one melanoma in women age 65 years or older required 22 excisions compared to 41 excisions in women ages 20 to 34 years. Similar patterns were observed in men and for other cancer types. In a population of 46 adults who underwent cancer screening subsequent to shave biopsy for removal of potential NMSC, 7.1 percent of patients reported their cosmetic results as poor (mean score 1.7, between excellent and good) compared to 16.1 percent of physicians who rated the results as poor (mean score 2.5, between good and fair). Few studies evaluated harms of screening.

### Detailed Results

#### Excision Rates per Melanoma, Basal Cell Cancer, or Squamous Cell Cancer Detected

The fair-quality SCREEN study evaluated the impact of skin cancer screening on the overall number of excisions needed for melanoma detection by number of melanomas detected (Table 4). The study included 15,983 total excisions performed in 360,288 adults screened for skin lesions suspicious for melanoma, squamous cell carcinoma, or basal cell carcinoma. Calculations were based on only one excision per person and one malignant finding per tumor per person.

Comparing men and women, similar numbers of excisions were needed to detect any melanoma (1 per 28 excisions) or any basal cell carcinoma (1 per 9 to 10 excisions). However, 28 additional excisions occurred in women compared to men to detect a single squamous cell carcinoma (56 in women vs. 28 in men). Large differences were seen in diagnostic yield analyzed by age, with younger women and men undergoing more excisions for a lower yield compared to older adults. Compared to women age 65 years and older, women ages 20 to 34 years experienced 19 additional excisions to detect one melanoma and 134 additional excisions to detect one basal cell carcinoma. The number needed to excise additional squamous cell lesions could not be calculated with the available data in young women. However, 565 additional excisions were needed to detect one squamous cell carcinoma in women ages 35 to 49 years compared to women older than age 65 years. Compared to men age 65 years and older, men ages 20 to 34 years experienced 24 additional excisions per one melanoma, 898 additional excisions per one squamous cell carcinoma, and 109 additional excisions per one basal cell carcinoma. Based on these excision rates, the estimated false-positive rate for melanoma or NMSC can be quite high in a screened population with a younger age distribution.

#### Cosmetic Harms

In one fair-quality study59 of routine outpatient cancer screening, cosmetic harms were evaluated by 45 patients and a single physician at 6 days and at 6 months after shave biopsy (Table 5). Participants were identified during routine skin cancer screening but the study authors did not further describe the screening process. Only patients who underwent razor-blade shave excision for suspected NMSC and did not have subsequent skin cancer were included. In 5 percent of shave sites, delayed healing and infection were postoperatively observed by the physician. Among the 60 percent of patients evaluated at 6 months, physicians reported shave site outcomes, including 52 percent hypopigmentation, 32 percent marginal hyperpigmentation, 23 percent erythema, 7 percent hypertrophic scarring, 4 percent hypotrophic scarring, and 13 percent recurrent nevus. At 6 months, the physician and the patients assessed patient outcomes at the excision site based on a four-point physical judgment scale of excellent, good, moderate, or poor. The mean patient evaluation score was higher (1.7, between excellent and good) than the mean physician score (2.5, between good and moderate). As such, 7.1 percent of patients expressed poor satisfaction with the cosmetic results from shave biopsy 6 months later compared to 16.1 percent of their physicians regarding the same lesion removal. The results do not directly assess cosmetic results from excisional biopsies needed for melanoma diagnosis, which are more invasive procedures.

## KQ 3 What Are the Test Characteristics of Visual Screening for Skin Cancer When Performed by Primary Care Providers Versus Dermatologists?

### Summary of Results

We identified two fair-quality cohort studies with data on the test characteristics of skin cancer screening performed by primary care physicians or dermatologists in Australia. Skin cancer outcomes were obtained through either cancer registry data57 or pathology and biopsy reports and an estimate of false-negative screening rates (Table 6).56 In the first study in Queensland, Australia, primary care physicians conducted screenings among 16,383 adults. Cancer outcomes were determined by pathology or biopsy reports for positive screens. False-negative rates for melanoma were estimated using prior literature and population melanoma rates. The recall rate was 14.1 percent for those who screened positive and were referred to their usual primary care physicians for followup. Based on the number of melanomas detected within 3 years of the first screening examination, sensitivity for melanoma detection was 40.2 percent (calculated) and specificity was 86.1 percent (95% CI, 85.6 to 86.6). The positive predictive value for melanoma was 1.4 percent. The second study evaluated the performance of volunteer dermatologists and plastic surgeons who conducted screening in 7,436 adults in suburban and rural areas in Western Australia. With followup to 24 months for melanoma through a cancer registry system, the sensitivity was 49.0 percent (95% CI, 34.4 to 63.7) and the specificity was 97.6 percent (95% CI, 97.2 to 97.9), with an overall recall rate of 2.7 percent. The positive predictive value was 11.9 percent (95% CI, 7.8 to 17.2). Different followup times for cancer outcomes prohibited direct comparison of screening accuracy between the two physician types.

Table 6 Diagnostic Accuracy of Primary Care Providers and Dermatologists for Diagnosing Melanoma Through Visual Skin Examination (KQ 3)

Study, Year Quality | Who Performed Screening? | Comparison/Gold Standard | Followup | Sensitivity (95% CI)^*^ | Specificity (95% CI)^*^ | Recall Rate^†^ | PPV (95% CI)^*,‡^ | Cancer Detection Rate | Cancer Rate
Fritschi, 2006^57^ Fair Australia | Volunteer dermatologists or plastic surgeons | Cancer diagnosis in regional cancer registry within 2 years of screening | 12 months melanoma | 69.7% (51.3 to 84.4) | 97.6% (97.2 to 97.9) | 2.7% | 11.4 (7.4 to 16.7) | 0.3% | 0.4%
Fritschi, 2006^57^ Fair Australia | Volunteer dermatologists or plastic surgeons | Cancer diagnosis in regional cancer registry within 2 years of screening | 24 months melanoma | 49.0% (34.4 to 63.7) | 97.6% (97.2 to 97.9) | 2.7% | 11.9 (7.8 to 17.2) | 0.3% | 0.7%
Aitken, 2006^56^ Fair Australia | Primary care physicians | For positive screen: pathology and biopsy reports Estimated the number of false-negatives based on prior literature60 and Queensland melanoma incidence rates | 36 months melanoma only | 40.2% | 86.1% (85.6 to 86.6) | 14.1% | 1.4% | 0.2% | 0.5%
Aitken, 2006^56^ Fair Australia | Primary care physicians | For positive screen: pathology and biopsy reports Estimated the number of false-negatives based on prior literature60 and Queensland melanoma incidence rates | 36 months any skin cancer | Cannot be calculated | Cannot be calculated | 14.1% | 16.9% | 2.4% | Cannot be calculated

Values that are italicized were calculated using available data from the study results.

* Confidence intervals reported for measures calculated by study authors.

† Recall rate = the number of skin examinations that resulted in a recommendation for followup with a dermatologist divided by the number of screened individuals; the recall rate is the same regardless whether followup is 1 or 2 years.

‡ Skin cancer diagnosis among those recalled for further examination.

Abbreviations: KQ = key question; CI = confidence interval; PPV = positive predictive value.

### Detailed Results

#### Screening by Primary Care Physicians

One fair-quality study of skin cancer screening within nine communities in Queensland, Australia allowed assessment of test characteristics of screening conducted by primary care physicians. The intervention, a pilot study intended to precede a randomized, controlled trial, had three components: 1) a community education program; 2) a physician education program, including a full day with dermatology specialists to review skin cancer epidemiology, early diagnosis, management, and patient communication aimed at encouraging primary care physicians to offer their patients whole-body skin examinations; and 3) free patient access to skin cancer screening clinics in the intervention regions. Whole-body skin examinations were provided by primary care physicians who practiced within the communities and by primary care physicians from outside the community employed by the research study. The research team sent personalized letters to men and women in the community ages 30 to 79 years to encourage participation in skin cancer screening. Positive screens were defined as a skin lesion suspected to be cancerous at the screening examination, and persons with positive screens were referred to their usual primary care physicians for diagnosis and management of the lesion.

Pathology reports from biopsy were used to ascertain cancer outcomes for patients who screened positive. Patients with negative screens were not linked to cancer registry data; instead, the negative screening rate for melanoma was estimated using the number of false-negative results from the literature60 and population-based estimates of melanoma incidence. Using a false-negative rate of 0.2 percent and an adjusted age distribution for screening participants, an estimated 49 participants would screen negative but subsequently be diagnosed with melanoma within 3 years of the examination, if the entire sample had been linked to cancer registry data. Because the false-negative rate was estimated only for melanoma and not for all skin cancers, test accuracy for sensitivity and specificity for all skin cancers could not be estimated.

The total sample included 16,383 adults. About 52 percent of the study population were women and the average age of those screened was 46.5 years (standard deviation, 16.4). Of those referred for further evaluation, 79.1 percent followed up with their physician.

During the screening program, 33 melanomas (including 13 in situ melanomas), 259 basal cell carcinomas, and 97 squamous cell carcinomas were detected. Other benign skin conditions were also detected. Calculated sensitivity of screening examinations conducted by primary care physicians for melanoma detection was 40.2 percent (33 melanomas detected within 3 years/[33 melanomas plus 49 estimated false-negative melanomas]) and specificity was 86.1 percent (95% CI, 85.6 to 86.6). The recall rate was 14.1 percent of all screening examinations referred for additional workup among 2,302 persons. The positive predictive value for melanoma detection among those with a positive screening examination was 1.4 percent, and the overall cancer detection rate was 0.2 percent.

No information was provided on the false-negative rate for NMSC, so we were not able to calculate sensitivity and specificity. Some study data were available to calculate the positive predictive value for all skin cancer, including melanoma and NMSC in this population, which was 16.9 percent. The cancer detection rate was 2.4 percent.

#### Screening by Dermatologists

From 1994 to 2002, the Lions Cancer Institute offered whole-body skin examinations to men and women age 20 years and older in rural and suburban areas of Western Australia. Advertisements in local papers recruited individuals to screening clinics. From 1996, the advertisements directly targeted persons with the following eight risk factors: 1) family history of melanoma; 2) five or more moles on the forearm; 3) previous removal of a benign nevus; 4) previous skin cancer; 5) lesion changing in size, color, or shape; 6) lesion that does not heal; 7) fair skin that burns rather than tans; and 8) episodes of severe burns as a child. Volunteer dermatologists and plastic surgeons performed the whole-body skin examinations on patients, referring participants to their usual primary care physicians for further evaluation of suspected lesions. All participants regardless of screening outcome were linked to the Lions Cancer Registry for detection of melanoma at 1 and 2 years postscreening examination. Data were only provided for melanoma outcomes, and there were no data on all skin cancers or NMSC.

Over the 13 years of the screening program, 9,808 persons were screened, of whom 7,436 met the study inclusion criteria. About 56 percent of the population were women and 50.6 percent were older than age 50 years at the time of the screening examination.

There were 33 melanoma lesions diagnosed within 1 year of the screening examination and 16 additional melanomas diagnosed within 2 years of the screening examination, a total of 49 melanomas. Sensitivity for melanoma at 1 year was 69.7 percent (95% CI, 51.3 to 84.4), declining at 2 years to 49.0 percent (95% CI, 34.4 to 63.7). Specificity was 97.6 percent (95% CI, 97.2 to 97.9). Calculated recall rates for the screening examinations was 2.7 percent. The positive predictive value ranged from 11.4 to 11.9 percent for cancers detected within 1 and 2 years, respectively. In this population, the cancer detection rate was 0.31 percent for cancers diagnosed within 1 year and 0.32 percent for cancers diagnosed within 2 years.

## KQ 4 Does Visual Screening for Skin Cancer Lead to Earlier Detection of Skin Cancer Compared to Usual Care?

### Summary of Results

We identified one fair-quality case-control study that measured the association between whole-body skin examinations performed by a physician during the 3 years before melanoma diagnosis for cases or referent date for controls and risk of invasive melanoma according to lesion thickness at diagnosis (Table 7). The study was conducted among 3,762 cases with incident melanoma in Queensland, Australia and 3,824 controls randomly selected through electoral rolls. Among the controls, 28.3 percent reported receiving a clinical skin examination by a physician within 3 years of their reference date compared to 35.3 percent of melanoma cases. In multivariate-adjusted models, cases diagnosed with thin melanoma (≤0.75 mm) had a 38 percent higher odds (odds ratio [OR], 1.38 [95% CI, 1.22 to 1.56]) of receiving a clinical skin examination by a physician in the previous 3 years compared to controls. Further, cases diagnosed with thicker lesions (>0.75 mm) had a 14 percent reduced odds (OR, 0.86 [95% CI, 0.75 to 0.98]) of recent physician skin examination compared to controls. When thick lesions were further stratified by lesion size, the thickest melanoma lesion cases (≥3.00 mm) had 40 percent reduced odds of recent physician skin examination compared to controls (OR, 0.60 [95% CI, 0.43 to 0.83]). As a case-control study with self-reported exposure, there is the potential for recall bias. Medical record review of patient skin cancer screening history to confirm self-report would strengthen future research.

Table 7 Association Between Physician Clinical Skin Examination and Lesion Thickness at Melanoma Detection (KQ 4)

Study | Total N | Study Population | Exposure | Main Analysis and Adjusted Confounders | Main Result OR (95% CI)
Aitken, 2010^61^ Fair Queensland, Australia | Controls: 3,824 Cases: 3,762 | Controls: Randomly selected from Queensland Electoral Roll, based on 5-year groups and sex distribution of cases Cases: Men and women ages 20 to 75 years with histologically confirmed primary melanoma diagnosed between January 2000 and December 2003 | During the last 3 years before (you first believed something was wrong [cases]/reference date [controls]), had a doctor deliberately checked all or nearly all of your whole body for early signs of skin cancer? | Logistic regression adjusted for age group, sex, education, employment status, marital status, eye color, hair color, skin color, degree of freckling, number of moles on back, age of arrival in Australia, average lifetime sun exposure, family history of melanoma, family history of nonmelanoma skin cancer, and ethnicity | Controls: Referent Lesion thickness (mm) ≤0.75: 1.38 (1.22–1.56) >0.75: 0.86 (0.75–0.98) Stratification of thicker lesions 0.76–1.49: 0.93 (0.79–1.10) 1.50–2.99: 0.83 (0.66–1.05) ≥3.00: 0.60 (0.43–0.83)

Abbreviations: KQ = key question; OR = odds ratio; CI = confidence interval.

### Detailed Results

A case-control study in Queensland, Australia examined melanoma thickness and receipt of a physician clinical skin examination in the 3 years prior to melanoma diagnosis for cases (n=3,762) and controls (n=3,824).61 Cases were men and women ages 20 to 75 years with a histologically confirmed first primary invasive cutaneous melanoma diagnosed between January 2000 and December 2003 who were identified through the Queensland Cancer Registry. Recruitment letters were mailed to cases' treating physicians explaining the research study and seeking permission to contact the patients. After physicians provided permission, cases were invited by letter to participate in the study. Controls were randomly selected from the Queensland Electoral Rolls and matched to 5-year age categories and the sex distribution of the cases. Controls were also contacted by letter about study participation.

In telephone interviews, information was obtained on demographics and melanoma risk factors, including ethnicity, natural hair color at age 21 years, eye color, color of skin before tanning, tendency to burn when exposed to sun for an hour without protection, number of moles on the back, childhood sunburn history, and age when arriving in Australia. Participation rates in the telephone interviews were 78.0 percent for cases and 50.4 percent for controls.

Among controls, 58 percent were male and 49 percent were ages 50 to 69 years. The frequency of sun exposure factors for controls included: 93 percent with a tendency to burn after sun exposure; 60 percent with a heavy to very heavy average lifetime sun exposure; 19.2 percent with previous diagnosis of NMSC; and 14.5 percent with family history of melanoma in a blood relative.

Information on skin cancer screening collected in telephone interviews included self-screening, screening by partners and other lay people, and screening by a doctor, referred to as a clinical skin examination. For cases, screening history was collected only until the time of first awareness of melanoma signs and symptoms. Controls were assigned a reference date to evaluate skin cancer screening exposure. Reference dates were based on the distribution of cases for time from first symptom awareness to date of telephone interview, so the time frame for recollection would be similar between cases and controls. Clinical skin examinations were determined in telephone interviews by asking the question, “During the last 3 years before (you believed something was wrong [cases]/reference date [controls]), had a doctor deliberately checked all or nearly all of your whole body for early signs of skin cancer?” The self-reported receipt of screening by cases and controls was not confirmed by medical record review. However, the question as phrased had been validated in prior work, and test-retest reliability in a sample of participants 1 to 3 months after the interview indicated good agreement for both the cases and the controls.62

Among the controls, 28.3 percent reported receiving a clinical skin examination by a physician within the 3 years before their reference date compared to 35.3 percent of melanoma cases. When further stratified by lesion thickness, case report of receiving a clinical skin examination declined as lesion thickness increased: 38.7 percent for lesions smaller than 0.75 mm, 30.3 percent for lesions 0.76 to 1.49 mm, 28.0 percent for lesions 1.5 to 2.99 mm, and 22.5 percent for lesions 3.00 mm or larger.

Multivariate models adjusted for confounders, including age group, sex, education, employment status, marital status, eye color, hair color, skin color, degree of freckling, number of moles on back, age of arrival in Australia, average lifetime sun exposure, family history of melanoma, family history of NMSC, and ethnicity. In multivariate-adjusted models, cases diagnosed with thin melanoma lesions (≤0.75 mm) had 38 percent higher odds (95% CI, 1.22 to 1.56) of receiving a physician clinical skin examination in the past 3 years compared to controls. Further, cases diagnosed with thicker lesions (>0.75 mm) had 14 percent reduced odds (95% CI, 0.75 to 0.98) of recent physician skin examination compared to controls.

When thick lesions were further stratified by size, the odds of having a clinical skin examination by a physician decreased as thickness increased: 7 percent decreased odds for lesions 0.76 to 1.49 mm (95% CI, 0.79 to 1.10); 17 percent decreased odds for lesions 1.50 to 2.99 mm (95% CI, 0.66 to 1.05); and 40 percent decreased odds for lesions 3.0 mm or larger (95% CI, 0.43 to 0.83).

As a case-control study, there is the potential for recall bias due to differential reporting prior to physician skin screening examination by cases compared to controls. However, the potential for cases to recall examinations differentially by lesion size seems unlikely. Nonetheless, medical record review of patient skin cancer screening history to confirm self-report would strengthen future research using case-control study designs, as would cohort studies with clear exposure categories.

## KQ 5 What Is the Association Between Earlier Detection of Skin Cancer and Skin Cancer Morbidity and Mortality and All-Cause Mortality?

### Summary of Results

We identified eight fair- or good-quality observational cohort studies that included more than 200,000 persons. The studies examined the association between lesion thickness or stage at diagnosis (either AJCC or SEER stage) and either melanoma-specific or all-cause mortality (Tables 8–10). We identified one good-quality study that evaluated cancer stage and all-cause mortality. We did not identify any studies that evaluated lesion thickness or stage at diagnosis associated with skin cancer morbidity.

Table 8 Association Between Stage at Melanoma Diagnosis and Melanoma-Related Mortality (KQ 5)

Study, Year Quality Country | N | % Female Age (Years) | Stage Distribution | Melanoma Deaths (n) | Primary Analysis | Confounders for Adjustment | Melanoma-Related Mortality Adjusted HR (95% CI)
Pollack, 2011^65^ Good U.S. (13 SEER regions) 1992–2006 | 68,495 | 45.1% female <40: (19.5%) 40–64: (48.9%) ≥65: (31.5%) | Localized: 82.5% Regional: 10.8% Distant: 3.3% Unstaged: 3.5% | NR | Cox regression restricted to 5- year followup after diagnosis | Stratified on histologic subtype and anatomic site and adjusted for sex, age at diagnosis, race/ethnicity, stage, and depth. | Localized: Referent Regional: 3.62 (3.35–3.91) Distant: 18.66 (16.54–21.06)
Zell, 2008^64^ Good U.S. (California) 1993–2003 | 39,049 | 43.1% female Median age: 58 (95% CI, 29.0–84.0) | Stage IA: 58.7% IB: 21.0% IIA: 8.6% IIB: 5.0% IIC: 1.2% IIIB: 13.1% IIIC: 1.7% IV: 0.7% | 2,842 | Cox proportional hazards | Age, sex, race/ethnicity, AJCC stage, histologic subtype, anatomic tumor site, tumor ulceration, SES quintile, radiation therapy, chemotherapy, and immunotherapy. | I: Referent II: 4.96 (4.51–5.56) III: 9.99 (8.84–11.29) IV: 27.1 (22.4–32.8)
Reyes-Ortiz, 2006^63^ Fair U.S. (11 SEER regions) 1988–2000 | 23,068 | 40.0% female <39: 0 (0%) 40–64: 0 (0%) ≥65: (100%) | In situ: 32.8% Localized: 45.7% Regional: 8.5% Distant: 3.0% Unknown: 10.0% | NR | Kaplan-Meier product limit Cox proportional hazards | Census tract median income, race/ethnicity, age, sex, marital status, years of diagnosis (1988–1993, 1994–1999), stage, tumor thickness, histology, site, and comorbidity (Charlson score of 0, 1, or 2+) | In situ: Referent Localized: 8.83 (6.0–12.9) Regional: 23.2 (15.7–34.3) Distant: 94.0 (63.3–139.5) Unknown: 19.1(13.1–27.8)

Abbreviations: KQ = key question; HR = hazard ratio; CI = confidence interval; SEER = Surveillance, Epidemiology, and End Results Program; NR = not reported; AJCC = American Joint Committee on Cancer; SES = socioeconomic status.

Table 9 Association Between Breslow Lesion Thickness of Melanoma at Diagnosis and Melanoma Mortality (KQ 5)

Study, Year Quality Country | N | % Female Age | Distribution of Breslow Thickness (mm) at Detection | Melanoma Deaths (n) | Primary Analysis | Confounders for Adjustment | Melanoma-Related Mortality Adjusted HR^*^ (95% CI)
Marashi-Pour, 2012^68^ Good Australia 1988–2007 | 52,330 | 42% female <40: 7,813 (15%) 40–69: 28,132 (54%) ≥70: 16,374 (31%) Missing: 11 (0%) | ≤1: 61% 1.01–2: 16% 2.01–4: 10% ≥4.01: 6% Missing: 7% | 5,291 melanoma deaths (13,581 from all causes) | Fine and Gray competing risk regression with backward modeling | Sex, age at diagnosis, histological type, body site, year and season of diagnosis, tumor thickness, and degree of spread at diagnosis | ≤1.0 mm: Referent 1.01–2.0 mm: 4.13 (3.74–4.56) 2.01–4.0 mm: 6.88 (6.18–7.65) ≥4.01 mm: 9.52 (8.42–10.77) Missing: 6.37 (5.57–7.29)
Green, 2012^69^ Fair Australia 1982–2006 | 26,736 | 46.4% female Mean age: 52.7 | <0.25: 2,372 (8.9%) 0.25–0.49: 11,552 (43.2%) 0.50–0.74: 8,366 (31.3%) 0.75–1.00: 4,446 (16.6%) | Total: 592 <0.25: 24 (4.1%) 0.25–0.49: 127 (21.5%) 0.50–0.74: 174 (29.4%) 0.75–1.00: 267 (45.1%) | Multivariate Cox proportional hazard models | Year, sex, time after diagnosis, sex^*^time after diagnosis (interaction), age group, site, level, morphology | <0.25 mm: Referent 0.25–0.49 mm: 1.14 (0.7–1.7) 0.50–0.74 mm: 1.84 (1.2–2.9) 0.75–1.00 mm: 4.33 (2.8–6.8)
Pollack, 2011^65^ Good U.S. (13 SEER regions) 1992–2006 | 68,495 | 45.1% female <40: 19.5% 40–64: 48.9% ≥65y: 31.5% | 0.01–1.00: 59.8% 1.01–2.00: 13.9% 2.01–4.00: 7.6% >4: 4.3% Unknown: 13.7% No tumor found: 0.7% | NR | Cox regression restricted to 5- year followup. 56,886 cases of 68,495 in multivariate analyses (missing data) | Stratified on histologic subtype and anatomic site. Adjusted for sex, age at diagnosis, race/ethnicity, stage, and depth | ≤1.0 mm: Referent 1.01–2.0 mm: 2.89 (2.62–3.18) 2.01–4.0 mm: 4.69 (4.24–5.02) >4.0 mm: 5.71 (5.10–6.39) No tumor found: 3.03 (1.98–4.64)
Reyes-Ortiz, 2006^63^ Fair U.S. (11 SEER regions) 1988–1999 to 2000 | 23,068 | 40% female <39: 0 (0%) 40–64: 0 (0%) ≥65: 23,068 (100%) | <1.00: 30.7% 1.01–2.00: 8.8% 2.01–4.00: 6.6% >4.00: 3.9% Unknown: 50.0% | NR | Kaplan-Meier product limit Cox proportional hazards | Census tract median income, race/ethnicity, age, sex, marital status, years of diagnosis (1988–1993, 1994–1999), stage, tumor thickness, histology, site, and comorbidity (Charlson score of 0, 1, or 2+) | ≤1.00 mm: Referent 1.01–2.0 mm: 2.06 (1.69–2.50) 2.01–4.0 mm: 3.11 (2.57–3.76) >4.0 mm: 3.17 (2.56–3.92) Unknown: 2.05 (1.70–2.47)
Leiter, 2004^70^ Fair Germany 1976–2000 | 12,728 | 59% female Mean age: 50 (SD, 15.7) | ≤0.25: 8.4% 0.26–0.50: 36.3% 0.51–0.75: 29.7% 0.76–1.00: 25.6% | 162 | Multivariate Cox proportional hazard models | Adjusted by age, sex, Breslow tumor thickness, Clark level of invasion, ulceration, regression, histologic subtypes, and body sites | ≤0.50 mm: Referent 0.51–0.75 mm: 1.9 (1.2–2.9) 0.76–1.00 mm: 3.9 (2.6–5.8)
Luke, 2003^67,†^ Fair Australia 1980–2000 | 9,519 | 50% female <39: 1,999 (21%) 40–69: 5,015 (53%) ≥70: 2,505 (26%) | ≤0.50: 35.1% 0.51–1.00: 31.8% 1.01–1.50: 11.1% 1.51–2.00: 5.9% 2.01–2.50: 3.9% 2.51–3.00: 2.7% 3.01–3.50: 1.9% 3.51–4.00: 1.8% 4.01–4.50: 1.9% 4.51–5.00: 1.2% 5.01–5.50: 0.5% 5.51–6.00: 0.8% ≥6.01: 1.4% | NR | Cox proportional hazard regression (relative risk of case fatality) | Diagnostic period, Breslow thickness, Clark level, body site, age at diagnosis, and sex | ≤0.50 mm: Referent 0.51–1.00 mm: 2.81 (1.81–4.35) 1.01–1.50 mm: 6.18 (3.75–10.20) 1.51–2.00 mm: 8.53 (5.05–14.43) 2.01–2.50 mm: 13.89 (8.16–23.64) 2.51–3.00 mm: 15.44 (8.90–26.80) 3.01–3.50 mm: 20.74 (11.83–36.34) 3.51–4.00 mm: 27.39 (15.71–47.73) 4.01–4.50 mm: 32.62 (18.78–56.63) 4.51–5.00 mm: 21.09 (11.38–39.09) 5.01–5.50 mm: 22.1 (10.62–45.99) 5.51–6.00 mm: 33.99 (18.13–63.73) ≥6.01: 23.08 (12.70–41.95)
Owen, 2001^66^ Fair U.S. 1970–1995 | 4,560 | 46% female Mean age at surgery: 48.3 (14.2) | <0.75: 10.5% 0.75–1.0: 13.2% 1.0–1.5: 26.1% 1.5–3.0: 32.8% 3.0–4.0: 7.3% >4.0: 10.0% | 867 | Cox proportional hazards | Age, sex, and site of primary lesion | ≤0.75 mm: 0.28 (0.17–0.44) 0.75–1.0 mm: 0.55 (0.4–0.76) 1.0–1.5 mm: Referent 1.5–3.0 mm: 1.93 (1.6–2.34) 3.0–4.0 mm: 3.02 (2.37–3.86) >4.0 mm: 3.88 (3.12–4.83)

* Leiter 2004 and Owen 2001 reported relative risks, not hazard ratios.

† Missing data n=1,103; percentages based off of n=8,416.

Abbreviations: KQ = key question; HR = hazard ratio; CI = confidence interval; SEER = Surveillance, Epidemiology, and End Results Program; NR = not reported; SD = standard deviation.

Table 10 Association Between Melanoma AJCC Stage and All-Cause Mortality (KQ 5)

Study, Year Quality Country | Dates of Data Collection | N | Age % Female | All-Cause Deaths | Primary Analysis | Adjustment Variables | All-Cause Mortality HR (95% CI)
Zell, 2008^64^ Good California, U.S. | 1993–2003 | 39,049 | Median: 58 years (95% CI, 29.0–84.0) 43.1% | 6,706 | Cox proportional hazard ratio | Age, sex, race/ethnicity, AJCC stage, histologic subtype, anatomic tumor site, surgery stage, SES quintile, radiation therapy, chemotherapy, and immunotherapy | I: Referent II: HR, 2.26 (95% CI, 2.14–2.39) III: HR, 4.27 (95% CI, 3.9–4.67) IV: HR, 10.39 (95% CI, 8.96–12.0)

Abbreviations: AJCC = American Joint Committee on Cancer; KQ = key question; HR = hazard ratio; CI = confidence interval; SES = socioeconomic status.

All studies demonstrated a consistent linear increase in risk of melanoma mortality with increasing tumor thickness or stage, regardless of categorization. Tumor thickness larger than 4.0 mm was associated with a 3.1 to 32.6 increased risk of melanoma mortality compared to thinner lesions in multivariate-adjusted models. In the largest study of 68,495 melanoma cases diagnosed from 1992 to 2006 and identified through 13 SEER registries, each 1.0-mm increase in tumor thickness was associated with a subsequent increase in melanoma mortality. Compared to thin lesions (<1 mm), increased risk of melanoma mortality by thickness were: 2.89 (95% CI, 2.62 to 3.18) for tumors 1.01 to 2.00 mm; 4.69 (95% CI, 4.24 to 5.02) for tumors 2.01 to 4.00 mm; and 5.71 (95% CI, 5.10 to 6.39) for tumors larger than 4.00 mm. Using the same study population and categorizing by SEER summary stage, tumors in the distant stage were associated with an 18.66-fold increased risk of melanoma mortality compared to localized disease. Finally, results in a cohort of 39,049 California residents with a diagnosis of melanoma demonstrated that late stage at diagnosis was associated with a 10.4-fold increased risk of all-cause mortality in adjusted hazard ratio (HR) models.

### Detailed Results

#### Stage at Diagnosis and Melanoma Mortality

Three fair- to good-quality cohort studies evaluated the association between stage at diagnosis and melanoma mortality and also reported measures of risk of melanoma death according to stage at diagnosis using either AJCC or SEER stages (Table 8). The three studies had similar consistent, linear results.63-65 In one study that used AJCC stage I disease as the comparison, stage II melanoma had a 4.96-fold increased relative risk of mortality (95% CI, 4.51 to 5.56); stage III melanoma had a 9.99-fold increased relative risk (95% CI, 8.84 to 11.29); and stage IV melanoma had a 27.1-fold increased relative risk (95% CI, 22.4 to 32.8).64

Two studies used the SEER stages of local, regional, distant, and unknown.63, 65 One study used in situ melanoma as the reference category. Two study populations potentially overlap but likely minimally. One study evaluated 13 SEER regions from 1992 to 2006 for all ages. The second study used SEER-Medicare data from 11 SEER regions from 1988 to 2000. Using in situ melanoma as the reference category, the HR of risk of melanoma death was 8.83 (localized), 23.2 (regional), and 94.0 (distant).63 Using localized stage as the reference category, risk of melanoma death was 3.62 for regional and 18.66 for distant.65 All estimates in the three studies reached statistical significance.

#### Lesion Thickness at Diagnosis and Melanoma Mortality

Seven studies using tumor thickness as a main exposure found that the risk of melanoma death increased linearly with increasing tumor thickness at diagnosis (Table 9).63, 65-70 Reference categories ranged from 0.25 mm or smaller to 1.0 mm or smaller. Maximum tumor thickness categories ranged from 1.0 mm to 6 mm or larger.

Because of changes in reference category, actual estimates of melanoma mortality varied. In three studies using tumor thickness of 1.0 mm or smaller as the reference category and risk groups consistent with the AJCC staging system,49 HR risk of melanoma death for a tumor thickness of 1.01 to 2.00 mm ranged from 2.06^63^ to 4.13.^68^ Tumors with a thickness of 2.01 to 4.00 mm had risk of melanoma death ranging from 3.11^63^ to 6.88.^68^ Tumors with a thickness larger than 4.0 mm reported associated risks of 5.71^65^ and 9.52.^68^ In two studies using a lesion thickness of 0.50 mm or smaller as the reference category, risk estimates increased with increasing lesion thickness, from 3.9 for thickness of 0.76 to 1.0 mm to 23.08 for thickness larger than 6.0 mm.70 One study used lesion thickness of 1 to 1.5 mm as the reference category and found incrementally decreasing risk of melanoma mortality for tumors 0.75 to 1.00 mm (RR, 0.55) and 0.75 mm or smaller (RR, 0.28), and risk increasing to 3.88 for tumors larger than 4.00 mm.66

#### Stage at Diagnosis and All-Cause Mortality

We identified one good-quality study that evaluated the association between stage at melanoma diagnosis and all-cause mortality (Table 10). A study of 39,049 California residents with a median age of 58.0 years (95% CI, 29 to 84) who were diagnosed with melanoma from 1993 to 2003 found increased HR of all-cause mortality was associated with increased melanoma stage at detection, with estimates of 2.26 (95% CI, 2.14 to 2.39) for stage II melanoma, 4.27 (95% CI, 3.90 to 4.67) for stage III melanoma, and 10.39 (95% CI, 8.96 to 12.0) for stage IV melanoma, compared to stage I disease.64