# Methods

## Scope and Purpose

This systematic review was designed to update the prior 2009 review on the effectiveness of skin cancer screening in average-risk persons. For this review, we adapted the previous analytic framework and key questions (KQs) to address the benefits and harms of primary care screening for skin cancer. Since our review was focused on visual skin cancer screening within primary care settings, skin self-examination was considered to be outside the scope of this review.

## Analytic Framework and KQs

Using USPSTF methods (detailed in Appendix A), we developed an analytic framework (Figure 1) and five KQs:

1. What is the direct evidence that visual skin cancer screening by a primary care provider or dermatologist reduces skin cancer morbidity and mortality and all-cause mortality?
2. What are the harms of skin cancer screening and diagnostic followup?
3. What are the test characteristics of visual skin cancer screening when performed by primary care providers versus dermatologists?
4. Does visual skin cancer screening lead to earlier detection of skin cancer compared to usual care?
5. What is the association between earlier detection of skin cancer and skin cancer morbidity and mortality and all-cause mortality?

Figure 1 Analytic Framework

Abbreviations: AK = actinic keratosis; BCC = basal cell carcinoma; SCC = squamous cell carcinoma.

Figure 1 is an analytic framework that depicts the five Key Questions (KQs) described in the Methods section. Specifically, it illustrates the following questions: whether visual skin cancer screening by a primary care provider or dermatologist reduces skin cancer morbidity and mortality and all-cause mortality (KQ 1), the harms of skin cancer screening and diagnostic followup (KQ 2), the test characteristics of visual skin cancer screening performed by primary care providers vs. dermatologists (KQ 3), whether visual skin cancer screening leads to earlier detection of skin cancer compared to usual care (KQ 4), and the association between earlier detection of skin cancer and skin cancer morbidity and mortality and all-cause mortality.

## Data Sources and Searches

We designed the review to be an extension of the 2009 systematic review.47 The literature search for this systematic review covered MEDLINE, PubMed, and the Cochrane Central Register of Controlled Trials for studies published from January 1, 1995 through June 1, 2015. We worked with a medical librarian to develop our search strategy (Appendix A) and all searches were limited to English-language articles. We managed literature search results using version X5 of EndNote (Thomson Reuters, Philadelphia, PA), a bibliographic management software database, and an Access database (Microsoft, Redmond, WA).

To ensure comprehensiveness, we reviewed the reference lists of included studies, systematic reviews, and meta-analyses to identify relevant articles published before or not identified in our literature searches. We also supplemented our database searches with suggestions from experts and searched Clinicaltrials.gov to identify relevant ongoing trials (Appendix B).

All reviewed abstracts and full-text articles that might contain references of interest were marked, and references were assessed by the team. Articles identified through reference lists are included in the literature flow diagram (Appendix A Figure 1) as “identified through other sources.” Articles that were not already identified in the original search results were evaluated using the inclusion/exclusion criteria described above.

## Study Selection

We developed an a priori set of inclusion and exclusion criteria (Appendix A Table 1). Two researchers independently reviewed 12,514 unique titles and abstracts to determine if the studies met the inclusion or exclusion criteria for design, population, intervention, and outcomes. We then reviewed the 453 full-text potentially relevant articles for inclusion using dual review. We resolved disagreements by consultation and consensus with a third reviewer, if necessary. We excluded articles that did not meet the inclusion criteria or were rated as poor quality, as described below. Excluded studies are listed in Appendix C. Systematic reviews were reviewed to identify potential included articles.

We included studies of asymptomatic adolescents and adults age 15 years and older. Included studies were required to be fair to good quality and conducted in countries with a United Nations Human Development Index score of 0.9 or greater.48 We excluded studies that focused on nonskin cancers, populations under surveillance because of prior skin cancer diagnosis, skin self-screening or partner screening, intermediate or health outcomes relating clinician skin examination to other risk factors (e.g., sun protective behaviors), or measures of doctor-patient relationship quality.

For effectiveness and harms studies (KQs 1–4), acceptable screening tests were defined as whole or partial visual skin examination conducted by primary care providers (or related mid-level staff) or dermatologists with or without tools to aid examination (e.g., dermatoscopy, whole body photography). We excluded screening studies that focused on skin examinations in response to patient concerns for suspicious lesions, skin self-screening by individuals or partners, or physician counseling for self-screening. For studies focusing on morbidity and mortality (KQs 1 and 5), we reviewed studies that investigated skin cancer mortality, all-cause mortality, or morbidity associated with any skin cancer (including melanoma in situ, dysplastic nevi, and actinic keratosis), including quality of life. For test characteristic studies (KQ 3), we included studies that assessed cancer outcomes through cancer registry–based systems or pathology/biopsy reports within a defined period postscreening examination, and estimated false-negative rates for melanoma detection in participants who screened negative. For studies on early detection of skin cancer (KQs 4 and 5), we included studies that evaluated either American Joint Committee on Cancer (AJCC) stage49 or Breslow lesion thickness at diagnosis.

We evaluated trials, cohort studies, other observational studies, and ecologic studies that reported clinical outcomes and included case series or case reports for identifications of harms in KQ 2.

## Quality Assessment and Data Abstraction

Two reviewers independently appraised all articles that met the inclusion criteria for this review as good, fair, or poor quality. Appraisal criteria were adapted from the USPSTF design-specific quality criteria (Appendix A Table 2). The final quality rating in the evidence tables is based on a combination of criteria adapted from the USPSTF methods,50 Dufault 2011,^51^ and Tu 2008.^52^ In general, a good-quality study met all criteria well. A fair-quality study did not clearly meet at least one criterion but had no known issues that would invalidate its results. Poor-quality studies had severe limitations, including one or more of the following risks of bias: unclear study population, unclear screening strategy, lack of defined followup, and lack of accounting for confounders or reporting of baseline characteristics.

Four researchers extracted data from all included studies rated as fair to good quality into evidence tables. A second reviewer checked the data for accuracy. The reviewers abstracted study characteristics (e.g., population, purpose, exposure, and outcomes), study design elements (e.g., recruitment procedures, inclusion/exclusion criteria, followup duration and attrition), outcomes for screening studies (e.g., true positives, diagnostic yield, positive predictive value), health outcomes (e.g., skin cancer morbidity and mortality), and harms.

## Data Synthesis and Analysis

For the body of evidence defined by the KQs, we created summary evidence tables to capture key study characteristics and sources of heterogeneity (e.g., study quality, sample size, geographic location, age, and sex). Further, for each KQ, we present results summarized qualitatively in the absence of data available to pool across studies.

## Expert Review and Public Comment

A draft research plan that included the analytic framework, KQs, and inclusion criteria was available for public comment from May 15 to June 11, 2014. We made no substantive changes to our review methods based on comments received. A draft version of this report was reviewed by four invited content experts and federal partners from the Centers for Disease Control and Prevention, Centers for Medicare & Medicaid Services, National Institutes of Health, Veterans Health Administration, and the Military Health Service. Comments received during this process were presented to the USPSTF during its deliberation of the evidence and were addressed in the final version of the report. Additionally, a draft of the full report was posted on the USPSTF Web site from November 30 to December 28, 2015. A few comments were received during this public comment period. We made clarifications and additions to the Introduction and Discussion sections to incorporate important points noted by commenters.

## USPSTF Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to refine inclusion criteria, address methodological decisions on applicable evidence, and resolve issues around scope for the final evidence synthesis. The Agency for Healthcare Research and Quality funded this research under a contract to support USPSTF work. Agency staff provided oversight for the project and assisted in external review of the draft evidence report.