# Additional Tables

Appendix D Table 1 Melanoma Mortality Associated With Visual Skin Cancer Screening in Men (KQ 1)

Katalinic, 2012^53^ Fair | Total Population 2009 (Millions) | Prescreening (1998–1999) Melanoma Deaths (n) | Prescreening (1998–1999) WASR (95% CI) | Screening Program (2003–2004) Melanoma Deaths (n) | Screening Program (2003–2004) WASR (95% CI) | Postscreening (2008–2009) Melanoma Deaths (n) | Postscreening (2008–2009) WASR (95% CI)
Intervention region
Schleswig-Holstein (360,288 persons screened) | 1.39 | 42 | 1.9 (1.5–2.4) | 43 | 1.6 (1.2–1.9) | 28 | 1.0 (0.7–1.3)
Comparison regions
South: Hamburg | 0.87 | 19 | 1.3 (0.9–1.8) | 29 | 2.0 (1.5–2.5) | 24 | 1.4 (1.0–1.8)
West: Lower-Saxony | 3.90 | 112 | 1.7 (1.5–1.9) | 123 | 1.8 (1.5–2.0) | 151 | 2.0 (1.8–2.3)
East: Mecklenburg-Vorpommern | 0.82 | 15 | 1.1 (0.7–1.5) | 23 | 1.6 (1.1–2.2) | 28 | 1.6 (1.2–2.1)
North: Denmark | 2.74 | 117 | 2.9 (2.4–3.3) | 118 | 2.7 (2.4–3.1) | 150 | 3.2 (2.8–3.5)
Germany^*^ | 38.8 | 1,000 | 1.6 (1.6–1.7) | 1,229 | 1.8 (1.7–1.9) | 1,382 | 1.8 (1.7–1.9)

* Excludes Schleswig-Holstein region.

Abbreviations: CI = confidence interval; KQ = key question; WASR = world age-standardized morality rate (per 100,000).

Appendix D Table 2 Melanoma Mortality Associated With Visual Skin Cancer Screening in Women (KQ 2)

Katalinic, 2012^53^ Fair | Total Population 2009 (Millions) | Prescreening (1998–1999) Melanoma Deaths (n) | Prescreening (1998–1999) WASR (95% CI) | Screening Program (2003–2004) Melanoma Deaths (n) | Screening Program (2003–2004) WASR (95% CI) | Postscreening (2008–2009) Melanoma Deaths (n) | Postscreening (2008–2009) WASR (95% CI)
Intervention region
Schleswig-Holstein (360,288 persons screened) | 1.44 | 45 | 1.4 (1.1–1.8) | 39 | 1.3 (0.9–1.6) | 22 | 0.7 (0.5–1.0)
Comparison regions
South: Hamburg | 0.91 | 22 | 1.2 (0.8–1.6) | 23 | 1.1 (0.7–1.4) | 23 | 1.1 (0.7–1.5)
West: Lower-Saxony | 4.04 | 112 | 1.3 (1.1–1.4) | 116 | 1.2 (1.0–1.4) | 102 | 1.1 (0.9–1.3)
East: Mecklenburg-Vorpommern | 0.84 | 17 | 0.8 (0.5–1.2) | 20 | 1.0 (0.6–1.3) | 23 | 1.1 (0.7–1.5)
North: Denmark | 2.79 | 86 | 1.8 (1.5–2.1) | 103 | 1.8 (1.5–2.1) | 103 | 1.9 (1.6–2.1)
Germany^*^ | 40.3 | 940 | 1.1 (1.0–1.1) | 984 | 1.1 (1.0–1.1) | 1,148 | 1.2 (1.1–1.2)

* Excludes Schleswig-Holstein region.

Abbreviations: CI = confidence interval; KQ = key question; WASR = world age-standardized morality rate (per 100,000).

Appendix D Table 3 Impact of Screening on Detection of Melanoma in Situ, Squamous Cell Carcinoma, and Basal Cell Carcinoma

Study Year Quality Location | N Screened | Age-Adjusted Incidence Rates per 100,000 (95% CI) | In situ Melanoma | Malignant Melanoma | In situ SCC | SCC | BCC
Breitbart 2012^55^ Good Schleswig-Holstein, Germany | 360,288 | Baseline (2001–2003) | 5.8 (5.2–6.4) | 14.2 (13.3–15.1) | 6.7 (6.3–7.2) | 11.2 (10.6–11.8) | 60.5 (59.0–62.1)
Breitbart 2012^55^ Good Schleswig-Holstein, Germany | 360,288 | SCREEN (2003–2004) | 8.5 (7.5–9.5) | 18.0 (16.6–19.4) | 8.8 (8.1–9.6) | 12.9 (12.0–13.8) | 78.4 (75.9–80.8)
Breitbart 2012^55^ Good Schleswig-Holstein, Germany | 360,288 | % change | 48% increase | 27% increase | 31% increase | 15% increase | 29% increase

Abbreviations: CI = confidence interval; SCC = squamous cell carcinoma; BCC = basal cell carcinoma; SCREEN = Skin Cancer Research to Provide Evidence for Effectiveness of Screening in Northern Germany.