# Excluded Studies

Code | Reason for Exclusion
E1 | Not English
E2 | Not original research in a peer-reviewed journal
E3 | Publication date not 1995-present
E4 | Ineligible SETTING (a) non-generalizable to primary care; (b) low HDI country
E5 | Ineligible POPULATION
E6 | Ineligible OUTCOMES
E7 | Ineligible screening strategy
E8 | Ineligible treatment
E9 | Ineligible study design
E10 | Study rated as poor quality
E11 | Overlapping study population
E12 | N/A

Abbreviations: HDI = Human Development Index, N/A = not applicable.

1 Screening for melanoma. Med Lett Drugs Ther. 2011;53(1372):72. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21897350].
2 Do I need an annual skin check to screen for cancer?. Mayo Clin Womens Healthsource. 2009;13(6):8. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 19415051].
3 New tools aid in diagnosing and detecting skin cancer in earliest stages. Dermatol Nurs. 2009;21(4):222-3. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 19691242].
4 Early detection of melanoma plus regular skin exams is vital for beating disease. Dermatol Nurs. 2009;21(6):363-4. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 20102024].
5 How to decrease morbidity and mortality of skin cancer: primary prevention of skin cancer/screening of skin cancer. Report of a workshop held under the auspices of the Society of Dermatological Prevention (ADP e.V.), Commission of Early Detection and Prevention of Skin Cancer. 11 May 1994, Hamburg, Germany. Eur J Cancer Prev. 1996;5(4):297-9. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 8894567].
6 Abbas Q, Celebi ME, Fondon I. Computer-aided pattern classification system for dermoscopy images. Skin Res Technol. 2012;18(3):278-89. KQ3E9. [pmid: 22093020].
7 Abbas Q, Garcia IF, Emre Celebi M, et al. Unified approach for lesion border detection based on mixture modeling and local entropy thresholding. Skin Res Technol. 2013;19(3):314-9. KQ3E9. [pmid: 23573804].
8 Abbas Q, Garcia IF, Rashid M. Automatic skin tumour border detection for digital dermoscopy using a new digital image analysis scheme. Br J Biomed Sci. 2010;67(4):177-83. KQ3E4. [pmid: 21294444].
9 Affleck AG, Varma S. A case of do-it-yourself Mohs' surgery using bloodroot obtained from the internet. Br J Dermatol. 2007;157(5):1078-9. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17854372].
10 Aitken JF, Elwood JM, Lowe JB, et al. A randomised trial of population screening for melanoma. J Med Screen. 2002;9(1):33-7. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 11943795].
11 Aitken JF, Youl PH, Janda M, et al. Increase in skin cancer screening during a community-based randomized intervention trial. Int J Cancer. 2006;118(4):1010-6. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 16152577].
12 Alam M, Ratner D. Cutaneous squamous-cell carcinoma. N Engl J Med. 2001;344(13):975-83. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 11274625].
13 Aldridge RB, Naysmith L, Ooi ET, et al. The importance of a full clinical examination: assessment of index lesions referred to a skin cancer clinic without a total body skin examination would miss one in three melanomas. Acta Derm Venereol. 2013;93(6):689-92. KQ2E5, KQ3E5. [pmid: 23695107].
14 Altamura D, Menzies SW, Argenziano G, et al. Dermatoscopy of basal cell carcinoma: morphologic variability of global and local features and accuracy of diagnosis. J Am Acad Dermatol. 2010;62(1):67-75. KQ3E7. [pmid: 19828209].
15 Amrock SM, Meydani A. Trends and disparities in total-body skin examination: evaluating the National Health Interview Survey, 2000-2010. JAMA Dermatol. 2013;149(3):363-4. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 23552730].
16 Andersson AP, Dahlstrom KK, Drzewiecki KT. Prognosis of thin cutaneous head and neck melanoma (<1mm). Eur J Surg Oncol. 1996;22(1):55-7. KQ5E6. [pmid: 8846868].
17 Andersson TM, Eriksson H, Hansson J, et al. Estimating the cure proportion of malignant melanoma, an alternative approach to assess long term survival: a population-based study. Cancer Epidemiol. 2014;38(1):93-9. KQ5E6. [pmid: 24447700].
18 Andreeva VA, Cockburn MG. Cutaneous melanoma and other skin cancer screening among Hispanics in the United States: a review of the evidence, disparities, and need for expanding the intervention and research agendas. Arch Dermatol. 2011;147(6):743-5. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 21690545].
19 Annessi G, Bono R, Sampogna F, et al. Sensitivity, specificity, and diagnostic accuracy of three dermoscopic algorithmic methods in the diagnosis of doubtful melanocytic lesions: the importance of light brown structureless areas in differentiating atypical melanocytic nevi from thin melanomas. J Am Acad Dermatol. 2007;56(5):759-67. KQ3E7. [pmid: 17316894].
20 Anzai S, Anan T, Kai Y, et al. Skin cancer screening on a fishing island and in an inland agricultural area of Japan. J Dermatol. 2005;32(11):875-82. KQ1E6, KQ2E6, KQ3E9, KQ4E9, KQ5E6. [pmid: 16361747].
21 Argenziano G, Puig S, Zalaudek I, et al. Dermoscopy improves accuracy of primary care physicians to triage lesions suggestive of skin cancer. J Clin Oncol. 2006;24(12):1877-82. KQ3E7. [pmid: 16622262].
22 Argenziano G, Zalaudek I, Hofmann-Wellenhof R, et al. Total body skin examination for skin cancer screening in patients with focused symptoms. J Am Acad Dermatol. 2012;66(2):212-9. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 21757257].
23 Augustin M, Stadler R, Reusch M, et al. Skin cancer screening in Germany - perception by the public. J Dtsch Dermatol Ges. 2012;10(1):42-9. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 21923730].
24 Austin JR, Byers RM, Brown WD, et al. Influence of biopsy on the prognosis of cutaneous melanoma of the head and neck. Head Neck. 1996;18(2):107-17. KQ2E5. [pmid: 8647675].
25 Averbook BJ, Fu P, Rao JS, et al. A long-term analysis of 1018 patients with melanoma by classic Cox regression and tree-structured survival analysis at a major referral center: Implications on the future of cancer staging. Surgery. 2002;132(4):589-602. discussion 602-4. KQ5E6. [pmid: 12407342].
26 Averbook BJ, Lee SJ, Delman KA, et al. Pediatric melanoma: analysis of an international registry. Cancer. 2013;119(22):4012-9. KQ5E6. [pmid: 24022819].
27 Averbook BJ, Russo LJ, Mansour EG. A long-term analysis of 620 patients with malignant melanoma at a major referral center. Surgery. 1998;124(4):746-55. discussion 755-6. KQ5E6. [pmid: 9780997].
28 Azzarello LM, Jacobsen PB. Factors influencing participation in cutaneous screening among individuals with a family history of melanoma. J Am Acad Dermatol. 2007;56(3):398-406. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 17184873].
29 Baade P, Coory M. Trends in melanoma mortality in Australia: 1950-2002 and their implications for melanoma control. Aust N Z J Public Health. 2005;29(4):383-6. KQ1E13. [pmid: 16222938].
30 Baade P, Meng X, Youlden D, et al. Time trends and latitudinal differences in melanoma thickness distribution in Australia 1990-2006. Int J Cancer. 2012;130(1):170-8. KQ4E7. [pmid: 21344376].
31 Badertscher N, Meier M, Rosemann T, et al. The role of skin self-examination at the Swiss skin cancer day. BMC Health Serv Res. 2014;14:581. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7. [pmid: 25408258].
32 Baehner FL, Li R, Jenkins T, et al. The impact of primary melanoma thickness and microscopic tumor burden in sentinel lymph nodes on melanoma patient survival. Ann Surg Oncol. 2012;19(3):1034-42. KQ5E7. [pmid: 21989664].
33 Bafounta ML, Beauchet A, Aegerter P, et al. Is dermoscopy (epiluminescence microscopy) useful for the diagnosis of melanoma? Results of a meta-analysis using techniques adapted to the evaluation of diagnostic tests. Arch Dermatol. 2001;137(10):1343-50. KQ3E13. [pmid: 11594860].
34 Balch CM, Soong SJ, Gershenwald JE, et al. Prognostic factors analysis of 17,600 melanoma patients: validation of the American Joint Committee on Cancer melanoma staging system. J Clin Oncol. 2001;19(16):3622-34. KQ5E6. [pmid: 11504744].
35 Balch CM, Soong SJ, Smith T, et al. Long-term results of a prospective surgical trial comparing 2 cm vs. 4 cm excision margins for 740 patients with 1-4 mm melanomas. Ann Surg Oncol. 2001;8(2):101-8. KQ2E5, KQ5E6. [pmid: 11258773].
36 Balch CM, Soong S, Ross MI, et al. Long-term results of a multi-institutional randomized trial comparing prognostic factors and surgical results for intermediate thickness melanomas (1.0 to 4.0 mm). Intergroup Melanoma Surgical Trial. Ann Surg Oncol. 2000;7(2):87-97. KQ5E6. [pmid: 10761786].
37 Baldwin BT, Cherpelis BS, Sondak V, et al. Sentinel lymph node biopsy in melanoma: Facts and controversies. Clin Dermatol. 2010;28(3):319-23. KQ2E2, KQ6. [pmid: 20541686].
38 Bambara M, Magnano M, Castelli G, et al. 0109 Study on diseases of the skin in an industrial population of a petrochemical site in Sicily. Occup Environ Med. 2014:A74. KQ1E6.
39 Banky JP, Kelly JW, English DR, et al. Incidence of new and changed nevi and melanomas detected using baseline images and dermoscopy in patients at high risk for melanoma. Arch Dermatol. 2005;141(8):998-1006. KQ1E7. [pmid: 16103329].
40 Barzegari M, Ghaninezhad H, Mansoori P, et al. Computer-aided dermoscopy for diagnosis of melanoma. BMC Dermatol. 2005;5:8. KQ3E4. [pmid: 16000171].
41 Barzilai DA, Cooper KD, Neuhauser D, et al. Geographic and patient variation in receipt of surveillance procedures after local excision of cutaneous melanoma. J Invest Dermatol. 2004;122(2):246-55. KQ2E5. [pmid: 15009702].
42 Bataille V. Early detection of melanoma improves survival. Practitioner. 2009;253(1722):29-32. 3. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 19938560].
43 Bauer AM. Current trends of surgical management of head and neck carcinomas. Nurs Clin North Am. 2001;36(3):501-6. x. KQ2E2. [pmid: 11532664].
44 Bauer P, Cristofolini P, Boi S, et al. Digital epiluminescence microscopy: usefulness in the differential diagnosis of cutaneous pigmentary lesions. A statistical comparison between visual and computer inspection. Melanoma Res. 2000;10(4):345-9. KQ3E13. [pmid: 10985668].
45 Bello DM, Chou JF, Panageas KS, et al. Prognosis of acral melanoma: a series of 281 patients. Ann Surg Oncol. 2013;20(11):3618-25. KQ5E6. [pmid: 23838913].
46 Benelli C, Roscetti E, Pozzo VD, et al. The dermoscopic versus the clinical diagnosis of melanoma. Eur J Dermatol. 1999;9(6):470-6. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 10491506].
47 Bennassar A, Ishioka P, Vilalta A. Surgical treatment of primary melanoma. Dermatol Ther. 2012;25(5):432-42. KQ2E7. [pmid: 23046022].
48 Ben-Porat L, Panageas KS, Hanlon C, et al. Estimates of stage-specific survival are altered by changes in the 2002 American Joint Committee on Cancer staging system for melanoma. Cancer. 2006;106(1):163-71. KQ5E6. [pmid: 16331596].
49 Berwick M, Armstrong BK, Ben-Porat L, et al. Sun exposure and mortality from melanoma. J Natl Cancer Inst. 2005;97(3):195-9. KQ1E7, KQ2E5, KQ3E5, KQ4E6, KQ5E7. [pmid: 15687362].
50 Beyeler M, Dummer R. Cutaneous melanoma: uncommon presentations. Clin Dermatol. 2005;23(6):587-92. KQ1E9, KQ2E6, KQ3E9, KQ4E9, KQ5E9. [pmid: 16325067].
51 Bhattacharyya N, Nayak VK. Survival outcomes for second primary head and neck cancer: a matched analysis. Otolaryngol Head Neck Surg. 2005;132(1):63-8. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 15632911].
52 Boi S, Cristofolini M, Micciolo R, et al. Incidence and mortality data from cutaneous melanoma in Trentino: registry-based study. J Cutan Med Surg. 2008;12(2):59-63. KQ1E7. [pmid: 18346401].
53 Bong JL, Perkins W. Shave excision of benign facial melanocytic naevi: a patient's satisfaction survey. Dermatol Surg. 2003;29(3):227-9. KQ2E5. [pmid: 12614413].
54 Bono A, Bartoli C, Cascinelli N, et al. Melanoma detection. A prospective study comparing diagnosis with the naked eye, dermatoscopy and telespectrophotometry. Dermatology. 2002;205(4):362-6. KQ3E5. [pmid: 12444332].
55 Bono A, Ferrari A. Early diagnosis remains the most reliable way to cure children with melanoma. Pediatr Blood Cancer. 2005;45(3):355. author reply 356. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 15809990].
56 Bono A, Tolomio E, Trincone S, et al. Micro-melanoma detection: a clinical study on 206 consecutive cases of pigmented skin lesions with a diameter < or = 3 mm. Br J Dermatol. 2006;155(3):570-3. KQ3E7. [pmid: 16911283].
57 Borden EC. Reducing primary melanoma mortality. Curr Oncol Rep. 2000;2(4):289-91. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 11122855].
58 Bordoni A, Leoni-Parvex S, Peverelli S, et al. Opportunistic screening strategy for cutaneous melanoma does not change the incidence of nodular and thick lesions nor reduce mortality: a population-based descriptive study in the European region with the highest incidence. Melanoma Res. 2013;23(5):402-7. KQ1E7, KQ5E7. [pmid: 23839077].
59 Boulos S, Fiala K, Butler DF. Free skin cancer screening provides access to care. J Am Acad Dermatol. 2012;67(4):787-8. KQ1E6, KQ2E6, KQ3E4, KQ4E6, KQ5E6. [pmid: 22980248].
60 Bourne P, Rosendahl C, Keir J, et al. BLINCK-A diagnostic algorithm for skin cancer diagnosis combining clinical features with dermatoscopy findings. Dermatol Pract Concept. 2012;2(2):202a12. KQ3E7. [pmid: 23785600].
61 Bowns IR, Collins K, Walters SJ, et al. Telemedicine in dermatology: a randomised controlled trial. Health Technol Assess. 2006;10(43):iii-iv. ix. xi. 1. 39. KQ3E7. [pmid: 17049140].
62 Bradford PT, Goldstein AM, McMaster ML, et al. Acral lentiginous melanoma: incidence and survival patterns in the United States 1986-2005. Arch Dermatol. 2009;145(4):427-34. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 19380664].
63 Brandt TP. Skin cancer screening. Med Clin North Am. 1996;80(1):99-114. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 8569303].
64 Breuninger H, Schlagenhauff B, Stroebel W, et al. Patterns of local horizontal spread of melanomas: consequences for surgery and histopathologic investigation. Am J Surg Pathol. 1999;23(12):1493-8. KQ2E6. [pmid: 10584702].
65 Brown JE, Butow PN, Culjak G, et al. Psychosocial predictors of outcome: time to relapse and survival in patients with early stage melanoma. Br J Cancer. 2000;83(11):1448-53. KQ5E6. [pmid: 11076652].
66 Bruce AJ, Brodland DG. Overview of skin cancer detection and prevention for the primary care physician. Mayo Clin Proc. 2000;75(5):491-500. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 10807078].
67 Brunner M, Veness MJ, Ch'ng S, et al. Distant metastases from cutaneous squamous cell carcinoma--analysis of AJCC stage IV. Head Neck. 2013;35(1):72-5. KQ5E6. [pmid: 22266877].
68 Buckley D, McMonagle C. Melanoma in primary care. The role of the general practitioner. Ir J Med Sci. 2014;183(3):363-8. KQ1E7, KQ3E5. [pmid: 24091614].
69 Buettner PG, Leiter U, Eigentler TK, et al. Development of prognostic factors and survival in cutaneous melanoma over 25 years: An analysis of the Central Malignant Melanoma Registry of the German Dermatological Society. Cancer. 2005;103(3):616-24. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 15630700].
70 Bulliard JL, Maspoli M, Panizzon RG, et al. Evaluation of the Euromelanoma skin cancer screening campaign: the Swiss experience. J Eur Acad Dermatol Venereol. 2008;22(3):365-6. KQ1E6, KQ2E6, KQ3E7, KQ4E6, KQ5E6. [pmid: 18269606].
71 Bursa V, Pizinger K, Solc J, et al. Our experience with operative treatment of malignant melanoma. Acta Chir Plast. 1996;38(1):21-3. KQ2E5. [pmid: 8771806].
72 Burton RC, Howe C, Adamson L, et al. General practitioner screening for melanoma: sensitivity, specificity, and effect of training. J Med Screen. 1998;5(3):156-61. KQ3E5, KQ4E6. [pmid: 9795877].
73 Butler JM. Playing detective. Assessing skin lesions in primary care. Adv Nurse Pract. 1997;5(8):41-3. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 9459955].
74 Carducci M, Betti R. Basal cell carcinoma: surgical margin detection using digital dermoscopy. Dermatol Surg. 2012;38(6):964-5. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 22642455].
75 Carli P, Balzi D, de Giorgi V, et al. Results of surveillance programme aimed at early diagnosis of cutaneous melanoma in high risk Mediterranean subjects. Eur J Dermatol. 2003;13(5):482-6. KQ1E5. [pmid: 14693495].
76 Carli P, Chiarugi A, De Giorgi V. Examination of lesions (including dermoscopy) without contact with the patient is associated with improper management in about 30% of equivocal melanomas. Dermatol Surg. 2005;31(2):169-72. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 15762209].
77 Carli P, De Giorgi V, Argenziano G, et al. Pre-operative diagnosis of pigmented skin lesions: in vivo dermoscopy performs better than dermoscopy on photographic images. J Eur Acad Dermatol Venereol. 2002;16(4):339-46. KQ2E6, KQ3E7. [pmid: 12224689].
78 Carli P, De Giorgi V, Chiarugi A, et al. Effect of lesion size on the diagnostic performance of dermoscopy in melanoma detection. Dermatology. 2003;206(4):292-6. KQ3E5. [pmid: 12771468].
79 Carli P, de Giorgi V, Chiarugi A, et al. Addition of dermoscopy to conventional naked-eye examination in melanoma screening: a randomized study. J Am Acad Dermatol. 2004;50(5):683-9. KQ3E5. [pmid: 15097950].
80 Carli P, De Giorgi V, Crocetti E, et al. Diagnostic and referral accuracy of family doctors in melanoma screening: effect of a short formal training. Eur J Cancer Prev. 2005;14(1):51-5. KQ3E7. [pmid: 15677895].
81 Carli P, De Giorgi V, Crocetti E, et al. Improvement of malignant/benign ratio in excised melanocytic lesions in the ‘dermoscopy era’: a retrospective study 1997-2001. Br J Dermatol. 2004;150(4):687-92. KQ3E5. [pmid: 15099364].
82 Carli P, De Giorgi V, Giannotti B. Dermoscopy as a second step in the diagnosis of doubtful pigmented skin lesions: how great is the risk of missing a melanoma?. J Eur Acad Dermatol Venereol. 2001;15(1):24-6. KQ2E6, KQ3E6. [pmid: 11451316].
83 Carli P, De Giorgi V, Giannotti B, et al. Skin cancer day in Italy: method of referral to open access clinics and tumor prevalence in the examined population. Eur J Dermatol. 2003;13(1):76-9. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 12609788].
84 Carli P, De Giorgi V, Massi D, et al. The role of pattern analysis and the ABCD rule of dermoscopy in the detection of histological atypia in melanocytic naevi. Br J Dermatol. 2000;143(2):290-7. KQ3E6. [pmid: 10951135].
85 Carli P, De Giorgi V, Nardini P, et al. Melanoma detection rate and concordance between self-skin examination and clinical evaluation in patients attending a pigmented lesion clinic in Italy. Br J Dermatol. 2002;146(2):261-6. KQ3E7. [pmid: 11903237].
86 Carli P, de Giorgi V, Palli D, et al. Preoperative assessment of melanoma thickness by ABCD score of dermatoscopy. J Am Acad Dermatol. 2000;43(3):459-66. KQ3E6. [pmid: 10954657].
87 Carli P, De Giorgi V, Palli D, et al. Dermatologist detection and skin self-examination are associated with thinner melanomas: results from a survey of the Italian Multidisciplinary Group on Melanoma. Arch Dermatol. 2003;139(5):607-12. KQ4E5. [pmid: 12756097].
88 Carli P, de Giorgi V, Salvini C, et al. The gold standard for photographing pigmented skin lesions for diagnostic purposes: contact versus distant imaging. Skin Res Technol. 2002;8(4):255-9. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 12423545].
89 Carli P, Ghigliotti G, Gnone M, et al. Baseline factors influencing decisions on digital follow-up of melanocytic lesions in daily practice: an Italian multicenter survey. J Am Acad Dermatol. 2006;55(2):256-62. KQ2E6, KQ3E6. [pmid: 16844508].
90 Carli P, Mannone F, De Giorgi V, et al. The problem of false-positive diagnosis in melanoma screening: the impact of dermoscopy. Melanoma Res. 2003;13(2):179-82. KQ2E5, KQ3E5. [pmid: 12690302].
91 Carli P, Massi D, de Giorgi V, et al. Clinically and dermoscopically featureless melanoma: when prevention fails. J Am Acad Dermatol. 2002;46(6):957-9. KQ2E5. [pmid: 12063500].
92 Carli P, Nardini P, Crocetti E, et al. Frequency and characteristics of melanomas missed at a pigmented lesion clinic: a registry-based study. Melanoma Res. 2004;14(5):403-7. KQ2E5, KQ3E5. [pmid: 15457097].
93 Carlos-Ortega B, Sanchez-Alva ME, Ysita-Morales A, et al. Correlation among simple observation and dermoscopy in the study of pigmented lesions of the skin. Rev Med Inst Mex Seguro Soc. 2007;45(6):541-8. KQ3E1. [pmid: 18593536].
94 Cavalcanti PG, Scharcanski J. Automated prescreening of pigmented skin lesions using standard cameras. Comput Med Imaging Graph. 2011;35(6):481-91. KQ3E6. [pmid: 21489751].
95 Celebi ME, Iyatomi H, Schaefer G, et al. Lesion border detection in dermoscopy images. Comput Med Imaging Graph. 2009;33(2):148-53. KQ3E2. [pmid: 19121917].
96 Celebi ME, Iyatomi H, Schaefer G, et al. Approximate lesion localization in dermoscopy images. Skin Res Technol. 2009;15(3):314-22. KQ3E13. [pmid: 19624428].
97 Cha HC, Harting M, Cha KB, et al. Effects of contiguous scars in dermatoscopic evaluation of clinically atypical melanocytic nevi. J Am Acad Dermatol. 2012;66(5):e179-80. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 22507589].
98 Chagpar RB, Ross MI, Reintgen DS, et al. Factors associated with improved survival among young adult melanoma patients despite a greater incidence of sentinel lymph node metastasis. J Surg Res. 2007;143(1):164-8. KQ5E6. [pmid: 17950088].
99 Chang AE, Karnell LH, Menck HR. The National Cancer Data Base report on cutaneous and noncutaneous melanoma: a summary of 84,836 cases from the past decade. The American College of Surgeons Commission on Cancer and the American Cancer Society. Cancer. 1998;83(8):1664-78. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7. [pmid: 9781962].
100 Chartier T, Bigby M. Rational follow-up recommendations for patients with melanoma. Arch Dermatol. 2000;136(9):1145-7. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 10987873].
101 Cherian P, Tait CP. Melanoma in private practice: do dermatologists make a difference?. Australas J Dermatol. 2009;50(4):257-60. KQ1E6, KQ2E6, KQ3E5, KQ4E6, KQ5E6. [pmid: 19916968].
102 Chintamani Shankar M, Singhal V, Singh JP, et al. Squamous cell carcinoma developing in the scar of Fournier's gangrene--case report. BMC Cancer. 2004;4:16. KQ2E5. [pmid: 15113443].
103 Choudhury K, Volkmer B, Greinert R, et al. Effectiveness of skin cancer screening programmes. Br J Dermatol. 2012:94-8. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 22881593].
104 Civantos F Jr, Zitsch R, et al. Sentinel node biopsy for squamous cell carcinoma of the head and neck. J Surg Oncol. 2008;97(8):683-90. KQ3E2. [pmid: 18493916].
105 Clark GS, Pappas-Politis EC, Cherpelis BS, et al. Surgical management of melanoma in situ on chronically sun-damaged skin. Cancer Control. 2008;15(3):216-24. KQ2E2. [pmid: 18596673].
106 Cokkinides VE, Geller AC, Jemal A. Trends in melanoma mortality among non-Hispanic whites by educational attainment, 1993-2007. Arch Dermatol. 2012;148(5):587-91. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7. [pmid: 22250192].
107 Collins MK, Secrest AM, Ferris LK. Screening for melanoma. Melanoma Res. 2014;24(5):428-36. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 24999755].
108 Commens C. Skin screening in health promotion. Australas J Dermatol. 1995;36(2):103. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 7646388].
109 Conti EM, Cercato MC, Gatta G, et al. Childhood melanoma in Europe since 1978: a population-based survival study. Eur J Cancer. 2001;37(6):780-4. KQ5E7. [pmid: 11311654].
110 Coory M, Baade P, Aitken J, et al. Trends for in situ and invasive melanoma in Queensland, Australia, 1982-2002. Cancer Causes Control. 2006;17(1):21-7. KQ5E6. [pmid: 16411049].
111 Coory M, Smithers M, Aitken J, et al. Urban-rural differences in survival from cutaneous melanoma in Queensland. Aust N Z J Public Health. 2006;30(1):71-4. KQ5E6. [pmid: 16509022].
112 Cordova KB, Weinstock MA. Skin cancer prevention and detection--melanoma and beyond. Med Health R I. 2005;88(3):92-5. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 15915783].
113 Coups EJ, Stapleton JL, Hudson SV, et al. Skin cancer screening among Hispanic adults in the United States: results from the 2010 National Health Interview Survey. Arch Dermatol. 2012;148(7):861-3. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 22801634].
114 Curiel-Lewandrowski C, Kim CC, Swetter SM, et al. Survival is not the only valuable end point in melanoma screening. J Invest Dermatol. 2012;132(5):1332-7. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 22336950].
115 Dal Pozzo V, Benelli C, Roscetti E. The seven features for melanoma: a new dermoscopic algorithm for the diagnosis of malignant melanoma. Eur J Dermatol. 1999;9(4):303-8. KQ3E4. [pmid: 10356410].
116 Day GR, Barbour RH. Automated skin lesion screening--a new approach. Melanoma Res. 2001;11(1):31-5. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 11254113].
117 De Giorgi V, Grazzini M, Rossari S, et al. Adding dermatoscopy to naked eye examination of equivocal melanocytic skin lesions: effect on intention to excise by general dermatologists. Clin Exp Dermatol. 2011;36(3):255-9. KQ3E5. [pmid: 21091756].
118 De Giorgi V, Grazzini M, Rossari S, et al. Total body photography versus digital dermoscopic follow-up in the diagnosis of pigmented lesions. Dermatol Surg. 2011;37(3):406-7. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21410826].
119 de Lima Vazquez V, Sachetto T, Perpetuo NM, et al. Prognostic factors for lymph node metastasis from advanced squamous cell carcinoma of the skin of the trunk and extremities. World J Surg Oncol. 2008;6:73. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 18601735].
120 De Rooij MJ, Rampen FH, Schouten LJ, et al. Total skin examination during screening for malignant melanoma does not increase the detection rate. Br J Dermatol. 1996;135(1):42-5. KQ3E6. [pmid: 8776357].
121 de Rooij MJ, Rampen FH, Schouten LJ, et al. Skin cancer screening focusing on melanoma yields more selective attendance. Arch Dermatol. 1995;131(4):422-5. KQ3E4. [pmid: 7726583].
122 de Vries E, Coebergh JW. Cutaneous malignant melanoma in Europe. Eur J Cancer. 2004;40(16):2355-66. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 15519506].
123 de Vries M, Vonkeman WG, van Ginkel RJ, et al. Morbidity after inguinal sentinel lymph node biopsy and completion lymph node dissection in patients with cutaneous melanoma. Eur J Surg Oncol. 2006;32(7):785-9. KQ5E7. [pmid: 16806794].
124 Del Mar CB, Green AC. Aid to diagnosis of melanoma in primary medical care. BMJ. 1995;310(6978):492-5. KQ1E6, KQ3E6, KQ5E6. [pmid: 7888887].
125 Dhiwakar M, Khan NA, McClymont LG. Surgery for head and neck skin tumors in the elderly. Head Neck. 2007;29(9):851-6. KQ2E4. [pmid: 17427964].
126 Dolan NC, Martin GJ, Robinson JK, et al. Skin cancer control practices among physicians in a university general medicine practice. J Gen Intern Med. 1995;10(9):515-9. KQ3E13. [pmid: 8523156].
127 Douglas NC, Baillie L, Soyer HP. Skin cancer screening of outdoor workers in Queensland. Med J Aust. 2011;195(2):100-1. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 21770887].
128 Dozier S, Wagner RF Jr, et al. Beachfront screening for skin cancer in Texas Gulf coast surfers. South Med J. 1997;90(1):55-8. KQ1E6. [pmid: 9003825].
129 Drugge RJ, Nguyen C, Drugge ED, et al. Melanoma screening with serial whole body photographic change detection using Melanoscan technology. Dermatol Online J. 2009;15(6):1. KQ3E5, KQ4E5, KQ5E5. [pmid: 19723475].
130 Drugge RJ, Nguyen C, Gliga L, et al. Clinical pathway for melanoma detection using comprehensive cutaneous analysis with Melanoscan. Dermatol Online J. 2010;16(8):1. KQ3E5. [pmid: 20804678].
131 Duff CG, Melsom D, Rigby HS, et al. A 6 year prospective analysis of the diagnosis of malignant melanoma in a pigmented-lesion clinic: even the experts miss malignant melanomas, but not often. Br J Plast Surg. 2001;54(4):317-21. KQ3E9. [pmid: 11355986].
132 Durbec F, Vitry F, Granel-Brocard F, et al. The role of circumstances of diagnosis and access to dermatological care in early diagnosis of cutaneous melanoma: a population-based study in France. Arch Dermatol. 2010;146(3):240-6. KQ1E6, KQ2E6, KQ3E6, KQ4E7, KQ5E6. [pmid: 20231493].
133 Edman RL, Klaus SN. Is routine screening for melanoma a benign practice?. JAMA. 2000;284(7):883-6. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 10938180].
134 Edmondson PC, Curley RK, Marsden RA, et al. Screening for malignant melanoma using instant photography. J Med Screen. 1999;6(1):42-6. KQ1E6, KQ4E7. [pmid: 10321371].
135 Eide MJ, Weinstock MA, Dufresne RG, et al. Relationship of treatment delay with surgical defect size from keratinocyte carcinoma (basal cell carcinoma and squamous cell carcinoma of the skin). J Invest Dermatol. 2005;124(2):308-14. KQ2E5. [pmid: 15675948].
136 Eisemann N, Waldmann A, Geller AC, et al. Non-melanoma skin cancer incidence and impact of skin cancer screening on incidence. J Invest Dermatol. 2014;134(1):43-50. KQ1E11, KQ4E6, KQ5E6. [pmid: 23877569].
137 Elsheikh TM, Kirkpatrick JL, Fischer D, et al. Does the time of day or weekday affect screening accuracy? A pilot correlation study with cytotechnologist workload and abnormal rate detection using the ThinPrep Imaging System. Cancer Cytopathol. 2010;118(1):41-6. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 20099317].
138 Elwood JM. Screening for melanoma. Cancer Treat Res. 1996;86:129-47. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 8886443].
139 Engelberg D, Gallagher RP, Rivers JK. Follow-up and evaluation of skin cancer screening in British Columbia. J Am Acad Dermatol. 1999;41(1):37-42. KQ3E5. [pmid: 10411408].
140 English DR, Burton RC, del Mar CB, et al. Evaluation of aid to diagnosis of pigmented skin lesions in general practice: controlled trial randomised by practice. BMJ. 2003;327(7411):375. KQ3E6. [pmid: 12919990].
141 Essner R. Surgical treatment of malignant melanoma. Surg Clin North Am. 2003;83(1):109-56. KQ2E2, KQ6. [pmid: 12691453].
142 Estrada JG. Non-melanoma skin cancer in Catalonia. A community-based prevalence study. Int J Dermatol. 2005;44(11):922-4. KQ1E6, KQ3E4. [pmid: 16336524].
143 Faries M. Survival and the sentinel lymph node in melanoma. Ann Surg Oncol. 2010;17(1):18-20. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 19885700].
144 Fawzy FI, Canada AL, Fawzy NW. Malignant melanoma: effects of a brief, structured psychiatric intervention on survival and recurrence at 10-year follow-up. Arch Gen Psychiatry. 2003;60(1):100-3. KQ2E6, KQ5E7. [pmid: 12511177].
145 Federman DG, Concato J, Kirsner RS. Screening for skin cancer: absence of evidence. Arch Dermatol. 2009;145(8):926-7. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 19687426].
146 Federman DG, Kravetz JD, Tobin DG, et al. Full-body skin examinations: the patient's perspective. Arch Dermatol. 2004;140(5):530-4. KQ1E6, KQ2E5, KQ3E7, KQ4E7, KQ5E6. [pmid: 15148096].
147 Feit NE, Dusza SW, Marghoob AA. Melanomas detected with the aid of total cutaneous photography. Br J Dermatol. 2004;150(4):706-14. KQ1E7, KQ2E7, KQ3E7, KQ4E7. [pmid: 15099367].
148 Fernandez CA, McClure LA, LeBlanc WG, et al. A comparison of Florida skin cancer screening rates with those in the rest of the United States. Arch Dermatol. 2012;148(3):393-5. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 22431787].
149 Ferrandiz L, Moreno-Ramirez D, Camacho FM. Shave excision of common acquired melanocytic nevi: cosmetic outcome, recurrences, and complications. Dermatol Surg. 2005;31(9 Pt 1):1112-5. KQ2E7. [pmid: 16164859].
150 Ferrara G, Argenziano G, Cerroni L, et al. A pilot study of a combined dermoscopic-pathological approach to the telediagnosis of melanocytic skin neoplasms. J Telemed Telecare. 2004;10(1):34-8. KQ3E4. [pmid: 15006214].
151 Ferrara G, Argenziano G, Giorgio CM, et al. Dermoscopic-pathologic correlation: apropos of six equivocal cases. Semin Cutan Med Surg. 2009;28(3):157-64. KQ3E5. [pmid: 19782939].
152 Ferrini R. Screening for skin cancer. Am Fam Physician. 2002;65(7):1401-2. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 11996425].
153 Fisher M, Vines HH, Hasora P. Clinical inquiries. Which technique for removing nevi is least scarring?. J Fam Pract. 2007;56(9):743-4. 746. KQ2E2. [pmid: 17764646].
154 Fisher NM, Schaffer JV, Berwick M, et al. Breslow depth of cutaneous melanoma: impact of factors related to surveillance of the skin, including prior skin biopsies and family history of melanoma. J Am Acad Dermatol. 2005;53(3):393-406. KQ2E6, KQ4E4. [pmid: 16112344].
155 Forsea AM. Melanoma staging and sentinel lymph node biopsy. Acta Dermatovenerol Croat. 2010;18(4):279-88. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21251448].
156 Friedman RJ, Gutkowicz-Krusin D, Farber MJ, et al. The diagnostic performance of expert dermoscopists vs a computer-vision system on small-diameter melanomas. Arch Dermatol. 2008;144(4):476-82. KQ3E5. [pmid: 18427041].
157 Fueyo-Casado A, Vazquez-Lopez F, Sanchez-Martin J, et al. Evaluation of a program for the automatic dermoscopic diagnosis of melanoma in a general dermatology setting. Dermatol Surg. 2009;35(2):257-9. discussion 260-2. KQ3E6. [pmid: 19215265].
158 Futoryan T, Grande D. Postoperative wound infection rates in dermatologic surgery. Dermatol Surg. 1995;21(6):509-14. KQ1E13, KQ2E5, KQ3E6, KQ4E13, KQ5E13. [pmid: 7773598].
159 Gajda M, Kaminska-Winciorek G. Do not let to be late: overview of reasons for melanoma delayed diagnosis. Asian Pac J Cancer Prev. 2014;15(9):3873-7. KQ4E2. [pmid: 24935566].
160 Garcia Arroyo JL, Garcia Zapirain B. Detection of pigment network in dermoscopy images using supervised machine learning and structural analysis. Comput Biol Med. 2014;44:144-57. KQ3E4. [pmid: 24314859].
161 Garcia C, Holman J, Poletti E. Mohs surgery: commentaries and controversies. Int J Dermatol. 2005;44(11):893-905. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 16336520].
162 Garg A, Geller A. Need to improve skin cancer screening of high-risk patients: Comment on “Skin cancer screening by dermatologists, family practitioners, and internists”. Arch Dermatol. 2011;147(1):44-5. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21242391].
163 Garnavi R, Aldeen M, Celebi ME, et al. Border detection in dermoscopy images using hybrid thresholding on optimized color channels. Comput Med Imaging Graph. 2011;35(2):105-15. KQ3E6. [pmid: 20832992].
164 Geller AC. Screening for melanoma. Dermatol Clin. 2002;20(4):629-40. viii. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 12380050].
165 Geller AC, Greinert R, Sinclair C, et al. A nationwide population-based skin cancer screening in Germany: proceedings of the first meeting of the International Task Force on Skin Cancer Screening and Prevention (September 24 and 25, 2009). Cancer Epidemiol. 2010;34(3):355-8. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 20381443].
166 Geller AC, Sober AJ, Zhang Z, et al. Strategies for improving melanoma education and screening for men age >or= 50 years: findings from the American Academy of Dermatological National Skin Cancer Sreening Program. Cancer. 2002;95(7):1554-61. KQ1E6, KQ4E6. [pmid: 12237925].
167 Geller AC, Zhang Z, Sober AJ, et al. The first 15 years of the American Academy of Dermatology skin cancer screening programs: 1985-1999. J Am Acad Dermatol. 2003;48(1):34-41. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 12522368].
168 Goldsmith SM. Cost analysis suggests overemphasis on biopsy rate for melanoma diagnosis. J Am Acad Dermatol. 2013;68(3):517-9. KQ1E4. [pmid: 23394922].
169 Goodson AG, Florell SR, Hyde M, et al. Comparative analysis of total body and dermatoscopic photographic monitoring of nevi in similar patient populations at risk for cutaneous melanoma. Dermatol Surg. 2010;36(7):1087-98. KQ3E4. [pmid: 20653722].
170 Goto M, Kai Y, Arakawa S, et al. Analysis of 256 cases of basal cell carcinoma after either one-step or two-step surgery in a Japanese institution. J Dermatol. 2012;39(1):68-71. KQ2E6. [pmid: 21951151].
171 Grange F, Woronoff AS, Bera R, et al. Efficacy of a general practitioner training campaign for early detection of melanoma in France. Br J Dermatol. 2014;170(1):123-9. KQ1E6. [pmid: 23937244].
172 Grann AF, Froslev T, Olesen AB, et al. The impact of comorbidity and stage on prognosis of Danish melanoma patients, 1987-2009: a registry-based cohort study. Br J Cancer. 2013;109(1):265-71. KQ5E6. [pmid: 23681188].
173 Greinert R, Boniol M. Skin cancer--primary and secondary prevention (information campaigns and screening)--with a focus on children & sunbeds. Prog Biophys Mol Biol. 2011;107(3):473-6. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21906618].
174 Griffiths RW, Feeley K, Suvarna SK. Audit of clinical and histological prognostic factors in primary invasive squamous cell carcinoma of the skin: assessment in a minimum 5 year follow-up study after conventional excisional surgery. Br J Plast Surg. 2002;55(4):287-92. KQ5E7. [pmid: 12160533].
175 Grimaldi L, Silvestri A, Brandi C, et al. Digital epiluminescence dermoscopy for pigmented cutaneous lesions, primary care physicians, and telediagnosis: a useful tool?. J Plast Reconstr Aesthet Surg. 2009;62(8):1054-8. KQ3E5. [pmid: 18547883].
176 Grob JJ, Bonerandi JJ. The ‘ugly duckling’ sign: identification of the common characteristics of nevi in an individual as a basis for melanoma screening. Arch Dermatol. 1998;134(1):103-4. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 9449921].
177 Guillen DR, Cockerell CJ. Accurate diagnosis of cutaneous keratinocytic neoplasms: the importance of histological step sections (and other factors). Arch Dermatol. 2000;136(4):535-7. KQ3E2. [pmid: 10768653].
178 Gurgen J, Gatti M. Epiluminescence microscopy (dermoscopy) versus visual inspection during Mohs microscopic surgery of infiltrative basal cell carcinoma. Dermatol Surg. 2012;38(7 Pt 1):1066-9. KQ3E5. [pmid: 22676346].
179 Guther S, Ramrath K, Dyall-Smith D, et al. Development of a targeted risk-group model for skin cancer screening based on more than 100,000 total skin examinations. J Eur Acad Dermatol Venereol. 2012;26(1):86-94. KQ3E6. [pmid: 21371132].
180 Haenssle HA, Korpas B, Hansen-Hagge C, et al. Seven-point checklist for dermatoscopy: performance during 10 years of prospective surveillance of patients at increased melanoma risk. J Am Acad Dermatol. 2010;62(5):785-93. KQ3E5. [pmid: 20226567].
181 Hajdarevic S, Hornsten A, Sundbom E, et al. Health-care delay in malignant melanoma: various pathways to diagnosis and treatment. Dermatol Res Pract. 2014;2014:294287. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 24516469].
182 Haniffa MA, Lloyd JJ, Lawrence CM. The use of a spectrophotometric intracutaneous analysis device in the real-time diagnosis of melanoma in the setting of a melanoma screening clinic. Br J Dermatol. 2007;156(6):1350-2. KQ3E6. [pmid: 17535234].
183 Harrison PV, Kirby B, Dickinson Y, et al. Teledermatology--high technology or not?. J Telemed Telecare. 1998:31-2. KQ3E7. [pmid: 9640726].
184 Hauschild A, Chen SC, Weichenthal M, et al. To excise or not: impact of MelaFind on German dermatologists' decisions to biopsy atypical lesions. J Dtsch Dermatol Ges. 2014;12(7):606-14. KQ3E7. [pmid: 24944011].
185 Hayashi K, Uhara H, Okuyama R. Detection of the tumor margin of basal-cell carcinoma using dermoscopy and high-frequency ultrasound with narrow pieces of surgical tape as skin markers. Dermatol Surg. 2014;40(6):704-6. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 24852480].
186 Hazan C, Melzer K, Panageas KS, et al. Evaluation of the proliferation marker MIB-1 in the prognosis of cutaneous malignant melanoma. Cancer. 2002;95(3):634-40. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 12209757].
187 Heckman CJ. Enhancing skin cancer screening through behavioral intervention. JAMA Dermatol. 2014;150(4):363-5. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 24553600].
188 Helfand M, Mahon SM, Eden KB, et al. Screening for skin cancer. Am J Prev Med. 2001;20(3 Suppl):47-58. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 11306232].
189 Helfand M, Mahon S, Eden K. Screening for Skin Cancer. 2001. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 20722115].
190 Herd RM, Cooper EJ, Hunter JA, et al. Cutaneous malignant melanoma Publicity, screening clinics and survival--the Edinburgh experience 1982-90. Br J Dermatol. 1995;132(4):563-70. KQ1E6, KQ4E6, KQ5E6. [pmid: 7748747].
191 Hernandez C, Kim H, Mauleon G, et al. A pilot program in collaboration with community centers to increase awareness and participation in skin cancer screening among Latinos in Chicago. J Cancer Educ. 2013;28(2):342-5. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 23378167].
192 Hernandez C, Mermelstein R, Robinson JK, et al. Assessing students' ability to detect melanomas using standardized patients and moulage. J Am Acad Dermatol. 2013;68(3):e83-8. KQ3E5. [pmid: 22196980].
193 Herschorn A. Dermoscopy for melanoma detection in family practice. Can Fam Physician. 2012;58(7):740-5. e372. 8. KQ3E2. [pmid: 22859635].
194 Hershock D. Genetics, prevention and screening for melanoma. Cancer Chemother Biol Response Modif. 2005;22:707-28. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7. [pmid: 16110635].
195 Hinton D. Strategies for skin cancer screening. Dermatol Nurs. 2008;20(6):475. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 19241746].
196 Hocutt JE Jr, Morgan LO. Dermatoscopic screening in family practice. Del Med J. 2001;73(6):227-34. KQ3E6. [pmid: 11449929].
197 Hoffmann K, Gambichler T, Rick A, et al. Diagnostic and neural analysis of skin cancer (DANAOS). A multicentre study for collection and computer-aided analysis of data from pigmented skin lesions using digital dermoscopy. Br J Dermatol. 2003;149(4):801-9. KQ3E6. [pmid: 14616373].
198 Hohnheiser AM, Gefeller O, Gohl J, et al. Malignant melanoma of the skin: long-term follow-up and time to first recurrence. World J Surg. 2011;35(3):580-9. KQ4E7, KQ5E6. [pmid: 21125274].
199 Holme SA, Varma S, Chowdhury MM, et al. Audit of a melanoma screening day in the U.K.: clinical results, participant satisfaction and perceived value. Br J Dermatol. 2001;145(5):784-8. KQ1E6, KQ3E5. [pmid: 11736902].
200 Hossain D, Qian J, Adupe J, et al. Differentiation of melanoma and benign nevi by fluorescence in-situ hybridization. Melanoma Res. 2011;21(5):426-30. KQ3E13. [pmid: 21900793].
201 Hu S, Kirsner RS. Suboptimal skin cancer screening and delayed melanoma diagnosis in Hispanics: comment on “Cutaneous melanoma and other skin cancer screening among Hispanics in the United States”. Arch Dermatol. 2011;147(6):745-6. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21690546].
202 Hu S, Soza-Vento RM, Parker DF, et al. Comparison of stage at diagnosis of melanoma among Hispanic, black, and white patients in Miami-Dade County, Florida. Arch Dermatol. 2006;142(6):704-8. KQ2E5. [pmid: 16785372].
203 Hunger RE, Della Torre R, Serov A, et al. Assessment of melanocytic skin lesions with a high-definition laser Doppler imaging system. Skin Res Technol. 2012;18(2):207-11. KQ3E7. [pmid: 22092722].
204 Hussussian CJ. Surgical treatment of advanced melanoma. Clin Plast Surg. 2010;37(1):161-8. KQ2E2, KQ6. [pmid: 19914466].
205 Iyatomi H, Celebi M, Oka H, et al. An Internet-based melanoma screening system with acral volar lesion support. Conf Proc IEEE Eng Med Biol Soc. 2008;2008:5156-9. KQ3E13. [pmid: 19163878].
206 Iyatomi H, Norton KA, Celebi M, et al. Classification of melanocytic skin lesions from non-melanocytic lesions. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:5407-10. KQ3E5. [pmid: 21096271].
207 Iyatomi H, Oka H, Celebi ME, et al. An improved Internet-based melanoma screening system with dermatologist-like tumor area extraction algorithm. Comput Med Imaging Graph. 2008;32(7):566-79. KQ3E5. [pmid: 18703311].
208 Iyatomi H, Oka H, Celebi ME, et al. Computer-based classification of dermoscopy images of melanocytic lesions on acral volar skin. J Invest Dermatol. 2008;128(8):2049-54. KQ3E5. [pmid: 18323788].
209 Jackson AM, Morgan DR, Ellison R. Diagnosis of malignant melanoma by general practitioners and hospital specialists. Postgrad Med J. 2000;76(895):295-8. KQ3E5. [pmid: 10775284].
210 Jackson A. ‘Is this mole all right’?. Practitioner. 1998;242(1585):254-6. 260. 2. 264 passim. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 10492981].
211 Jackson A, Wilkinson C, Ranger M, et al. Can primary prevention or selective screening for melanoma be more precisely targeted through general practice? A prospective study to validate a self administered risk score. BMJ. 1998;316(7124):34-8. discussion 38-9. KQ3E6. [pmid: 9451264].
212 Janda M, Lowe JB, Elwood M, et al. Do centralised skin screening clinics increase participation in melanoma screening (Australia)?. Cancer Causes Control. 2006;17(2):161-8. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 16425094].
213 Janda M, Youl P, Neale R, et al. Clinical skin examination outcomes after a video-based behavioral intervention: analysis from a randomized clinical trial. JAMA Dermatol. 2014;150(4):372-9. KQ1E6, KQ3E7. [pmid: 24553807].
214 Jonna BP, Delfino RJ, Newman WG, et al. Positive predictive value for presumptive diagnoses of skin cancer and compliance with follow-up among patients attending a community screening program. Prev Med. 1998;27(4):611-6. KQ1E6, KQ3E5, KQ4E6. [pmid: 9672956].
215 Kansal AR, Shaul AJ, Stern S, et al. Cost-effectiveness of a FISH assay for the diagnosis of melanoma in the USA. Expert Rev Pharmacoecon Outcomes Res. 2013;13(3):371-80. KQ3E5. [pmid: 23672374].
216 Kantor J, Kantor DE. Routine dermatologist-performed full-body skin examination and early melanoma detection. Arch Dermatol. 2009;145(8):873-6. KQ3E6, KQ4E6. [pmid: 19687416].
217 Kanzler MH. The current status of evaluation and treatment of high-risk cutaneous melanoma: therapeutic breakthroughs remain elusive. Arch Dermatol. 2007;143(6):785-7. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17576947].
218 Karampoiki V, Flores FJ, Altinoz H, et al. Screening Evaluation System--Europe (SESy_Europe) met skin cancer screening. Cent Eur J Public Health. 2007;15(2):71-3. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 17645221].
219 Karim RZ, Scolyer RA, Li W, et al. False negative sentinel lymph node biopsies in melanoma may result from deficiencies in nuclear medicine, surgery, or pathology. Ann Surg. 2008;247(6):1003-10. KQ2E5. [pmid: 18520228].
220 Katris P. Results from a skin cancer screening program in Western Australia. Med J Aust. 1995;163(10):557. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 8538531].
221 Katris P, Crock JG, Gray BN. Research note: the Lions Cancer Institute and the Western Australian Society of Plastic Surgeons skin cancer screening programme. Aust N Z J Surg. 1996;66(2):101-4. KQ1E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 8602803].
222 Katris P, Donovan RJ, Gray BN. Nurses screening for skin cancer: an observation study. Aust N Z J Public Health. 1998;22(3 Suppl):381-3. KQ3E5. [pmid: 9629826].
223 Keeley D. Screening for melanoma risk is misguided. BMJ. 1995;310(6984):916. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 7719185].
224 Kelly JW, Yeatman JM, Regalia C, et al. A high incidence of melanoma found in patients with multiple dysplastic naevi by photographic surveillance. Med J Aust. 1997;167(4):191-4. KQ3E5. [pmid: 9293264].
225 Kirsner RS, Wilkinson JD, Ma F, et al. The association of Medicare health care delivery systems with stage at diagnosis and survival for patients with melanoma. Arch Dermatol. 2005;141(6):753-7. KQ5E6, KQ6. [pmid: 15967922].
226 Kitchener SJ, McMaster S, Nasveld P. Who attends skin cancer screening in the suburbs?. Aust N Z J Public Health. 2006;30(3):290-1. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 16800212].
227 Kitchener S, McMaster S, Nasveld P. Dermoscopy in primary care for detection of melanoma. Int J Dermatol. 2009;48(12):1397-8. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 20415681].
228 Koh HK. Melanoma screening: focusing the public health journey. Arch Dermatol. 2007;143(1):101-3. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17224549].
229 Koh HK, Norton LA, Geller AC, et al. Evaluation of the American Academy of Dermatology's National Skin Cancer Early Detection and Screening Program. J Am Acad Dermatol. 1996;34(6):971-8. KQ1E6, KQ4E6, KQ3E5. [pmid: 8647990].
230 Konstadoulakis MM, Messaris E, Zografos G, et al. Common prognostic factors for stage III melanoma patients and for stage I and II melanoma patients with recurrence to their regional lymph nodes. Melanoma Res. 2002;12(4):357-64. KQ5E6. [pmid: 12170185].
231 Kovalyshyn I, Dusza SW, Siamas K, et al. The impact of physician screening on melanoma detection. Arch Dermatol. 2011;147(11):1269-75. KQ3E5. [pmid: 21768448].
232 Kretschmer L, Starz H, Thoms KM, et al. Age as a key factor influencing metastasizing patterns and disease-specific survival after sentinel lymph node biopsy for cutaneous melanoma. Int J Cancer. 2011;129(6):1435-42. KQ5E6. [pmid: 21064111].
233 Kricker A, Armstrong B, Hansen V, et al. Basal cell carcinoma and squamous cell carcinoma growth rates and determinants of size in community patients. J Am Acad Dermatol. 2014;70(3):456-64. KQ5E6. [pmid: 24373780].
234 Kroemer S, Fruhauf J, Campbell TM, et al. Mobile teledermatology for skin tumour screening: diagnostic accuracy of clinical and dermoscopic image tele-evaluation using cellular phones. Br J Dermatol. 2011;164(5):973-9. KQ3E9. [pmid: 21219286].
235 Kyrgidis A, Tzellos T, Mocellin S, et al. Sentinel lymph node biopsy followed by lymph node dissection for localised primary cutaneous melanoma. Cochrane Database Syst Rev. 2015;5. CD010307. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7. [pmid: 25978975].
236 Lai SM, King JB, Garimella S, et al. Effect of the staging schema on melanoma cancer reporting, 1999 to 2006. J Am Acad Dermatol. 2011;65(5 Suppl 1):S95-103. KQ1E4, KQ2E4, KQ3E4, KQ4E4, KQ5E4. [pmid: 22018073].
237 Lallas A, Argenziano G, Kyrgidis A, et al. Dermoscopy uncovers clinically undetectable pigmentation in basal cell carcinoma. Br J Dermatol. 2014;170(1):192-5. KQ3E6. [pmid: 24117444].
238 Lamel SA, Haldeman KM, Ely H, et al. Application of mobile teledermatology for skin cancer screening. J Am Acad Dermatol. 2012;67(4):576-81. KQ3E6. [pmid: 22243769].
239 Lane JE, Dalton RR, Sangueza OP. Cutaneous melanoma: detecting it earlier, weighing management options. J Fam Pract. 2007;56(1):18-28. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17217894].
240 Lasithiotakis KG, Leiter U, Eigentler T, et al. Improvement of overall survival of patients with cutaneous melanoma in Germany, 1976-2001: which factors contributed?. Cancer. 2007;109(6):1174-82. KQ1E5, KQ4E5, KQ5E5. [pmid: 17265520].
241 Laub DR Jr. Death from metastatic basal cell carcinoma: herbal remedy or just unlucky?. J Plast Reconstr Aesthet Surg. 2008;61(7):846-8. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 18472318].
242 Lee EH, Busam KJ. Desmoplastic melanoma presenting after laser treatment: a case report and tale of caution. Dermatol Surg. 2011;37(11):1689-92. KQ1E9, KQ2E4, KQ3E9, KQ4E9, KQ5E9. [pmid: 21790855].
243 Lehto US, Ojanen M, Dyba T, et al. Baseline psychosocial predictors of survival in localized melanoma. J Psychosom Res. 2007;63(1). 15-Sep. KQ2E6. [pmid: 17586333].
244 Lejeune FJ. The impact of surgery on the course of melanoma. Recent Results Cancer Res. 2002;160:151-7. KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 12079209].
245 Limpert GH. Skin-cancer screening: a three-year experience that paid for itself. J Fam Pract. 1995;40(5):471-5. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 7730771].
246 Lin KW, Sharangpani R. Screening for skin cancer. Am Fam Physician. 2010;81(12):1435-6. quiz 1429. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 20540480].
247 Linos E, Wehner MR, Frosch DL, et al. Patient-reported problems after office procedures. JAMA Intern Med. 2013;173(13):1249-50. KQ2E6. [pmid: 23689235].
248 Little P, Keefe M, White J. Screening for melanoma. BMJ. 1995;311(7001):389-90. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 7640558].
249 Livingstone E, Windemuth-Kieselbach C, Eigentler TK, et al. A first prospective population-based analysis investigating the actual practice of melanoma diagnosis, treatment and follow-up. Eur J Cancer. 2011;47(13):1977-89. KQ4E5. [pmid: 21612915].
250 Lowe M, Hill N, Page A, et al. The impact of shave biopsy on the management of patients with thin melanomas. Am Surg. 2011;77(8):1050-3. KQ2E4, KQ3E4, KQ4E4. [pmid: 21944522].
251 MacKie RM, Fleming C, McMahon AD, et al. The use of the dermatoscope to identify early melanoma using the three-colour test. Br J Dermatol. 2002;146(3):481-4. KQ3E6. [pmid: 11952549].
252 Malvehy J, Hauschild A, Curiel-Lewandrowski C, et al. Clinical performance of the Nevisense system in cutaneous melanoma detection: an international, multicentre, prospective and blinded clinical trial on efficacy and safety. Br J Dermatol. 2014;171(5):1099-107. KQ3E5. [pmid: 24841846].
253 Marks R. Positive predictive value of skin cancer screening. J Am Acad Dermatol. 2006;55(3):544-5. author reply 545-6. KQ3E2. [pmid: 16908378].
254 Marks R. Squamous cell carcinoma. Lancet. 1996;347(9003):735-8. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 8602006].
255 Massone C, Maak D, Hofmann-Wellenhof R, et al. Teledermatology for skin cancer prevention: an experience on 690 Austrian patients. J Eur Acad Dermatol Venereol. 2014;28(8):1103-8. KQ3E5. [pmid: 24372877].
256 Matteucci P, Pinder R, Magdum A, et al. Accuracy in skin lesion diagnosis and the exclusion of malignancy. J Plast Reconstr Aesthet Surg. 2011;64(11):1460-5. KQ4E6, KQ4E6. [pmid: 21741335].
257 Mauad EC, Silva TB, Latorre MR, et al. Opportunistic screening for skin cancer using a mobile unit in Brazil. BMC Dermatol. 2011;11:12. KQ1E5, KQ4E5. [pmid: 21645347].
258 Mayer JE, Swetter SM, Fu T, et al. Screening, early detection, education, and trends for melanoma: current status (2007-2013) and future directions: Part II. Screening, education, and future directions. J Am Acad Dermatol. 2014;71(4):611 e1-611 e10. quiz 621-2. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 25219717].
259 Mayer JE, Swetter SM, Fu T, et al. Screening, early detection, education, and trends for melanoma: current status (2007-2013) and future directions: Part I. Epidemiology, high-risk groups, clinical strategies, and diagnostic technology. J Am Acad Dermatol. 2014;71(4):599 e1-599 e12. quiz 610, 599 e12. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 25219716].
260 Melia J. Early detection of cutaneous malignant melanoma in Britain. Int J Epidemiol. 1995:S39-44. KQ1E6. [pmid: 7558550].
261 Melia J, Cooper EJ, Frost T, et al. Cancer Research Campaign health education programme to promote the early detection of cutaneous malignant melanoma. II. Characteristics and incidence of melanoma. Br J Dermatol. 1995;132(3):414-21. KQ1E6, KQ3E6, KQ4E7. [pmid: 7718458].
262 Melia J, Harland C, Moss S, et al. Feasibility of targeted early detection for melanoma: a population-based screening study. Br J Cancer. 2000;82(9):1605-9. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 10789732].
263 Melia J, Moss S, Coleman D, et al. The relation between mortality from malignant melanoma and early detection in the Cancer Research Campaign Mole Watcher Study. Br J Cancer. 2001;85(6):803-7. KQ1E6. [pmid: 11556828].
264 Menzies SW, Emery J, Staples M, et al. Impact of dermoscopy and short-term sequential digital dermoscopy imaging for the management of pigmented lesions in primary care: a sequential intervention trial. Br J Dermatol. 2009;161(6):1270-7. KQ3E7, KQ4E6. [pmid: 19747359].
265 Mills JK, White I, Diggs B, et al. Effect of biopsy type on outcomes in the treatment of primary cutaneous melanoma. Am J Surg. 2013;205(5):585-90. discussion 590. KQ2E13, KQ3E13, KQ4E13. [pmid: 23592167].
266 Moore P, Hundley J, Hundley J, et al. Does shave biopsy accurately predict the final breslow depth of primary cutaneous melanoma?. Am Surg. 2009;75(5):369-73. discussion 374. KQ2E4, KQ4E4. [pmid: 19445285].
267 Moran B, McDonald I, Wall D, et al. Complete skin examination is essential in the assessment of dermatology patients: findings from 483 patients. Br J Dermatol. 2011;165(5):1124-6. KQ1E6, KQ3E5, KQ4E5. [pmid: 21711328].
268 Moreno-Ramirez D, Ferrandiz L, Galdeano R, et al. Teledermatoscopy as a triage system for pigmented lesions: a pilot study. Clin Exp Dermatol. 2006;31(1):13-8. KQ3E7. [pmid: 16309470].
269 Moreno-Ramirez D, Ferrandiz L, Nieto-Garcia A, et al. Store-and-forward teledermatology in skin cancer triage: experience and evaluation of 2009 teleconsultations. Arch Dermatol. 2007;143(4):479-84. KQ3E5. [pmid: 17438180].
270 Mosterd K, Thissen MR, van Marion AM, et al. Correlation between histologic findings on punch biopsy specimens and subsequent excision specimens in recurrent basal cell carcinoma. J Am Acad Dermatol. 2011;64(2):323-7. KQ2E5. [pmid: 21238826].
271 Munoz C, Vazquez-Botet M. Melanoma in situ in Puerto Rico: clinical characteristics and detection patterns. P R Health Sci J. 2004;23(3):179-82. KQ4E5. [pmid: 15631171].
272 Murali R, Doubrovsky A, Watson GF, et al. Diagnosis of metastatic melanoma by fine-needle biopsy: analysis of 2,204 cases. Am J Clin Pathol. 2007;127(3):385-97. KQ3E13. [pmid: 17276948].
273 Nagano T, Ueda M, Suzuki T, et al. Skin cancer screening in Okinawa, Japan. J Dermatol Sci. 1999;19(3):161-5. KQ3E7. [pmid: 10215187].
274 Nathansohn N, Orenstein A, Trau H, et al. Pigmented lesions clinic for early detection of melanoma: preliminary results. Isr Med Assoc J. 2007;9(10):708-12. KQ3E6. [pmid: 17987757].
275 Nichols AC, Bhattacharyya N. Racial differences in stage and survival in head and neck squamous cell carcinoma. Laryngoscope. 2007;117(5):770-5. KQ5E13. [pmid: 17473666].
276 Nikkels AF, Nikkels-Tassoudji N, Jerusalem-Noury E, et al. Skin cancer screening campaign in the German speaking Community of Belgium. Acta Clin Belg. 2004;59(4):194-8. KQ3E6. [pmid: 15597726].
277 Oivanen T, Kojo K, Pylkkanen L, et al. Early detection of skin cancer as public health policy: comparison of campaign and routine activity. Prev Med. 2008;46(2):160-5. KQ3E7. [pmid: 17919714].
278 O'Leary JA, Berend KR, Johnson JL, et al. Subungual melanoma. A review of 93 cases with identification of prognostic variables. Clin Orthop Relat Res. 2000;(378):206-12. KQ5E5. [pmid: 10986996].
279 Orfaniotis G, Mennie JC, Fairbairn N, et al. Findings of computed tomography in stage IIB and IIC melanoma: a six-year retrospective study in the South-East of Scotland. J Plast Reconstr Aesthet Surg. 2012;65(9):1216-9. KQ5E13. [pmid: 22525255].
280 Osborne JE. Skin cancer screening and surveillance. Br J Dermatol. 2002;146(5):745-54. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 12000369].
281 Osborne JE, Bourke JF, Graham-Brown RA, et al. False negative clinical diagnoses of malignant melanoma. Br J Dermatol. 1999;140(5):902-8. KQ2E4, KQ6. [pmid: 10354030].
282 Osborne JE, Chave TA, Hutchinson PE. Comparison of diagnostic accuracy for cutaneous malignant melanoma between general dermatology, plastic surgery and pigmented lesion clinics. Br J Dermatol. 2003;148(2):252-8. KQ3E6. [pmid: 12588376].
283 Pacifico MD, Grover R, Sanders R. Use of an early-detection strategy to improve disease control in melanoma patients. Br J Plast Surg. 2004;57(2):105-11. KQ1E13, KQ4E7. [pmid: 15037164].
284 Pacifico MD, Pearl RA, Grover R. The UK Government two-week rule and its impact on melanoma prognosis: an evidence-based study. Ann R Coll Surg Engl. 2007;89(6):609-15. KQ1E6, KQ2E2, KQ3E13, KQ4E13, KQ5E13. [pmid: 18201477].
285 Paoli J, Danielsson M, Wennberg AM. Results of the ‘Euromelanoma Day’ screening campaign in Sweden 2008. J Eur Acad Dermatol Venereol. 2009;23(11):1304-10. KQ3E5. [pmid: 19522711].
286 Penel N, Fournier C, Lefebvre D, et al. Multivariate analysis of risk factors for wound infection in head and neck squamous cell carcinoma surgery with opening of mucosa. Study of 260 surgical procedures. Oral Oncol. 2005;41(3):294-303. KQ2E5. [pmid: 15743692].
287 Pennie ML, Soon SL, Risser JB, et al. Melanoma outcomes for Medicare patients: association of stage and survival with detection by a dermatologist vs a nondermatologist. Arch Dermatol. 2007;143(4):488-94. KQ1E7, KQ3E7, KQ5E7. [pmid: 17438181].
288 Petit JY, Avril MF, Margulis A, et al. Evaluation of cosmetic results of a randomized trial comparing surgery and radiotherapy in the treatment of basal cell carcinoma of the face. Plast Reconstr Surg. 2000;105(7):2544-51. KQ2E7. [pmid: 10845311].
289 Pilko G, Besic N, Zgajnar J, et al. Prognostic heterogeneity after the excision of lymph node metastases in patients with cutaneous melanoma. Surg Oncol. 2011;20(1):26-34. KQ5E7. [pmid: 19900803].
290 Plym A, Ullenhag GJ, Breivald M, et al. Clinical characteristics, management and survival in young adults diagnosed with malignant melanoma: A population-based cohort study. Acta Oncol. 2014;53(5):688-96. KQ5E6. [pmid: 24369746].
291 Pollitt RA, Clarke CA, Shema SJ, et al. California Medicaid enrollment and melanoma stage at diagnosis: a population-based study. Am J Prev Med. 2008;35(1). 13-Jul. KQ5E6. [pmid: 18482824].
292 Poo-Hwu WJ, Ariyan S, Lamb L, et al. Follow-up recommendations for patients with American Joint Committee on Cancer Stages I-III malignant melanoma. Cancer. 1999;86(11):2252-8. KQ5E6. [pmid: 10590365].
293 Posther KE, Selim MA, Mosca PJ, et al. Histopathologic characteristics, recurrence patterns, and survival of 129 patients with desmoplastic melanoma. Ann Surg Oncol. 2006;13(5):728-39. KQ5E6. [pmid: 16538415].
294 Poulsen M, Round C, Keller J, et al. Factors influencing relapse-free survival in Merkel cell carcinoma of the lower limb--a review of 60 cases. Int J Radiat Oncol Biol Phys. 2010;76(2):393-7. KQ5E6. [pmid: 19515508].
295 Poziomczyk CS, Koche B, Dornelles Mde A, et al. Pain evaluation in the cryosurgery of actinic keratoses. An Bras Dermatol. 2011;86(4):645-50. KQ2E7, KQ6. [pmid: 21987127].
296 Printz C. Target: melanoma: skin cancer screenings hold promise to reduce mortality rates, but usage of widespread screening lags. Cancer. 2013;119(13):2359-60. KQ1E2. [pmid: 23775430].
297 Puig S, Argenziano G, Zalaudek I, et al. Melanomas that failed dermoscopic detection: a combined clinicodermoscopic approach for not missing melanoma. Dermatol Surg. 2007;33(10):1262-73. KQ2E6. [pmid: 17903162].
298 Purdue MP, Freeman LE, Anderson WF, et al. Recent trends in incidence of cutaneous melanoma among US Caucasian young adults. J Invest Dermatol. 2008;128(12):2905-8. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7. [pmid: 18615112].
299 Quereux G, N'Guyen JM, Cary M, et al. Validation of the Self-Assessment of Melanoma Risk Score for a melanoma-targeted screening. Eur J Cancer Prev. 2012;21(6):588-95. KQ3E5. [pmid: 22555198].
300 Rademaker M, Oakley A. Digital monitoring by whole body photography and sequential digital dermoscopy detects thinner melanomas. J Prim Health Care. 2010;2(4):268-72. KQ2E6, KQ3E6, KQ4E6. [pmid: 21125066].
301 Rajpara SM, Botello AP, Townend J, et al. Systematic review of dermoscopy and digital dermoscopy/ artificial intelligence for the diagnosis of melanoma. Br J Dermatol. 2009;161(3):591-604. KQ3E9. [pmid: 19302072].
302 Rampen FH, Casparie-van Velsen JI, van Huystee BE, et al. False-negative findings in skin cancer and melanoma screening. J Am Acad Dermatol. 1995;33(1):59-63. KQ2E6, KQ3E6. [pmid: 7601947].
303 Rampen RH. Point-counterpoint. Mass population skin cancer screening is not worthwhile. J Cutan Med Surg. 1998;2(3):128-9. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 9556369].
304 Ravin AG, Pickett N, Johnson JL, et al. Melanoma of the ear: treatment and survival probabilities based on 199 patients. Ann Plast Surg. 2006;57(1):70-6. KQ5E6. [pmid: 16799312].
305 Reintgen C, Shivers S, Reintgen M, et al. The changing face of malignant melanoma. J Surg Oncol. 2010;101(6):443-6. KQ5E6. [pmid: 20401913].
306 Reisenauer A, Lee BJ, Akamine K, et al. Management of melanoma in a patient population: using electronic health records to enhance postdiagnosis surveillance. JAMA Dermatol. 2013;149(3):365-6. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 23552748].
307 Resnik KS, DiLeonardo M, Gibbons G. Clinically occult cutaneous metastases. J Am Acad Dermatol. 2006;55(6):1044-7. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 17110220].
308 Retsas S, Henry K, Mohammed MQ, et al. Prognostic factors of cutaneous melanoma and a new staging system proposed by the American Joint Committee on Cancer (AJCC): validation in a cohort of 1284 patients. Eur J Cancer. 2002;38(4):511-6. KQ5E6. [pmid: 11872343].
309 Rex J, Paradelo C, Mangas C, et al. Management of primary cutaneous melanoma of the hands and feet: a clinicoprognostic study. Dermatol Surg. 2009;35(10):1505-13. KQ5E6. [pmid: 19686364].
310 Rhodes AR. Prognostic usefulness of sentinel lymph node biopsy for patients who have clinically node negative, localized, primary invasive cutaneous melanoma: a Bayesian analysis using informative published reports. Arch Dermatol. 2011;147(4):408-15. KQ5E2, KQ6. [pmid: 21173300].
311 Richtig E, Ambros-Rudolph CM, Trapp M, et al. Melanoma markers in marathon runners: increase with sun exposure and physical strain. Dermatology. 2008;217(1):38-44. KQ3E7. [pmid: 18367839].
312 Richtig E, Santigli E, Fink-Puches R, et al. Assessing melanoma risk factors: how closely do patients and doctors agree?. Public Health. 2008;122(12):1433-9. KQ3E7. [pmid: 18752818].
313 Rigel DS. Is the ounce of screening and prevention for skin cancer worth the pound of cure?. CA Cancer J Clin. 1998;48(4):236-8. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 9676538].
314 Rissin Y, Fodor L, Ishach H, et al. Patient satisfaction after removal of skin lesions. J Eur Acad Dermatol Venereol. 2007;21(7):951-5. KQ2E9. [pmid: 17659005].
315 Robati RM, Toossi P, Karimi M, et al. Screening for skin cancer: a pilot study in Tehran, Iran. Indian J Dermatol. 2014;59(1):105. KQ2E4, KQ3E4, KQ4E4. [pmid: 24470679].
316 Robinson JK, McGaghie WC. Skin cancer detection in a clinical practice examination with standardized patients. J Am Acad Dermatol. 1996;34(4):709-11. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 8601670].
317 Roder DM, Luke CG, McCaul KA, et al. Trends in prognostic factors of melanoma in South Australia, 1981-1992: implications for health promotion. Med J Aust. 1995;162(1):25-9. KQ5E6. [pmid: 7845294].
318 Roetzheim RG, Lee JH, Ferrante JM, et al. The influence of dermatologist and primary care physician visits on melanoma outcomes among Medicare beneficiaries. J Am Board Fam Med. 2013;26(6):637-47. KQ1E7, KQ3E7. [pmid: 24204060].
319 Roetzheim RG, Pal N, van Durme DJ, et al. Increasing supplies of dermatologists and family physicians are associated with earlier stage of melanoma detection. J Am Acad Dermatol. 2000;43(2 Pt 1):211-8. KQ3E6. [pmid: 10906640].
320 Rosenblatt L, Marks R. Deaths due to squamous cell carcinoma in Australia: is there a case for a public health intervention?. Australasian Journal of Dermatology. 1996;37(1):26-9. KQ5E6. [pmid: 8936067].
321 Rosendahl C, Williams G, Eley D, et al. The impact of subspecialization and dermatoscopy use on accuracy of melanoma diagnosis among primary care doctors in Australia. J Am Acad Dermatol. 2012;67(5):846-52. KQ3E6. [pmid: 22325462].
322 Rossi CR, De Salvo GL, Bonandini E, et al. Factors predictive of nonsentinel lymph node involvement and clinical outcome in melanoma patients with metastatic sentinel lymph node. Ann Surg Oncol. 2008;15(4):1202-10. KQ5E13. [pmid: 18165880].
323 Rossi CR, Vecchiato A, Bezze G, et al. Early detection of melanoma: an educational campaign in Padova, Italy. Melanoma Res. 2000;10(2):181-7. KQ1E6, KQ2E6, KQ3E7, KQ4E6. [pmid: 10803719].
324 Rouhani P, Arheart KL, Kirsner RS. Differences in melanoma outcomes among Hispanic Medicare enrollees. J Am Acad Dermatol. 2010;62(5):768-76. KQ5E6. [pmid: 20219264].
325 Rowbotham MC, Leong SP. How to reduce the incidence of neuropathic pain: sentinel node biopsy for diagnosis of metastatic malignant melanoma. Pain. 2011;152(12):2681-2. KQ2E2, KQ6. [pmid: 21983239].
326 Rubegni P, Cevenini G, Burroni M, et al. Objective follow-up of atypical melanocytic skin lesions: a retrospective study. Arch Dermatol Res. 2010;302(7):551-60. KQ3E6. [pmid: 20411393].
327 Rueth NM, Groth SS, Tuttle TM, et al. Conditional survival after surgical treatment of melanoma: an analysis of the Surveillance, Epidemiology, and End Results database. Ann Surg Oncol. 2010;17(6):1662-8. KQ5E6. [pmid: 20165985].
328 Rughani MG, Swan MC, Adams TS, et al. Sentinel node status predicts survival in thick melanomas: the Oxford perspective. Eur J Surg Oncol. 2012;38(10):936-42. KQ5E6. [pmid: 22617251].
329 Rughani MG, Swan MC, Adams TS, et al. Sentinel lymph node biopsy in melanoma: The Oxford ten year clinical experience. J Plast Reconstr Aesthet Surg. 2011;64(10):1284-90. KQ5E6, KQ6. [pmid: 21612993].
330 Russell L. Patient's page. Malignant melanoma and the importance of screening. South Med J. 2008;101(5):455. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 18414149].
331 Rutkowski P, Nowecki ZI, Nasierowska-Guttmejer A, et al. Lymph node status and survival in cutaneous malignant melanoma--sentinel lymph node biopsy impact. Eur J Surg Oncol. 2003;29(7):611-8. KQ2E7. [pmid: 12943629].
332 Sahn RE, Lang PG. Sentinel lymph node biopsy for high-risk nonmelanoma skin cancers. Dermatol Surg. 2007;33(7):786-92. discussion 792-3. KQ2E7, KQ6. [pmid: 17598843].
333 Saida T, Miyazaki A, Oguchi S, et al. Significance of dermoscopic patterns in detecting malignant melanoma on acral volar skin: results of a multicenter study in Japan. Arch Dermatol. 2004;140(10):1233-8. KQ3E5. [pmid: 15492186].
334 Salerni G, Carrera C, Lovatto L, et al. Characterization of 1152 lesions excised over 10 years using total-body photography and digital dermatoscopy in the surveillance of patients at high risk for melanoma. J Am Acad Dermatol. 2012;67(5):836-45. KQ3E6. [pmid: 22521205].
335 Salerni G, Carrera C, Lovatto L, et al. Benefits of total body photography and digital dermatoscopy ("two-step method of digital follow-up") in the early diagnosis of melanoma in patients at high risk for melanoma. J Am Acad Dermatol. 2012;67(1):e17-27. KQ3E5. [pmid: 21683472].
336 Salerni G, Lovatto L, Carrera C, et al. Melanomas detected in a follow-up program compared with melanomas referred to a melanoma unit. Arch Dermatol. 2011;147(5):549-55. KQ3E5. [pmid: 21242346].
337 Salerni G, Teran T, Puig S, et al. Meta-analysis of digital dermoscopy follow-up of melanocytic skin lesions: a study on behalf of the International Dermoscopy Society. J Eur Acad Dermatol Venereol. 2013;27(7):805-14. KQ3E6. [pmid: 23181611].
338 Salvio AG, Assumpcao Junior A, Segalla JG, et al. One year experience of a model for melanoma continuous prevention in the city of Jau (Sao Paulo), Brazil. An Bras Dermatol. 2011;86(4):669-74. KQ1E4, KQ2E4, KQ3E4, KQ4E4, KQ5E4. [pmid: 21987131].
339 Sankaran N. A call for stepped-up melanoma screening. Ann Intern Med. 1997;126(4):I60-1. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 9446503].
340 Sanlorenzo M, Ribero S, Osella-Abate S, et al. Prognostic differences across sexes in melanoma patients: what has changed from the past?. Melanoma Res. 2014;24(6):568-76. KQ5E6. [pmid: 24892954].
341 Sargeran K, Murtomaa H, Safavi SM, et al. Survival after lip cancer diagnosis. J Craniofac Surg. 2009;20(1):248-52. KQ5E13. [pmid: 19165039].
342 Satorres Nieto M, Gargallo Albiol J, Gay Escoda C. Surgical management of actinic cheilitis. Med Oral. 2001;6(3):205-17. KQ2E1. [pmid: 11500638].
343 Schaefer I, Rustenbach SJ, Zimmer L, et al. Prevalence of skin diseases in a cohort of 48,665 employees in Germany. Dermatology. 2008;217(2):169-72. KQ3E4. [pmid: 18525204].
344 Schiffner R, Schiffner-Rohe J, Landthaler M, et al. Long-term dermoscopic follow-up of melanocytic naevi: clinical outcome and patient compliance. Br J Dermatol. 2003;149(1):79-86. KQ2E5. [pmid: 12890198].
345 Schmid-Wendtner MH, Baumert J, Eberle J, et al. Disease progression in patients with thin cutaneous melanomas (tumour thickness < or = 0.75 mm): clinical and epidemiological data from the Tumour Center Munich 1977-98. Br J Dermatol. 2003;149(4):788-93. KQ5E6. [pmid: 14616371].
346 Schmid-Wendtner MH, Berking C, Baumert J, et al. Cutaneous melanoma in childhood and adolescence: an analysis of 36 patients. J Am Acad Dermatol. 2002;46(6):874-9. KQ5E6. [pmid: 12063484].
347 Schmitt J, Seidler A, Heinisch G, et al. Effectiveness of skin cancer screening for individuals age 14 to 34 years. J Dtsch Dermatol Ges. 2011;9(8):608-16. KQ3E6, KQ4E13. [pmid: 21501381].
348 Schneider JS, Moore DH 2nd, Mendelsohn ML. Screening program reduced melanoma mortality at the Lawrence Livermore National Laboratory 1984 to 1996. J Am Acad Dermatol. 2008;58(5):741-9. KQ1E4, KQ3E4, KQ4E4. [pmid: 18068264].
349 Schneider R. Dermoscopy in melanoma screening. Arch Dermatol. 2002;138(10):1378-9. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 12374550].
350 Schumacher H, Huang S. A 20-year-old basal cell carcinoma. Plast Reconstr Surg. 2005;115(2):668-9. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9. [pmid: 15692395].
351 Schwartz JL, Wang TS, Hamilton TA, et al. Thin primary cutaneous melanomas: associated detection patterns, lesion characteristics, and patient characteristics. Cancer. 2002;95(7):1562-8. KQ4E7. [pmid: 12237926].
352 Scoggins CR, Bowen AL, Martin RC, et al. Prognostic information from sentinel lymph node biopsy in patients with thick melanoma. Arch Surg. 2010;145(7):622-7. KQ5E6, KQ6. [pmid: 20644123].
353 Seetharamu N, Tu TJ, Christos P, et al. Enrollment in clinical trials correlates with improved survival in metastatic melanoma. Oncology. 2011;81(42130):403-9. KQ5E6. [pmid: 22270052].
354 Seidenari S, Arginelli F, Dunsby C, et al. Multiphoton laser tomography and fluorescence lifetime imaging of melanoma: morphologic features and quantitative data for sensitive and specific non-invasive diagnostics. PloS One. 2013;8(7):e70682. KQ3E7. [pmid: 23923016].
355 Seidenari S, Bellucci C, Bassoli S, et al. High magnification digital dermoscopy of basal cell carcinoma: a single-centre study on 400 cases. Acta Derm Venereol. 2014;94(6):677-82. KQ3E6. [pmid: 24682274].
356 Seidenari S, Benati E, Ponti G, et al. Italian Euromelanoma Day Screening Campaign (2005-2007) and the planning of melanoma screening strategies. Eur J Cancer Prev. 2012;21(1):89-95. KQ3E5. [pmid: 22001916].
357 Seidenari S, Longo C, Giusti F, et al. Clinical selection of melanocytic lesions for dermoscopy decreases the identification of suspicious lesions in comparison with dermoscopy without clinical preselection. Br J Dermatol. 2006;154(5):873-9. KQ3E5. [pmid: 16634889].
358 Seo SH, Son SW, Kim IH. Round excisions lead to shorter scars and better scar positioning than traditional elliptical excisions. Dermatology. 2008;217(3):276-80. KQ2E6. [pmid: 18688169].
359 Seregard S. To biopsy or not to biopsy?. Acta Ophthalmol. 2009;87(6):586-7. KQ2E13, KQ6. [pmid: 19719803].
360 Seretis K, Thomaidis V, Karpouzis A, et al. Epidemiology of surgical treatment of nonmelanoma skin cancer of the head and neck in Greece. Dermatol Surg. 2010;36(1):15-22. KQ2E13. [pmid: 19912277].
361 Sewell LD, Marks VJ. Excision of a peristomal basal cell carcinoma using Mohs micrographic surgery. Dermatol Surg. 2008;34(7):971-3. KQ1E9, KQ2E9, KQ3E9, KQ4E9, KQ5E9. [pmid: 18384605].
362 Shalom A, Klein D, Friedman T, et al. Lack of complications in minor skin lesion excisions in patients taking aspirin or warfarin products. Am Surg. 2008;74(4):354-7. KQ2E5. [pmid: 18453305].
363 Shalom A, Wong L. Outcome of aspirin use during excision of cutaneous lesions. Ann Plast Surg. 2003;50(3):296-8. KQ2E5. [pmid: 12800908].
364 Shields CL, Kaliki S, Al-Dahmash SA, et al. American Joint Committee on Cancer (AJCC) clinical classification predicts conjunctival melanoma outcomes. Ophthal Plast Reconstr Surg. 2012;28(5):313-23. KQ5E5, KQ6. [pmid: 22965011].
365 Siao D, Velayos F. Avoiding rash decision making: skin cancer screening of patients with inflammatory bowel disease. Clin Gastroenterol Hepatol. 2014;12(2):274-6. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 24183955].
366 Sibson L, Dunn R, Evans J, et al. The virtual mole clinic: preliminary results from the Plymouth skin cancer screening study using telemedicine. Med Inform Internet Med. 1999;24(3):189-99. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 10654813].
367 Simpson CL. The ABCs of Melanoma: Expanding Basic Screening and Education. Virtual Mentor. 2006;8(8):517-9. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 23234690].
368 Singh S, Stevenson JH, McGurty D. An evaluation of Polaroid photographic imaging for cutaneous-lesion referrals to an outpatient clinic: a pilot study. Br J Plast Surg. 2001;54(2):140-3. KQ3E5. [pmid: 11207125].
369 Slater LJ. Brush biopsy: false negative results. J Oral Maxillofac Surg. 2004;62(6):764. KQ2E13. [pmid: 15181904].
370 Smeets NW, Krekels GA, Ostertag JU, et al. Surgical excision vs Mohs' micrographic surgery for basal-cell carcinoma of the face: randomised controlled trial. Lancet. 2004;364(9447):1766-72. KQ2E6, KQ6. [pmid: 15541449].
371 Smith LC, Cox NH, Dawn G. Shave biopsy without local anaesthetic to diagnose basal cell carcinoma and other skin tumours prior to definitive treatment: analysis of 109 lesions. Br J Dermatol. 2009;160(1):180-2. KQ2E4. [pmid: 18795923].
372 Smith Y, Weinberg A, Klauss S, et al. Improving screening for melanoma by measuring similarity to pre-classified images. Melanoma Res. 2000;10(3):265-72. KQ3E5. [pmid: 10890381].
373 Sneyd MJ. Skin Phenotype and the Impact of Surveillance on Melanoma in New Zealand. Asian Pac J Cancer Prev. 2001;2(1):49-55. KQ1E6. [pmid: 12718654].
374 Sneyd M, Cox B. The control of melanoma in New Zealand. N Z Med J. 2006;119(1242):U2169. KQ1E6. [pmid: 16998570].
375 Soufir N, Grandchamp B, Basset-Seguin N. New trends in the susceptibility to melanoma. Cancer Treat Res. 2009;146:213-23. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 19415206].
376 Soyer HP. Dermoscopy and recently developed imaging techniques. Introduction. Semin Cutan Med Surg. 2009;28(3):141. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 19782936].
377 Soyer HP, Argenziano G, Zalaudek I, et al. Three-point checklist of dermoscopy. A new screening method for early detection of melanoma. Dermatology. 2004;208(1):27-31. KQ3E5. [pmid: 14730233].
378 Soyer HP, Smolle J, Leitinger G, et al. Diagnostic reliability of dermoscopic criteria for detecting malignant melanoma. Dermatology. 1995;190(1):25-30. KQ3E5. [pmid: 7894091].
379 Stang A. Genital and nongenital nonmelanoma skin cancer: more epidemiological studies are needed. J Invest Dermatol. 2007;127(10):2296-9. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17853917].
380 Stang A, Stang K, Stegmaier C, et al. Skin melanoma in Saarland: incidence, survival and mortality 1970-1996. Eur J Cancer Prev. 2001;10(5):407-15. KQ5E6. [pmid: 11711755].
381 Stratman EJ. Overscreening and underscreening for melanoma: comment on “the influence of age and sex on reasons for seeking and expected benefits of skin cancer screening”. Arch Dermatol. 2010;146(10):1102. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 20956640].
382 Swetter SM, Geller AC. Perspective: catch melanoma early. Nature. 2014;515(7527):S117. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 25407708].
383 Swetter SM, Pollitt RA, Johnson TM, et al. Behavioral determinants of successful early melanoma detection: role of self and physician skin examination. Cancer. 2012;118(15):3725-34. KQ4E9. [pmid: 22179848].
384 Swetter SM, Waddell BL, Vazquez MD, et al. Increased effectiveness of targeted skin cancer screening in the Veterans Affairs population of Northern California. Prev Med. 2003;36(2):164-71. KQ1E6, KQ2E6, KQ3E7, KQ4E6, KQ5E6. [pmid: 12590991].
385 Tas F, Keskin S, Karadeniz A, et al. Noncutaneous melanoma have distinct features from each other and cutaneous melanoma. Oncology. 2011;81(42130):353-8. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 22248874].
386 Tavoloni Braga JC, Gomes E, Macedo MP, et al. Early detection of melanoma arising within nevus spilus. J Am Acad Dermatol. 2014;70(2):e31-2. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 24438974].
387 Thomas JM. Lymphoedema in the observation and biopsy arms of MSLT-1. Ann Surg Oncol. 2011:S311. author reply S312-4. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21773841].
388 Thomas JM. Sentinel-node biopsy in melanoma. N Engl J Med. 2007;356(4):418. author reply 419-21. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17251542].
389 Thomas JM. The place of sentinel node biopsy in melanoma after the Multicenter Selective Lymphadenectomy Trial. ANZ J Surg. 2006;76(3):98-9. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 16626339].
390 Thomas JM. Time to re-evaluate sentinel node biopsy in melanoma post-multicenter selective lymphadenectomy trial. J Clin Oncol. 2005;23(36):9443-4. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 16361650].
391 Thompson JF. The value of sentinel node biopsy in patients with primary cutaneous melanoma. Dermatol Surg. 2008;34(4):550-4. discussion 554-5. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 18261107].
392 Thompson LD. Skin basal cell carcinoma. Ear Nose Throat J. 2010;89(9):418-20. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 20859866].
393 Tiplica GS, Olteanu R, Chiriac A, et al. Skin cancer screening campaigns in a Bucharest dermatology clinic. J Eur Acad Dermatol Venereol. 2014;28(3):388-9. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 23676085].
394 Tornberg S, Mansson-Brahme E, Linden D, et al. Screening for cutaneous malignant melanoma: a feasibility study. J Med Screen. 1996;3(4):211-5. KQ3E6. [pmid: 9041488].
395 Toth V, Somlai B, Hatvani Z, et al. Melanoma screening in a Hungarian nuclear power plant. Pathol Oncol Res. 2013;19(2):323-8. KQ1E4, KQ2E4, KQ3E4, KQ4E4, KQ5E4. [pmid: 23242566].
396 Tromme I, Sacre L, Hammouch F, et al. Availability of digital dermoscopy in daily practice dramatically reduces the number of excised melanocytic lesions: results from an observational study. Br J Dermatol. 2012;167(4):778-86. KQ3E4, KQ4E4. [pmid: 22564185].
397 Tryggvadottir L, Gislum M, Hakulinen T, et al. Trends in the survival of patients diagnosed with malignant melanoma of the skin in the Nordic countries 1964-2003 followed up to the end of 2006. Acta Oncol. 2010;49(5):665-72. KQ5E7. [pmid: 20491525].
398 Valachis A, Mauri D, Karampoiki V, et al. Time-trend of melanoma screening practice by primary care physicians: a meta-regression analysis. Ups J Med Sci. 2009;114(1):32-40. KQ3E6. [pmid: 19242870].
399 Valery PC, Neale R, Williams G, et al. The effect of skin examination surveys on the incidence of basal cell carcinoma in a Queensland community sample: a 10-year longitudinal study. J Investig Dermatol Symp Proc. 2004;9(2):148-51. KQ4E6. [pmid: 15083782].
400 van der Eerden PA, Lohuis PJ, Hart AA, et al. Secondary intention healing after excision of nonmelanoma skin cancer of the head and neck: statistical evaluation of prognostic values of wound characteristics and final cosmetic results. Plast Reconstr Surg. 2008;122(6):1747-55. KQ2E4, KQ4E6, KQ6. [pmid: 19050527].
401 van der Leest RJ, de Vries E, Bulliard JL, et al. The Euromelanoma skin cancer prevention campaign in Europe: characteristics and results of 2009 and 2010. J Eur Acad Dermatol Venereol. 2011;25(12):1455-65. KQ1E6, KQ2E6, KQ3E5, KQ4E6. [pmid: 21951235].
402 van der Leest RJ, Nijsten T, de Vries E. Screening for second primary melanomas: is it efficient? Reply from authors. Br J Dermatol. 2013;168(5):1135. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 23614564].
403 Vandaele MM, Richert B, Van der Endt JD, et al. Melanoma screening: results of the first one-day campaign in Belgium (‘melanoma Monday’). J Eur Acad Dermatol Venereol. 2000;14(6):470-2. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 11444268].
404 Varma S. Mobile teledermatology for skin tumour screening. Br J Dermatol. 2011;164(5):939-40. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21518326].
405 Venna SS, Lee D, Stadecker MJ, et al. Clinical recognition of actinic keratoses in a high-risk population: how good are we?. Arch Dermatol. 2005;141(4):507-9. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 15837871].
406 Veronesi A, Pizzichetta MA, De Giacomi C, et al. A two-year regional program for the early detection of cutaneous melanoma. Tumori. 2003;89(1). 5-Jan. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 12729352].
407 Viola KV, Tolpinrud WL, Gross CP, et al. Outcomes of referral to dermatology for suspicious lesions: implications for teledermatology. Arch Dermatol. 2011;147(5):556-60. KQ3E5. [pmid: 21576574].
408 Vogt V, Siegel M, Sundmacher L. Examining regional variation in the use of cancer screening in Germany. Soc Sci Med. 2014;110:74-80. KQ3E6. [pmid: 24727534].
409 Voigt H, Classen R. Topodermatographic image analysis for melanoma screening and the quantitative assessment of tumor dimension parameters of the skin. Cancer. 1995;75(4):981-8. KQ3E7. [pmid: 7842419].
410 Waldmann A, Nolte S, Weinstock MA, et al. Skin cancer screening participation and impact on melanoma incidence in Germany--an observational study on incidence trends in regions with and without population-based screening. Br J Cancer. 2012;106(5):970-4. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 22294187].
411 Wanat KA, Kist J, Jambusaria-Pahlajani A, et al. Improving students' ability to perform skin examinations and detect cutaneous malignancies using standardized patients and moulage. J Am Acad Dermatol. 2013;69(5):816-7. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 24124813].
412 Wang SQ, Kopf AW, Koenig K, et al. Detection of melanomas in patients followed up with total cutaneous examinations, total cutaneous photography, and dermoscopy. J Am Acad Dermatol. 2004;50(1):15-20. KQ3E6, KQ4E6. [pmid: 14699359].
413 Weary PE. Skin cancer screening. J Cutan Med Surg. 1998;3(1):49. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 10026013].
414 Weatherhead SC, Lawrence CM. Melanoma screening clinics: are we detecting more melanomas or reassuring the worried well?. Br J Dermatol. 2006;154(3):539-41. KQ1E6, KQ2E6, KQ3E6, KQ4E7. [pmid: 16445788].
415 Weinstock MA. Progress and prospects on melanoma: the way forward for early detection and reduced mortality. Clin Cancer Res. 2006;12(7 Pt 2):2297s-2300s. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 16609048].
416 Weinstock MA. Point-counterpoint. Mass population skin cancer screening can be worthwhile--(if it's done right). J Cutan Med Surg. 1998;2(3):129-32. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 9556370].
417 Welch HG, Woloshin S, Schwartz LM. Skin biopsy rates and incidence of melanoma: population based ecological study. BMJ. 2005;331(7515):481. KQ2E5, KQ4E5, KQ5E5. [pmid: 16081427].
418 Westerhoff K, McCarthy WH, Menzies SW. Increase in the sensitivity for melanoma diagnosis by primary care physicians using skin surface microscopy. Br J Dermatol. 2000;143(5):1016-20. KQ3E5. [pmid: 11069512].
419 Whited JD, Grichnik JM. The rational clinical examination. Does this patient have a mole or a melanoma?. JAMA. 1998;279(9):696-701. KQ3E2. [pmid: 9496989].
420 Wilde M, Jones B, Lewis BK, et al. Skin cancer screening in the homeless population. Dermatol Online J. 2013;19(1):14. KQ1E6, KQ3E6, KQ4E6. [pmid: 23374956].
421 Wilkes D. The use of dermoscopy in medical photography for the early detection of skin cancer. J Vis Commun Med. 2010;33(4):169-73. KQ3E2. [pmid: 21087188].
422 Williams HA, Fritschi L, Reid A, et al. Who attends skin cancer screening in Western Australia? Results from the Lions Cancer Institute Skin Cancer Screening Program. Aust N Z J Public Health. 2006;30(1):75-80. KQ1E13, KQ3E6, KQ4E6. [pmid: 16502955].
423 Wilson RL, Yentzer BA, Isom SP, et al. How good are US dermatologists at discriminating skin cancers? A number-needed-to-treat analysis. J Dermatolog Treat. 2012;23(1):65-9. KQ3E4, KQ4E4. [pmid: 21756146].
424 Wilson R, Jackson J, Rassekh C. A study of squamous cell carcinoma of the lip at West Virginia University Hospitals from 1980-2000. W V Med J. 2005;101(5):217-9. KQ5E6. [pmid: 16422271].
425 Wolf IH, Smolle J, Soyer HP, et al. Sensitivity in the clinical diagnosis of malignant melanoma. Melanoma Res. 1998;8(5):425-9. KQ3E5. [pmid: 9835456].
426 Wolf JA, Moreau JF, Akilov O, et al. Diagnostic inaccuracy of smartphone applications for melanoma detection. JAMA Dermatol. 2013;149(4):422-6. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 23325302].
427 Wollina U, Burroni M, Torricelli R, et al. Digital dermoscopy in clinical practise: a three-centre analysis. Skin Res Technol. 2007;13(2):133-42. KQ3E5, KQ4E6. [pmid: 17374053].
428 Xing Y, Chang GJ, Hu CY, et al. Conditional survival estimates improve over time for patients with advanced melanoma: results from a population-based analysis. Cancer. 2010;116(9):2234-41. KQ4E6, KQ5E6. [pmid: 20187100].
429 Yiannias JA, Laman SD, Stevens R, et al. Skin cancer prevention in annual performance of total skin examination, photoprotection counseling, and patient instruction of self-skin examination. Int J Dermatol. 2014;53(8):981-4. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 24134438].
430 Youl PH, Baade PD, Parekh S, et al. Association between melanoma thickness, clinical skin examination and socioeconomic status: results of a large population-based study. Int J Cancer. 2011;128(9):2158-65. KQ4E11. [pmid: 20607832].
431 Youl PH, Coxeter PD, Whiteman DC, et al. Screening for skin cancer in Queensland: who attends, and why and where do they attend?. Med J Aust. 2009;190(1):45. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E7. [pmid: 19120011].
432 Youl PH, Janda M, Elwood M, et al. Who attends skin cancer clinics within a randomized melanoma screening program?. Cancer Detect Prev. 2006;30(1):44-51. KQ4E6. [pmid: 16457967].
433 Youl PH, Janda M, Lowe JB, et al. Does the type of promotional material influence men's attendance at skin screening clinics?. Health Promot J Austr. 2005;16(3):229-32. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6. [pmid: 16375040].
434 Zager JS, Hochwald SN, Marzban SS, et al. Shave biopsy is a safe and accurate method for the initial evaluation of melanoma. J Am Coll Surg. 2011;212(4):454-60. discussion 460-2. KQ2E7, KQ3E7. [pmid: 21463767].
435 Zalaudek I, Schmid K, Niederkorn A, et al. Proposal for a clinical-dermoscopic classification of scalp naevi. Br J Dermatol. 2014;170(5):1065-72. KQ3E13. [pmid: 24641327].
436 Zhu JJ, Padillo O, Duff J, et al. Cavernous sinus and leptomeningeal metastases arising from a squamous cell carcinoma of the face: case report. Neurosurgery. 2004;54(2):492-8. discussion 498-9. KQ2E5. [pmid: 14744296].
437 Zogakis TG, Essner R, Wang HJ, et al. Natural history of melanoma in 773 patients with tumor-negative sentinel lymph nodes. Ann Surg Oncol. 2007;14(5):1604-11. KQ5E6, KQ6. [pmid: 17333418].
438 Zogakis TG, Essner R, Wang HJ, et al. Melanoma recurrence patterns after negative sentinel lymphadenectomy. Arch Surg. 2005;140(9):865-71. discussion 871-2. KQ5E13. [pmid: 16172295].