# Ongoing Studies

We identified 4 potentially relevant ongoing randomized controlled clinical trials through four registries: ClinicalTrials.gov (http://clinicaltrials.gov), Current Controlled Trials (http://www.controlled-trials.com), Australian New Zealand Clinical Trials Registry (http://www.anzctr.org.au), and the World Health Organization's International Clinical Trials Registry Platform (http://www.who.int/ictrp). We restricted our searches to “skin cancer” AND screening.

Four studies regarding skin cancer screening were identified from ClinicalTrials.gov. These four studies focused on skin cancer screening efficacy and range from not yet recruiting to recently completed. Two of the studies91, 92 focus on training and education for physicians regarding skin cancer screening. Of these two screening education projects the Skin Cancer Screening Education Study (SCSES) just began recruitment in February 2015. In addition to the two skin cancer screening education trials there are two other potentially relevant ongoing studies: One study addresses the attitudes and barriers93 to skin cancer screening in an academic dermatology clinic and depending on the demographics of the population, may not be considered included (those in dermatologist waiting room may not represent asymptomatic population). The beach based controlled trial94 represents an evaluation of a skin cancer and education program delivered at beaches. This intervention also includes skin cancer prevention education and therefore, depending on the actual methods may not contain the relevant population.

We also used NIH Research portfolio online reporting tools (RePORTer)95 to identify ongoing projects that are currently funded through NIH. From RePORTer we found one potentially relevant currently funded work on skin cancer screening. Comparative Assessments of screening Strategies for Melanoma (5R21CA182241) led by Dr. Sandra J. Lee at the Dana-Farber Cancer Institute, Harvard Medical School. The proposal is centered around research problems arising in the early detection of malignant melanoma with an emphasis on sex-based differences in the early diagnosis of melanoma. The principal research areas include: (i) Investigate the natural history of melanoma and develop stochastic models for early detection of melanoma, (ii) Evaluate the mortality benefit of potential screening programs in the general and high-risk populations, (iii) Establish a pilot database of individuals at high-risk of developing melanoma and evaluate the factors associated with the risk of developing melanoma and of fatal melanoma.

During our bridge search and expert review two additional screening efforts were brought to our attention. These include one US based training program for increasing effectiveness of primary care provider screening.96 This web-based training program aims to increase appropriate diagnosis and management of skin cancer screening. The second screening effort that would be of interest to future research is a French screening campaign.31This cluster randomized controlled trial was a targeted melanoma prevention intervention. This particular paper focused on patient prevention behavior, there may be relevant data from future papers that pertain to effectiveness of skin cancer screening by primary care physicians.