# Detailed Methods

## Search Strategy

Sources Searched
MEDLINE
PUBMED
Cochrane Central Register of Controlled Clinical Trials

Key:

- / = MeSH subject heading
- $ = truncation
- * = truncation
- ? = wildcard
- ab = word in abstract
- ae = adverse effects
- adj# = adjacent within x number of words
- near/# = adjacent within x number of words
- kw = keyword
- mo = mortality
- su = surgery
- ti = word in title

### Cochrane Central Register of Controlled Clinical Trials

#1 (skin or derm* or cutaneous or epithelial or epithelium or epiderm*):ti,ab,kw near/3 (cancer* or neoplasm* or carcinoma* or tumor* or tumour* or malignan* or lesion* or metasta* or dysplas*):ti,ab,kw
#2 melanoma*:ti,ab,kw
#3 (naevoid or nevoid):ti,ab,kw near/3 syndrome*:ti,ab,kw
#4 (dysplastic or malignant):ti,ab,kw near/2 (nevus or naevus or nevi or naevi):ti,ab,kw
#5 “Hutchinson's Melanotic Freckle”:ti,ab,kw
#6 “lentigo maligna”:ti,ab,kw
#7 basal:ti,ab,kw next cell:ti,ab,kw next (carcinoma* or neoplasm* or carcinoma* or tumor* or tumour* or malignan* or lesion* or metasta* or epithelioma*):ti,ab,kw
#8 (basocellular* or basosquamous):ti,ab,kw next carcinoma*:ti,ab,kw
#9 squamous:ti,ab,kw next cell:ti,ab,kw next (carcinoma* or neoplasm* or carcinoma* or tumor* or tumour* or malignan* or lesion* or metasta* or epithelioma*):ti,ab,kw
#10 merkel:ti,ab,kw next cell:ti,ab,kw next (carcinoma* or neoplasm* or carcinoma* or tumor* or tumour* or malignan* or lesion* or metasta* or epithelioma*):ti,ab,kw
#11 “actinic keratosis”:ti,ab,kw
#12 bowen*:ti,ab,kw next disease:ti,ab,kw
#13 cutaneous:ti,ab,kw near/2 lymphoma*:ti,ab,kw
#14 {or, #1-‘#13}
#15 screen*:ti,ab,kw
#16 (skin or body or physical):ti,ab,kw near/3 (exam* or inspect*):ti,ab,kw
#17 (dermoscop* or dermatoscop*):ti,ab,kw
#18 visual*:ti,ab,kw next inspect*:ti,ab,kw
#19 photography:ti,ab,kw
#20 {or #15-#19}
#21 #14 and #20 Publication Year from 1995 to 2015, in Trials
#22 (biopsy* or biopsies or biopsied):ti,ab,kw
#23 (excise* or excision*):ti,ab,kw
#24 rebiops*:ti,ab,kw
#25 #22 or #23 or #24
#26 (harm or harms or harmful or harmed):ti,ab,kw
#27 (death or deaths):ti,ab,kw
#28 (adverse or negative or unintended):ti,ab,kw next (effect* or event* or outcome* or reaction*):ti,ab,kw
#29 complication*:ti,ab,kw
#30 side:ti,ab,kw next effect*:ti,ab,kw
#31 safety:ti,ab,kw
#32 false:ti,ab,kw next negative*:ti,ab,kw
#33 misdiagnos*:ti,ab,kw
#34 overdiagnos*:ti,ab,kw
#35 (unneeded or unnecessary):ti,ab,kw near/5 (treat* or therap* or surg* or procedure*):ti,ab,kw
#36 label*:ti,ab,kw
#37 psychological:ti,ab,kw next effect*:ti,ab,kw
#38 (cicatrix or scar*):ti,ab,kw
#39 {or #26-#38}
#40 #14 and #25 and #39 Publication Year from 1995 to 2015, in Trials
#41 (detect* or diagnos* or biops*):ti,ab,kw near/5 stage:ti,ab,kw
#42 (late* or distant or advanced or end):ti,ab,kw next stage:ti,ab,kw
#43 (early or earlier):ti,ab,kw next (diagnos* or detect* or discovery or findings):ti,ab,kw
#44 #41 or #42 or #43
#45 #14 and #44 Publication Year from 1995 to 2015, in Trials
#46 (surger* or surgical):ti
#47 curettage:ti,ab,kw
#48 dessicat*:ti,ab,kw
#49 electrodessicat*:ti,ab,kw
#50 cryosurg*:ti,ab,kw
#51 “laser ablation”:ti,ab,kw
#52 mohs:ti,ab,kw
#53 metastasectom*:ti,ab,kw
#54 lymphadenectom*:ti,ab,kw
#55 (“lymph node” or “lymph nodes” or lymphoid):ti,ab,kw near/3 (remov* or dissect* or resect*):ti,ab,kw
#56 {or #46-#55}
#57 (lymphedema or lymphoedema):ti,ab,kw
#58 (surg* or postsurg* or post-surg*):ti,ab,kw near/2 infect*:ti,ab,kw
#59 {or #26-#31, #38, #57-#58}
#60 #14 and #56 and #59 Publication Year from 1995 to 2015, in Trials 1
#61 #21 or #40 or #45 or #60

### MEDLINE search strategy

Database: Ovid MEDLINE(R) <1946 to July Week 3 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <June 1, 2015>, Ovid MEDLINE(R) Daily Update <June 1, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Skin Neoplasms/
2. Melanoma/
3. Melanoma, Amelanotic/
4. Nevus/
5. Dysplastic Nevus Syndrome/
6. Hutchinson's Melanotic Freckle/
7. Carcinoma, Basal Cell/
8. Carcinoma, Squamous Cell/
9. Carcinoma, Merkel Cell/
10. Neoplasms, Basal Cell/
11. Neoplasms, Squamous Cell/
12. “Neoplasms, Adnexal and Skin Appendage”/
13. Actinic keratosis/
14. Bowen disease/
15. Lymphoma, T-Cell, Cutaneous/
16. ((skin or derm$ or cutaneous or epithelial or epithelium or epiderm$) adj3 (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or dysplas$)).ti.
17. melanoma$.ti.
18. ((naevoid or nevoid) adj3 syndrome$).ti.
19. ((dysplastic or malignant) adj2 (nevus or naevus or nevi or naevi)).ti.
20. Hutchinson$ Melanotic Freckle.ti.
21. lentigo maligna.ti.
22. (basal cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti.
23. ((basocellular$ or basosquamous) adj carcinoma$).ti.
24. (squamous cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti.
25. (merkel cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti.
26. actinic keratosis.ti.
27. bowen$ disease.ti.
28. (cutaneous adj2 lymphoma$).ti.
29. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28
30. ((skin or derm$ or cutaneous or epithelial or epithelium or epiderm$) adj3 (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or dysplas$)).ti,ab.
31. melanoma$.ti,ab.
32. ((naevoid or nevoid) adj3 syndrome$).ti,ab.
33. ((dysplastic or malignant) adj2 (nevus or naevus or nevi or naevi)).ti,ab.
34. Hutchinson$ Melanotic Freckle.ti,ab.
35. lentigo maligna.ti,ab.
36. (basal cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti,ab.
37. ((basocellular$ or basosquamous) adj carcinoma$).ti,ab.
38. (squamous cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti,ab.
39. (merkel cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti,ab.
40. actinic keratosis.ti,ab.
41. bowen$ disease.ti,ab.
42. (cutaneous adj2 lymphoma$).ti,ab.
43. 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42
44. limit 43 to (“in data review” or in process or “pubmed not medline”)
45. 29 or 44
46. Mass screening/
47. Early detection of Cancer/
48. (screen$ or detect$).ti,ab.
49. 46 or 47 or 48
50. Physical Examination/
51. Dermoscopy/
52. Photography/
53. ((skin or body or physical) adj3 (exam$ or inspect$)).ti,ab.
54. visual$ inspect$.ti,ab.
55. dermoscop$.ti,ab.
56. dermatoscop$.ti,ab.
57. photography.ti,ab.
58. 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57
59. 45 and 49 and 58
60. screen$.ti.
61. 45 and 60
62. 59 or 61
63. limit 62 to (english language and yr=“1995 -Current”)
64. remove duplicates from 63
65. Biopsy/
66. Biopsy, Needle/
67. Biopsy, Large-Core Needle/
68. Sentinel Lymph Node Biopsy/
69. (biopsy$ or biopsies or biopsied).ti,ab.
70. (excise* or excision$).ti,ab.
71. rebiopsy.ti,ab.
72. 65 or 66 or 67 or 68 or 69 or 70 or 71
73. (harm or harms or harmful or harmed).ti,ab.
74. (adverse effects or mortality).fs.
75. Mortality/
76. Morbidity/
77. death/
78. (death or deaths).ti,ab.
79. ((adverse or negative or unintended) adj (effect$ or event$ or outcome$ or reaction$)).ti,ab.
80. complication$.ti,ab.
81. side effect$.ti,ab.
82. safety.ti,ab.
83. false negative$.ti,ab.
84. misdiagnos$.ti,ab.
85. overdiagnos$.ti,ab.
86. ((unneeded or unnecessary) adj5 (treat$ or therap$ or surg$ or procedure$)).ti,ab.
87. label$.ti,ab.
88. psychological effect$.ti,ab.
89. Cicatrix/
90. (cicatrix or scar$).ti,ab.
91. 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90
92. 45 and 72 and 91
93. limit 92 to (english language and yr=“1995 -Current”)
94. remove duplicates from 93
95. Neoplasm Staging/
96. ((detect$ or diagnos$ or biops$) adj5 stage).ti,ab.
97. ((late$ or distant or advanced or end) adj stage).ti,ab.
98. ((early or earlier) adj (diagnos$ or detect$ or discovery or findings)).ti,ab.
99. 95 or 96 or 97 or 98
100. Registries/
101. Survival Analysis/
102. SEER program/
103. Morbidity/
104. Mortality/
105. Death/
106. mo.fs.
107. (registr$ or register$).ti,ab.
108. SEER.ti,ab.
109. “Surveillance epidemiology and end results”.ti,ab.
110. morbidit$.ti,ab.
111. mortalit$.ti,ab.
112. (death or deaths).ti,ab.
113. survival.ti,ab.
114. 110 or 111 or 112 or 113
115. limit 114 to (“in data review” or in process or “pubmed not medline”)
116. 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 115
117. 45 and 99 and 116
118. limit 117 to (english language and yr=“1995 -Current”)
119. remove duplicates from 118
120. Dermatologic Surgical Procedures/ ]
121. Curettage/
122. Dessication/
123. Cryosurgery/
124. Laser Therapy/
125. Mohs Surgery/
126. Lymph Node Excision/
127. (surger$ or surgical).ti.
128. curettage.ti,ab.
129. dessicat$.ti,ab.
130. electrodessicat$.ti,ab.
131. cryosurg$.ti,ab.
132. laser ablation.ti,ab.
133. mohs.ti,ab.
134. metastasectom$.ti,ab.
135. lymphadenectom$.ti,ab.
136. ((lymph node$ or lymphoid) adj3 (remov$ or dissect$ or resect$)).ti,ab.
137. 127 or 128 or 129 or 130 or 131 or 132 or 133 or 134 or 135 or 136
138. limit 137 to (“in data review” or in process or “pubmed not medline”)
139. 120 or 121 or 122 or 123 or 124 or 125 or 126 or 138
140. 45 and 139
141. Skin Neoplasms/su
142. Melanoma/su
143. Melanoma, Amelanotic/su
144. Nevus/su
145. Dysplastic Nevus Syndrome/su
146. Hutchinson's Melanotic Freckle/su
147. Carcinoma, Basal Cell/su
148. Carcinoma, Squamous Cell/su
149. Carcinoma, Merkel Cell/su
150. Neoplasms, Basal Cell/su
151. Neoplasms, Squamous Cell/su
152. “Neoplasms, Adnexal and Skin Appendage”/su
153. Actinic keratosis/su
154. Bowen disease/su
155. Lymphoma, T-Cell, Cutaneous/su
156. 140 or 141 or 142 or 143 or 144 or 145 or 146 or 147 or 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155
157. Lymphedema/
158. Lymph?edema.ti,ab.
159. Surgical wound infection/
160. ((surg$ or postsurg$ or post-surg$) adj2 infect$).ti,ab.
161. 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 89 or 90 or 157 or 158 or 159 or 160
162. 156 and 161
163. limit 162 to (english language and yr=“1995 -Current”)
164. 64 or 94 or 119 or 163
165. Animal/ not (Animal/ and Human/)
166. 164 not 165
167. (oral or tongue or larynx or laryng$ or hypolaryng$ or oropharyng$ or pharynx or pharyng$ or esophag$ or oesophag$ or gastric or ovary or ovaries or ovarian or cervical or cervix or endometrium or endometrial or lung or breast or ocular or vulva$ or anus or anal or mucosal).ti.
168. 166 not 167

### PubMed search strategy [publisher-supplied references only]

Search | Query
#62 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((#61) AND publisher[sb]) AND English[Language]) AND (“1995”[Date - Publication] : “3000”[Date - Publication])
#61 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #12 AND #60
#60 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #17 OR #34 OR #44 OR #59
#59 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #55 AND #58
#58 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #22 OR #23 OR #24 OR #25 OR #26 OR #32 OR #56 OR #57
#57 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (surg*[tiab] OR postsurg*[tiab] OR post surg*[tiab]) AND infect*[tiab]
#56 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search lymphedema[tiab] OR lymphoedema[tiab]
#55 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51 OR #52 OR #53 OR #54
#54 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (lymph node*[tiab] OR lymphoid[tiab]) AND (remov*[tiab] OR dissect*[tiab] OR resect*[tiab])
#53 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search lymphadenectomy*[tiab]
#52 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search metastasectom*[tiab]
#51 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search mohs[tiab]
#50 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search laser ablation[tiab]
#49 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search cryosurg*[tiab]
#48 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search electrodessicat*[tiab]
#47 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search dessicat*[tiab]
#46 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search curettage[tiab]
#45 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search surger*[ti] OR surgical[ti]
#44 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #38 AND #43
#43 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #39 OR #40 OR #41 OR #42
#42 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search survival[tiab]
#41 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search morbidity[tiab] OR mortality[tiab] OR death[tiab] OR deaths[tiab]
#40 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search SEER[tiab] OR surveillance epidemiology[tiab]
#39 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search registr*[tiab] OR register*[tiab]
#38 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #35 OR #36 OR #37
#37 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search early diagnos*[tiab] OR early detection[tiab] OR earlier diagnos*[tiab] OR earlier detection[tiab] OR diagnosed earl*[tiab] OR detected earl*[tiab]
#36 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search late stage[tiab] OR distant stage[tiab]
#35 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (detect*[tiab] OR diagnos*[tiab] OR biops*[tiab]) AND stage[tiab]
#34 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #21 AND #33
#33 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search scar*[tiab] OR cixatrix[tiab]
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search psychological effect*[tiab]
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search label*[tiab]
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((unneeded[tiab] OR unnecessary[tiab]) AND (treat*[tiab] OR therap*[tiab] OR surg*[tiab] OR procedure*[tiab]))
#28 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search misdiagnos*[tiab] OR overdiagnos*[tiab]
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search false negative[tiab]
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search safety[tiab]
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search side effect*[tiab]
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search complication*[tiab]
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search adverse effect*[tiab] OR adverse event*[tiab] OR adverse outcome*[tiab] OR adverse reaction*[tiab]
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search death[tiab] OR deaths[tiab] OR harm[tiab] OR harms[tiab] OR harmful[tiab] OR harmed[tiab]
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #18 OR #19 OR #20
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search rebiopsy[tiab]
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search excise*[tiab] OR excision*[tiab]
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search biopsy*[tiab] OR biopsies[tiab] OR biopsied[tiab]
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #13 OR #14 OR #15 OR #16
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search dermoscop*[tiab] OR dermatoscop*[tiab] OR photography[tiab]
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search visual inspect*[tiab] OR visually inspect[tiab]
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search skin exam*[tiab] OR body exam*[tiab] OR physical exam*[tiab]
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search screen*[tiab]
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search cutaneous[ti] AND lymphoma*[ti]
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search bowen disease[ti]
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search actinic keratosis[ti]
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search basocellular carcinoma*[ti] OR basosquamous carcinoma*[ti]
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (basal[ti] OR squamous[ti] OR merkel[ti]) AND (cancer*[ti] OR neoplasm*[ti] OR carcinoma*[ti] OR tumor*[ti] OR tumour*[ti] OR malignan[ti] OR lesion[ti] OR metasta*[ti] OR epithelioma*[ti])
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “lentigo maligna”[ti]
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “hutchinson's melanotic freckle”[ti]
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (dysplastic[ti] or malignant[ti]) AND (nevus[ti] OR naevus[ti] OR nevi[ti] OR naevi[ti])
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (naevoid[ti] or nevoid[ti]) AND syndrome*[ti]
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search melanoma*[ti]
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (skin[ti] or derm*[ti] or cutaneous[ti] or epithelial[ti] or epiderm*[ti]) AND (cancer*[ti] or neoplasm*[ti] or carcinoma*[ti] or tumor*[ti] or tumour*[ti] or malignan*[ti] or lesion*[ti] or metasta*[ti])

Appendix A Figure 1 Literature Flow Diagram

1 Number of articles that were not included in prior review: KQ1=3; KQ2=3; KQ3=1; KQ4=1; KQ5=8

Appendix Figure 1 is a flow chart that summarizes the search and selection of articles. There were 12,225 citations identified through literature databases. An additional 289 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 12,514 unique citations were reviewed at the title/abstract stage. The full text of 453 citations were examined for inclusion for one or more of the five Key Questions.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Population | Asymptomatic adults age 15 years and older | - Persons younger than age 15 years; - People already under surveillance for skin cancer due to previous skin or other cancer
Settings | Primary care-relevant, countries with a United Nations Human Development Index score of ≥0.9
Screening tests | Total or partial visual skin examination conducted by primary care providers or dermatologists with or without tools to aid examination (for example but not limited to, dermatoscopy; whole body photography) | - Diagnostic skin examinations in response to patient concern; - Skin self-screening by individuals or partners; - Physician counseling for self-screening
Comparison | KQs 1, 2: No visual skin examination KQ 3: Biopsy KQ 4: Usual care KQ 5: Stage at detection
Outcomes | KQs 1, 5: Morbidity associated with any skin cancer (including melanoma in situ, dysplastic nevi, actinic keratosis) including quality of life; skin cancer mortality; or all-cause mortality KQ 2: Any harm from screening, biopsy, or excision including over-diagnosis, psychosocial harms, or procedure-related adverse events KQ 3: Sensitivity, specificity, positive predictive value, false positive, false negative, cancer detection rates KQ 4: Lesion thickness or stage at diagnosis | Non-skin location Intermediate or health outcomes relating clinician skin examination to other risk behaviors (e.g., self-screening, sun protective behaviors) or measures of doctor-patient relationship quality
Study design | Fair- to good-quality studies published since January 1, 1995 to March 31, 2015. Systematic reviews (of included study designs); randomized, controlled trials; selected well-designed controlled clinical trials; observational studies including cohort and case-control studies; ecologic studies KQs 2: Same as above and including harms of screening case series | Poor-quality studies with a fatal flaw; studies outside of the publication window; case reports and case series (except as noted for KQs 2 and 6); decision analyses

Appendix A Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized controlled trials, adapted from the USPSTF methods50 | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were measurements equal, valid and reliable?; - Was there intervention fidelity?; - Was there adequate adherence to the intervention?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there evidence of selective reporting of outcomes?; - Was the device calibration and/or maintenance reported?
Ecologic studies adapted from Dufault 2011^51^ and Tu 2008^52^ | - A priori information: is the identified ecological relationship between the exposure and the outcomes biologically plausible and consistent which what is already known about a given topic at an individual subject level?; - Adequate sample size; - Level of aggregation appropriate / are the subjects in the ecologic study representative of the group, place or population of interest?; - Level of inference (individual, ecologic, unclear); - Pre-specification of ecologic units; - Classification of primary outcomes; were the exposure and outcome variables measured and defined in a similar or same way across the different populations or groups that are being studied?; - Analytic methodology: would it be practical to conduct alternative ways of studying the same question? Or was the ecologic study the only alternative?; - Validity of regression; - Use of covariates; have the data been collected on important confounding variables that might also explain the exposure-outcome relationship and have they been statistically adjusted for? If data are not available on key factors, is it reasonable to assume that heir prevalence is similar in the different groups or populations being compared?; - Discussion of cross-level bias / have the investigators interpreted their data with appropriate caveats? Did they acknowledge the possibility of an ecological fallacy? Were alternative explanations for the association between the exposure and outcomes considered by the investigators?; - Have the study data been collected at multiple levels? If yes, was multilevel modeling considered or used for analyzing the data?

Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.