# References

1 Nelson HD, Glass N, Huffman L, et al. Screening for syphilis: brief update for the US Preventive Services Task Force. Rockville (MD). Agency for Healthcare Research and Quality. 2004.
2 Calonge N, U. S. Preventive Services Task Force. Screening for syphilis infection: recommendation statement. [Erratum appears in Ann Fam Med. 2004 Sep-Oct;2(5):517]. Ann Fam Med. 2004;2(4):362-5. [pmid: 15335137].
3 Centers for Disease Control and Prevention. STD Surveillance Case Definitions. Available at: http://www.cdc.gov/std/stats/CaseDefinitions-2014.pdf. February 27, 2015.
4 Hicks C. Diagnostic testing for syphilis. Available at: http://www.uptodate.com/contents/diagnostic-testing-for-syphilis. January 14, 2015.
5 Gjestland T. The Oslo study of untreated syphilis; an epidemiologic investigation of the natural course of the syphilitic infection based upon a re-study of the Boeck-Bruusgaard material. Acta Derm Venereol Suppl (Stockh). 1955;35(Suppl 34):3-368. Annex I-LVI. [pmid: 13301322].
6 Workowski KA, Bolan GA. Sexually transmitted diseases treatment guidelines, 2015. MMWR Recommendations and reports : Morbidity and mortality weekly report Recommendations and reports / Centers for Disease Control. 2015;64(RR-03):1-137. [pmid: 26042815].
7 Shah BB, Lang AE. Acquired neurosyphilis presenting as movement disorders. Mov Disord. 2012;27(6):690-5. [pmid: 22410849].
8 Centers for Disease Control and Prevention. Sexually transmitted disease surveillance 2014. Atlanta, GA. Department of Health and Human Services. 2015. Available at: http://www.cdc.gov/std/stats14/surv-2014-print.pdf. March 9, 2016.
9 Beranard Roizman. Infectious Diseases in an Age of Change: The Impact of Human Ecology and Behavior on Disease Transmission. Washington, DC. The National Academies Press. 1995.
10 Moore MB Jr., Price EV, Knox JM, et al. EPIDEMIOLOGIC TREATMENT OF CONTACTS TO INFECTIOUS SYPHILIS. Public health reports. (Washington, DC : 1974). 1963;78:966-70. [pmid: 14084872].
11 Schroeter AL, Turner RH, Lucas JB, et al. Therapy for incubating syphilis. Effectiveness of gonorrhea treatment. JAMA. 1971;218(5):711-3. [pmid: 5171497].
12 Buchacz K, Patel P, Taylor M, et al. Syphilis increases HIV viral load and decreases CD4 cell counts in HIV-infected patients with new syphilis infections. Aids. 2004;18(15):2075-9. [pmid: 15577629].
13 Kofoed K, Gerstoft J, Mathiesen LR, et al. Syphilis and human immunodeficiency virus (HIV)-1 coinfection: influence on CD4 T-cell count, HIV-1 viral load, and treatment response. Sex Transm Dis. 2006;33(3):143-8. [pmid: 16505739].
14 Palacios R, Jimenez-Onate F, Aguilar M, et al. Impact of syphilis infection on HIV viral load and CD4 cell counts in HIV-infected patients. J Acquir Immune Defic Syndr. 2007;44(3):356-9. [pmid: 17159654].
15 Owusu-Edusei K Jr., Chesson HW, Gift TL, et al. The estimated direct medical cost of selected sexually transmitted infections in the United States, 2008. Sex Transm Dis. 2013;40(3):197-201. [pmid: 23403600].
16 Van Wagoner NJ, Harbison HS, Drewry J, et al. Characteristics of women reporting multiple recent sex partners presenting to a sexually transmitted disease clinic for care. Sex Transm Dis. 2011;38(3):210-5. [pmid: 20966829].
17 Mayer KH, Bush T, Henry K, et al. Ongoing sexually transmitted disease acquisition and risk-taking behavior among US HIV-infected patients in primary care: implications for prevention interventions. Sex Transm Dis. 2012;39(1):1-7. [pmid: 22183836].
18 Brodsky JL, Samuel MC, Mohle-Boetani JC, et al. Syphilis outbreak at a California men's prison, 2007-2008: propagation by lapses in clinical management, case management, and public health surveillance. J Correct Health Care. 2013;19(1):54-64. [pmid: 22989493].
19 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2011. Atlanta, GA. Department of Health and Human Services. 2012. Available at: http://www.cdc.gov/std/stats11/Surv2011.pdf. January 14, 2015.
20 Weinstock H, Berman S, Cates W Jr. Sexually transmitted diseases among American youth: incidence and prevalence estimates, 2000. Perspect Sex Reprod Health. 2004;36(1):6-10. [pmid: 14982671].
21 Marx R, Aral SO, Rolfs RT, et al. Crack, sex, and STD. Sex Transm Dis. 1991;18(2):92-101. [pmid: 1862466].
22 Recommendations for partner services programs for HIV infection, syphilis, gonorrhea, and chlamydial infection. MMWR Recomm Rep. 2008;57(Rr-9):1-83. quiz CE1-4.
23 Blank S, McDonnell DD, Rubin SR, et al. New approaches to syphilis control. Finding opportunities for syphilis treatment and congenital syphilis prevention in a women's correctional setting. Sex Transm Dis. 1997;24(4):218-26. [pmid: 9101633].
24 Centers for Disease C, Prevention. Discordant results from reverse sequence syphilis screening--five laboratories, United States, 2006-2010. MMWR Morb Mortal Wkly Rep. 2011;60(5):133-7. [pmid: 21307823].
25 Ratnam S. The laboratory diagnosis of syphilis. The Canadian journal of infectious diseases & medical microbiology. Journal canadien des maladies infectieuses et de la microbiologie medicale / AMMI Canada. 2005;16(1):45-51.
26 American Association for Clinical Chemistry. Syphilis Tests. Available at: http://labtestsonline.org/understanding/analytes/syphilis/tab/test. June 22, 2015.
27 U.S. Food and Drug Administration. FDA grants CLIA waiver expanding the availability of rapid screening test for syphilis. FDA News Release. U.S. department of Health and Human Services. Available at: http://www.fda.gov/newsevents/newsroom/pressannouncements/ucm426843.htm. May 6, 2015.
28 Binnicker MJ, Jespersen DJ, Rollins LO. Direct comparison of the traditional and reverse syphilis screening algorithms in a population with a low prevalence of syphilis. J Clin Microbiol. 2012;50(1):148-50. [pmid: 22090407].
29 Diagnostics Direct LLC. 510(k) Substantial Equivalence Determination Decision Summary #K102400. Available at: http://www.accessdata.fda.gov/cdrh_docs/reviews/k102400.pdf. May 19, 2015.
30 Sena AC, White BL, Sparling PF. Novel Treponema pallidum serologic tests: a paradigm shift in syphilis screening for the 21st century. Clin Infect Dis. 2010;51(6):700-8. [pmid: 20687840].
31 Marangoni A, Sambri V, Accardo S, et al. Evaluation of LIAISON Treponema Screen, a novel recombinant antigen-based chemiluminescence immunoassay for laboratory diagnosis of syphilis. Clin Diagn Lab Immunol. 2005;12(10):1231-4. [pmid: 16210488].
32 Binnicker MJ, Jespersen DJ, Rollins LO. Treponema-specific tests for serodiagnosis of syphilis: comparative evaluation of seven assays. J Clin Microbiol. 2011;49(4):1313-7. [pmid: 21346050].
33 Tucker JD, Bu J, Brown LB, et al. Accelerating worldwide syphilis screening through rapid testing: a systematic review. Lancet Infect Dis. 2010;10(6):381-6. [pmid: 20510278].
34 Park IU, Chow JM, Bolan G, et al. Screening for syphilis with the treponemal immunoassay: analysis of discordant serology results and implications for clinical management. J Infect Dis. 2011;204(9):1297-304. [pmid: 21930610].
35 Mahoney JF, Arnold RC, Harris A. Penicillin Treatment of Early Syphilis-A Preliminary Report. American journal of public health and the nation's health. 1943;33(12):1387-91.
36 Douglas JM Jr. Penicillin treatment of syphilis: clearing away the shadow on the land. JAMA. 2009;301(7):769-71. [pmid: 19224755].
37 Mattei PL, Beachkofsky TM, Gilson RT, et al. Syphilis: a reemerging infection. Am Fam Physician. 2012;86(5):433-40. [pmid: 22963062].
38 Ghanem KG, Erbelding EJ, Cheng WW, et al. Doxycycline compared with benzathine penicillin for the treatment of early syphilis. Clin Infect Dis. 2006;42(6):e45-9. [pmid: 16477545].
39 Wong T, Singh AE, De P. Primary syphilis: serological treatment response to doxycycline/tetracycline versus benzathine penicillin. Am J Med. 2008;121(10):903-8. [pmid: 18823862].
40 Hook EW 3rd, Roddy RE, Handsfield HH. Ceftriaxone therapy for incubating and early syphilis. J Infect Dis. 1988;158(4):881-4. [pmid: 3171231].
41 Riedner G, Rusizoka M, Todd J, et al. Single-dose azithromycin versus penicillin G benzathine for the treatment of early syphilis. N Engl J Med. 2005;353(12):1236-44. [pmid: 16177249].
42 Hook EW 3rd, Martin DH, Stephens J, et al. A randomized, comparative pilot study of azithromycin versus benzathine penicillin G for treatment of early syphilis. Sex Transm Dis. 2002;29(8):486-90. [pmid: 12172535].
43 Hook EW 3rd, Behets F, Van Damme K, et al. A phase III equivalence trial of azithromycin versus benzathine penicillin for treatment of early syphilis. J Infect Dis. 2010;201(11):1729-35. [pmid: 20402591].
44 Lukehart SA, Godornes C, Molini BJ, et al. Macrolide resistance in Treponema pallidum in the United States and Ireland. N Engl J Med. 2004;351(2):154-8. [pmid: 15247355].
45 Mitchell SJ, Engelman J, Kent CK, et al. Azithromycin-resistant syphilis infection: San Francisco, California, 2000-2004. Clin Infect Dis. 2006;42(3):337-45. [pmid: 16392078].
46 Su J, Hook E, Kenney K. Prevalence of the 23S rRNA point mutation in Treponema pallidum in the United States and Associated Factors, 2006--2008. 18th International Society for Sexually Transmitted Diseases Research,# OS1. 11.03. London, England. June. 2009.
47 Ballard RC, Berman SM, Fenton KA. Azithromycin versus penicillin for early syphilis. The New England journal of medicine. 2006;354(2):203-5. author reply -5. [pmid: 16407519].
48 Ghanem KG, Erbelding EJ, Wiener ZS, et al. Serological response to syphilis treatment in HIV-positive and HIV-negative patients attending sexually transmitted diseases clinics. Sex Transm Infect. 2007;83(2):97-101. [pmid: 16943224].
49 Beltran VM, Harrison KM, Hall HI, et al. Collection of social determinant of health measures in U.S. national surveillance systems for HIV, viral hepatitis, STDs, and TB. Public Health Rep. Suppl 3. 2011;126:41-53. [pmid: 21836737].
50 Tao G, Irwin KL. Receipt of HIV and STD testing services during routine general medical or gynecological examinations: variations by patient sexual risk behaviors. Sex Transm Dis. 2008;35(2):167-71. [pmid: 18090177].
51 Physicians AAoF. Syphilis. Available at: http://www.aafp.org/patient-care/clinical-recommendations/all/syphilis.html. June 22, 2015.
52 Burstein G, Jacobs A, Kissin D, et al. Changes in the 2010 STD Treatment Guidelines: What Adolescent Health Care Providers Should Know. American Congress of Obstetricians and Gynecologists. Washington, DC. Available at: https://www2.aap.org/sections/adolescenthealth/pdfs/STD%20Article%20Feb%202011.pdf. June 22, 2015.
53 Services USDoHaH. Guide for HIV/Aids Clinical Care. HRSA. Available at: http://hab.hrsa.gov/deliverhivaidscare/2014guide.pdf. June 22, 2015.
54 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
55 U.S. Preventive Services Task Force. Procedure Manual. Available at: http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. November 6, 2015.
56 Bissessor M, Fairley CK, Leslie D, et al. Frequent screening for syphilis as part of HIV monitoring increases the detection of early asymptomatic syphilis among HIV-positive homosexual men. J Acquir Immune Defic Syndr. 2010;55(2):211-6. [pmid: 20585261].
57 Cohen CE, Winston A, Asboe D, et al. Increasing detection of asymptomatic syphilis in HIV patients. Sex Transm Infect. 2005;81(3):217-9. [pmid: 15923288].
58 Zou H, Fairley CK, Guy R, et al. Automated, computer generated reminders and increased detection of gonorrhoea, chlamydia and syphilis in men who have sex with men. PLoS One. 2013;8(4):e61972. [pmid: 23613989].
59 Bissessor M, Fairley CK, Leslie D, et al. Use of a computer alert increases detection of early, asymptomatic syphilis among higher-risk men who have sex with men. Clin Infect Dis. 2011;53(1):57-8. [pmid: 21653303].
60 Wong EH, Klausner JD, Caguin-Grygiel G, et al. Evaluation of an IgM/IgG sensitive enzyme immunoassay and the utility of index values for the screening of syphilis infection in a high-risk population. Sex Transm Dis. 2011;38(6):528-32. [pmid: 21233789].
61 Tsang RS, Martin IE, Lau A, et al. Serological diagnosis of syphilis: comparison of the Trep-Chek IgG enzyme immunoassay with other screening and confirmatory tests. FEMS Immunol Med Microbiol. 2007;51(1):118-24. [pmid: 17854473].
62 Juarez-Figueroa L, Uribe-Salas F, Garcia-Cisneros S, et al. Evaluation of a rapid strip and a particle agglutination tests for syphilis diagnosis. Diagn Microbiol Infect Dis. 2007;59(2):123-6. [pmid: 17574784].
63 Mishra S, Boily MC, Ng V, et al. The laboratory impact of changing syphilis screening from the rapid-plasma reagin to a treponemal enzyme immunoassay: a case-study from the Greater Toronto Area. Sex Transm Dis. 2011;38(3):190-6. [pmid: 20706176].
64 Horberg MA, Ranatunga DK, Quesenberry CP, et al. Syphilis epidemiology and clinical outcomes in HIV-infected and HIV-uninfected patients in Kaiser Permanente Northern California. Sex Transm Dis. 2010;37(1):53-8. [pmid: 19734820].
65 Baffi CW, Aban I, Willig JH, et al. New syphilis cases and concurrent STI screening in a southeastern U.S. HIV clinic: a call to action. AIDS Patient Care STDS. 2010;24(1):23-9. [pmid: 20095902].
66 Hoover KW, Butler M, Workowski K, et al. STD screening of HIV-infected MSM in HIV clinics. Sex Transm Dis. 2010;37(12):771-6. [pmid: 20585275].
67 Mayer KH, Wang L, Koblin B, et al. Concomitant socioeconomic, behavioral, and biological factors associated with the disproportionate HIV infection burden among Black men who have sex with men in 6 U.S. cities. PLoS One. 2014;9(1):e87298. [pmid: 24498067].
68 Yang B, Hallmark CJ, Huang JS, et al. Characteristics and risk of syphilis diagnosis among HIV-infected male cohort: a population-based study in Houston, Texas. Sex Transm Dis. 2013;40(12):957-63. [pmid: 24220358].
69 Centers for Disease Control and Prevention. Sexually transmitted disease surveillance 2013. Atlanta, GA. Department of Health and Human Services. 2014. Available at: http://www.cdc.gov/std/stats13/surv2013-print.pdf. April 3, 2015.
70 Kahn RH, Peterman TA, Arno J, et al. Identifying likely syphilis transmitters: implications for control and evaluation. Sex Transm Dis. 2006;33(10):630-5. [pmid: 16601660].
71 Finelli L, Farley TP, Gibson JJ, et al. Prevalence monitoring in syphilis surveillance: results from a multicenter research program. Sex Transm Dis. 2002;29(12):769-74. [pmid: 12466718].
72 Kahn RH, Voigt RF, Swint E, et al. Early syphilis in the United States identified in corrections facilities, 1999-2002. Sex Transm Dis. 2004;31(6):360-4. [pmid: 15167646].
73 Larsen SA, Steiner BM, Rudolph AH. Laboratory diagnosis and interpretation of tests for syphilis. Clin Microbiol Rev. 1995;8(1):1-21. [pmid: 7704889].
74 Aberg JA, Kaplan JE, Libman H, et al. Primary care guidelines for the management of persons infected with human immunodeficiency virus: 2009 update by the HIV medicine Association of the Infectious Diseases Society of America. Clin Infect Dis. 2009;49(5):651-681. [pmid: 19640227].