# Discussion

## Summary of Review Findings

Targeted screening for syphilis in persons at increased risk of infection based on sociodemographic factors is currently recommended by the USPSTF and other groups and is the standard of practice in the United States.2 Routine screening in asymptomatic persons not at increased risk for syphilis infection is not recommended. Previous recommendations were based on various levels of evidence indicating that screening provides earlier identification and treatment of infections and reduces adverse health outcomes and transmission.

A summary of evidence for this update is provided in Table 7. No new studies were identified that determined the effectiveness of screening or described the harms of screening, consistent with results of prior reviews. However, four observational studies evaluated detection rates using specific screening intervals in MSM or HIV-positive populations (Key Question 1).56-59 Results from these studies indicated that testing for syphilis every 3 months identified more new cases of infection in MSM or men living with HIV compared with screening every 6 or 12 months. Detection rates were higher for early syphilis (8.1% vs. 3.1%; p=0.001),56 newly acquired syphilis (7.3 cases [95% CI, 5.2 to 9.9] vs. 2.8 cases [95% CI, 1.8 to 4.0] per 1,000 patient-years; p<0.05),57 early latent syphilis (1.7% vs. 0.4%; p=0.008),58 and early syphilis among higher-risk MSM (53% vs. 16%; p=0.001).59 These studies were all conducted outside the United States and are limited by their study designs, sample sizes, and clinical applicability to U.S. populations and other high-risk population subgroups. Importantly, the generalizability of these studies may be limited to MSM or men living with HIV as no studies on other population subgroups were identified. No studies were conducted specifically in adolescent populations.

Table 7 Summary of Evidence

Main findings from prior USPSTF reviews | Number/type of studies in update | Overall quality^*^ | Limitations | Consistency | Applicability | Summary of findings
Key Question 1. What is the effectiveness of screening for syphilis in reducing complications of the disease and transmission or acquisition of other STIs in asymptomatic, nonpregnant, sexually active adults and adolescents? What is the effectiveness of specific screening intervals and screening among population subgroups?
No studies met inclusion criteria. | 4 observational studies of MSM and HIV- positive males | Fair | No studies of screening effectiveness; no studies of screening intervals in other populations. | Consistent | Studies conducted in Europe and Australia in MSM and HIV+MSM; studies included high-prevalence populations | 4 non-U.S. studies on the effectiveness of screening for syphilis among MSM or HIV- infected men found that detection rates increased with routine screening every 3 months compared with annual screening. More cases of infection were detected for early syphilis in HIV-positive MSM (8.1% vs. 3.1%; p=0.001), newly acquired syphilis in HIV-positive MSM (7.3 cases [95% CI, 5.2 to 9.9] vs. 2.8 cases [95% CI, 1.8 to 4.0] per 1,000 patient-years; p<0.05); early latent syphilis in MSM (1.7% vs. 0.4%; p=0.008), and early syphilis in higher-risk MSM (16% vs. 53%; p=0.001) when screening occurred every 3 months compared with 6- or 12-month screening intervals.
Key Question 2. What is the effectiveness of risk assessment instruments or other risk stratification methods for identifying individuals who are at increased risk for syphilis?
No studies met criteria. | No studies | NA | NA | NA | NA | NA
Key Question 3. What is the accuracy of currently used screening tests and strategies for detecting syphilis infection?
Included mostly studies of diagnostic accuracy conducted in populations and settings not applicable to this update; descriptive information on new screening tests and methods also mentioned. | 5 observational studies (3 test accuracy; 2 testing sequence) | Fair | Not all tests currently used for screening in the U.S. were included; unclear sampling methods and interpretation of tests; some studies had technical shortcomings. | Consistent | Limited; 1 of 3 studies from the U.S. in STI clinic with high prevalence of MSM and HIV; 2 studies of testing sequence conducted in the U.S. and Canada; studies included high-prevalence populations | 3 observational studies of treponemal and nontreponemal tests found that screening tests for syphilis are accurate: sSensitivity 85.3%-98% and specificity 91%-100% for both treponemal and nontreponemal tests. 2 studies of the accuracy of reverse sequence testing found a higher rate of false-positive tests when using an automated treponemal test for initial screening compared with rapid plasma reagin in a low-prevalence U.S. population (0.6% vs. 0.0%; p=0.03), and in a higher prevalence Canadian population (0.26% vs. 0.13%). Both methods identified additional positive tests that would not have been identified using conventional methods.
Key Question 4. What are the harms of screening?
No studies identified | No studies | NA | NA | NA | NA | NA

* “Overall quality” is based on new evidence identified for the update plus previously reviewed evidence.

Abbreviations: CI=confidence interval; MSM=men who have sex with men; NA=not applicable; STI=sexually transmitted infection.

No new studies meeting inclusion criteria evaluated risk assessment instruments or risk stratification methods for identifying persons at increased risk for syphilis (Key Question 2). The prior reviews also did not identify studies evaluating risk instruments or risk stratification methods for nonpregnant adults.

Three studies of the diagnostic accuracy of screening tests met inclusion criteria (Key Question 3).60-62 One U.S. study found that screening with the Trep-Sure EIA followed by a confirmatory TPPA test in a higher prevalence population was slightly less sensitive than the traditional nontreponemal VDRL test (98.0% vs. 98.6%) but more specific (98.6% vs. 91.1%).60 In a lower prevalence population in Canada, screening with the Trep-Chek IgG EIA test followed by a confirmatory test had 85.3 percent sensitivity and 95.6 percent specificity compared with standard testing protocols.61 A study in a high prevalence population of sex workers in Mexico compared treponemal TPPA testing with VDRL testing followed by FTA-ABS and reported 100 percent specificity but 87.1 percent sensitivity compared with standard testing.62 These results are fairly consistent with the known sensitivities of the tests currently cleared by the FDA for syphilis testing (Table 3). However, limitations of these studies include minimal demographic information of populations tested and limited applicability to the general U.S population. The prior reviews included studies of diagnostic accuracy conducted in populations and settings not applicable to this review, including pregnant women, stored serum samples, symptomatic populations, and developing countries.

Two studies of reverse sequence testing conducted in both high and low prevalence populations used an automated treponemal test as the initial screening test. Rates of false-positive tests at the screening stage were higher than when RPR was used for initial screening.28,63 Both methods identified additional cases of syphilis that would not have been identified using conventional methods.

Although traditional screening (nontreponemal testing followed by treponemal testing) is recommended for general screening because it correlates with disease activity, it may have the disadvantage of missing early primary, previously treated, or longstanding untreated infections.73 There are limited data on reverse testing algorithms, which also require a nontreponemal test to gauge disease activity. The CDC recommends using a third treponemal test based on different antigens (TPPA or FTA-ABS) to confirm the original treponemal results when employing the reverse sequence screening algorithm (Figure 1).24

We identified two reports of test performance using reverse sequence screening that lacked comparison groups and were not included in this systematic review. These may offer additional context for this newly employed testing strategy, and they report similar outcomes as the two studies included in this review.24,34 A report by the CDC demonstrated a higher percentage of discrepant serology in low prevalence populations than in high prevalence populations (60.6% vs. 50.6%) using reverse sequence testing. Additionally, the percentage of tests with nonreactive confirmatory treponemal tests was greater in the low prevalence population than the high prevalence population. There was also a higher percentage of samples that were RPR negative but positive on both treponemal tests in the high prevalence population (43.6% vs. 35.8%). These samples may represent false-positives, early primary syphilis in an individual who has not developed nontreponemal antibodies, or a previous treated or untreated infection with seroversion of nontreponemal antibodies. Currently, there is no evidence to direct the management of patients with discrepant serology (e.g., positive enzyme/chemiluminescence immunoassay and negative RPR/positive TPPA). As with any diagnostic test, the diagnostic accuracy of reverse sequence screening appears to be affected by the population prevalence or risk of syphilis in the population being tested.

## Limitations

Limitations of this review include using only English-language articles, which could result in language bias, though we did not identify non-English–language studies otherwise meeting inclusion criteria in our searches. We only included studies with asymptomatic participants and settings and tests applicable to current practice in the United States to improve clinical relevance for the USPSTF, excluding some research in the field. For example, limiting the review to tests cleared by the FDA excludes studies of many rapid tests. This is especially important for screening in asymptomatic MSM and other high-risk populations, including HIV-positive populations. Diagnostic accuracy studies did not provide details on patient demographics other than risk groups, potentially limiting applicability. Studies were lacking for many Key Questions, and the number, quality, and applicability of studies varied widely. Also, the available screening studies focused on detection rates in MSM and HIV-positive populations in Australia and the United Kingdom, while other populations are also relevant to screening. The studies of screening in men living with HIV were included because the line between screening and disease management in the context of HIV care is a blurry one, yet the reintegration of patients with HIV into primary care is increasingly common. The included studies evaluated the effect of more frequent screening in a population considered higher risk for asymptomatic infection. As such, the generalizability of these studies may be limited.

## Emerging Issues and Next Steps

Screening tests for syphilis are accurate. However, the sequence of tests may result in different diagnostic accuracy depending on the population prevalence of the disease. Test sensitivity may also vary depending on the stage of the disease. While there may be a role for automated EIA- based screening, the clinical impact of altering syphilis testing algorithms is poorly understood, and positive results may confer a diagnosis of prior or latent infection requiring additional testing. More studies of reverse sequence screening could provide support for limited applications of this approach when utilized appropriately in certain populations. Consideration of rapid testing may provide evidence for FDA clearance of this technique and increase testing access and acceptability, potentially expanding screening strategies and encouraging point of care screening among persons at increased risk.

## Relevance for Priority Populations

Specific population subgroups at increased risk for infection are the most relevant to include in studies of syphilis screening. Expanding the field of testing types, including rapid tests, and further validation or evaluation of test sequence, has the potential to improve disease detection, particularly among priority populations. For example, the availability of rapid tests in high-risk populations or high-risk settings (HIV clinics, STI clinics, and MSM) may provide additional opportunities for point of care testing. The availability of automated tests, as employed by reverse sequence testing, may provide additional opportunity for screening populations at risk when confirmatory testing is available.

## Future Research

Research is lacking on the effectiveness of screening for syphilis in asymptomatic, nonpregnant, sexually active adolescents and adults without risk factors. Studies evaluating the effectiveness of different screening strategies for identifying persons at increased risk of infection, cotesting for concurrent STIs, and different screening intervals are needed to inform practice guidelines.

Risk assessment instruments could help narrow the field of targeted testing, and risk stratification methods could help improve screening efforts. Future studies of risk assessment could compare the effectiveness of screening versus not screening in populations with different levels of risk and the effectiveness of risk assessment instruments and validated prediction tools for identifying persons at increased risk for syphilis. Studies of diagnostic accuracy could include effectiveness of test strategies, including the sequence of tests. Future research should be directed at the direct comparison of the performance of various treponemal tests (EIA, chemiluminescence immunoassay, TPPA, FTA-ABS, and microbead immunoassay) and their use in well-defined patient populations whose clinical history and syphilis risk are known. New studies of diagnostic accuracy would characterize discordant serology with nonreactive confirmatory treponemal tests and study the utility of certain tests in diagnosing early primary syphilis.

## Conclusions

Only four new studies evaluating detection rates of syphilis using specific screening intervals in MSM or HIV-positive populations, three studies of the diagnostic accuracy of screening tests, and two studies of the accuracy of testing sequence met inclusion criteria. No studies evaluated the effectiveness of screening for syphilis, the effectiveness of risk assessment instruments or risk stratification methods, or the adverse effects of screening. There were no studies of adolescent populations. Results from four observational studies indicate that screening for syphilis in MSM or men living with HIV every 3 months may improve detection of early syphilis, newly acquired syphilis, early latent syphilis, and early syphilis among higher-risk MSM. Screening with treponemal or nontreponemal tests is accurate for diagnosing syphilis in asymptomatic persons (sensitivity >85% and specificity >91% for nontreponemal and treponemal tests in most studies) but requires confirmatory testing. Further research is needed to understand the impact of screening for syphilis on clinical outcomes; effective screening strategies, including reverse sequence screening, in various patient populations; and harms of screening.