# Results

## Key Question 1 What Is the Effectiveness of Screening for Syphilis in Reducing Complications of the Disease and Transmission or Acquisition of Other STIs in Asymptomatic, Nonpregnant, Sexually Active Adults and Adolescents? What Is the Effectiveness of Specific Screening Intervals and Screening Among Population Subgroups?

### Summary

No studies directly compared the effectiveness of syphilis screening in screened versus unscreened populations of nonpregnant adolescents or adults. Four observational studies evaluated detection rates using specific screening intervals in MSM or HIV-positive populations outside the United States. No studies evaluated detection rates or screening intervals in other population subgroups. A study of MSM living with HIV in Australia found that detection of asymptomatic early syphilis was higher among those screened every 3 months compared with those screened annually (8.1% vs. 3.1%; p=0.001).56 A study of patients living with HIV in London found that routine screening every 3 months detected more patients with newly acquired syphilis compared with screening every 6 months or more (7.3 cases [95% CI, 5.2 to 9.9] per 1,000 patient-years vs. 2.8 cases [95% CI, 1.8 to 4.0] per 1,000 patient-years; p<0.05).57 Another Australian study of MSM who received automated reminders for syphilis testing demonstrated higher testing rates among men choosing 3-month reminders versus controls receiving yearly testing (67.0% vs. 39.9%; p<0.0001) and higher detection rates of early latent syphilis compared with controls (1.7% vs. 0.4%; p=0.008).58 A related Australian study that implemented a system-based intervention focusing on computer reminders directed at clinicians of high-risk patients demonstrated an increased proportion of higher-risk MSM who received a diagnosis of early syphilis and who were asymptomatic when tested every 3 months versus annually (53% vs. 16%; p=0.001), but no difference among low-risk patients.59

The prior reviews for the USPSTF did not include studies meeting inclusion criteria for this Key Question.

### Evidence

Three fair-quality observational studies from the same health center in Australia56,58,59 and one fair-quality observational study from the United Kingdom57 evaluated detection rates of syphilis using specific screening intervals among MSM or HIV-positive populations (Appendixes C1 and C2). All four studies were conducted in MSM or men living with HIV, limiting generalizability to other populations. There were no studies in adolescents or other population subgroups, and three studies were conducted at one clinical site in Australia. Two studies of men living with HIV56,57 tested for syphilis as part of HIV disease monitoring rather than screening, potentially limiting applicability.

A pre-post intervention study conducted among 1,031 MSM attending a public STI clinic in Australia used a historic control group to compare the effect of implementing more frequent syphilis screening (every 3 months) with annual screening as part of disease monitoring in MSM living with HIV.56 The detection rate of asymptomatic syphilis infections was significantly higher for 3-month versus annual screening (8.1% vs. 3.1%; p=0.001). The proportion of MSM living with HIV with early syphilis who were asymptomatic at the time of diagnosis was 21 percent (3 of 14 patients) before the intervention versus 85 percent (41 of 48 patients) after the intervention (p=0.006).

An observational study conducted in London among 2,389 MSM attending an outpatient HIV clinic compared detection rates for routine syphilis screening as part of HIV care with detection rates during the year before routine screening was implemented.57 Routine screening every 3 months detected more patients with newly acquired syphilis compared with screening every 6 months or more (7.3 cases [95% CI, 5.2 to 9.9] per 1,000 patient-years vs. 2.8 cases [95% CI, 1.8 to 4.0] per 1,000 patient-years; p<0.05).57

A third Australian study, conducted at the same health center as the others, used a controlled observational design to evaluate the impact of computer-generated reminders on the rates of syphilis testing among 4,514 MSM who elected to receive a reminder every 3, 6, or 12 months.58 Men receiving reminders every 3 months had a statistically significantly higher detection rate of early syphilis during the 12-month observation period compared with concurrent controls who were not offered reminders (3.2% vs. 1.5%; p=0.025).

Using a system-based approach to testing, a study conducted at the same Australian health center evaluated whether a computer alert for physicians of MSM (in 6,789 consultations) to test higher-risk patients improved the rate of syphilis testing and diagnosis.59 Men who reported 10 or more sexual partners within the prior 12 months were defined as higher risk for syphilis. Results indicated an increased proportion of asymptomatic higher-risk men receiving diagnoses of early syphilis who were tested every 3 months versus annually (31/58 [53%] vs. 5/31 [16%]; p=0.001). There were no statistically significant changes in the proportion of syphilis diagnoses in asymptomatic lower-risk men who were tested every 3 months versus annually (3/16 [19%] vs. 1/10 [10%]; p=0.60).

## Key Question 2 What Is the Effectiveness of Risk Assessment Instruments or Other Risk Stratification Methods for Identifying Individuals Who Are at Increased Risk for Syphilis?

No studies evaluated risk assessment instruments or risk stratification methods for identifying individuals at increased risk for syphilis. The prior reviews also did not identify studies evaluating risk instruments or methods.

## Key Question 3 What Is the Accuracy of Currently Used Screening Tests and Strategies for Detecting Syphilis Infection?

### Summary

Three fair-quality observational studies of diagnostic accuracy evaluated treponemal and nontreponemal tests. A U.S. study conducted in a high-prevalence STI clinic (39.7% positive test rate) compared a treponemal EIA screening test (Trep-Sure™ EIA; Trinity Biotech, Jamestown, NY) with a traditional nontreponemal VDRL test as an initial screening examination, and used a TPPA assay as a confirmatory test. Screening with the Trep-Sure EIA in conjunction with a confirmatory TPPA test was slightly less sensitive than the VDRL test (98.0% vs. 98.6%) but more specific (98.6% vs. 91.1%).60 A Canadian study also reported results of the diagnostic accuracy of treponemal EIA tests (Trep-Chek immunoglobulin G [IgG] EIA; Phoenix Biotech Corp., Toronto, Canada) in a sample of specimens with a 5.6 percent positive test rate using conventional testing methods.61 Use of the Trep-Chek IgG EIA as a screening test followed by a confirmatory test resulted in a sensitivity of 85.3 percent and a specificity of 95.6 percent compared with standard testing protocols. A third study from Mexico compared the diagnostic accuracy of the treponemal TPPA test with VDRL testing followed by FTA-ABS in a population of female sex workers (15.7% prevalence) at an STI clinic and reported 100 percent specificity but lower sensitivity (87.1%) compared with the standard.62 Population demographics were not well characterized in any of the three studies.

Two observational studies from the United States and Canada compared traditional screening strategies with reverse screening strategies.28,63 A retrospective cohort study in Canada compared results using RPR or EIA screening as an initial test in a metropolitan area with a known high prevalence of syphilis.63 This study demonstrated an increase in the rate of confirmed positive tests using EIA as the initial screen compared with RPR screening (1.98% vs. 0.45%). A prospective cohort study in a low-prevalence U.S. population compared MFI followed by RPR screening and TPPA confirmation testing with conventional RPR screening followed by TPPA.28 Fifteen samples reacted when screened with MFI compared with four samples that reacted with RPR (1.5% vs. 0.4%; p=0.01). In both studies, initial screening using an automated treponemal test resulted in a higher rate of false-positives at the screening stage than when RPR testing was used for initial screening, but both methods also identified additional positive tests that would not have been identified using conventional methods.

The prior reviews mostly included studies of diagnostic accuracy conducted in populations and settings not applicable to this review.

### Evidence

#### Screening Tests

Three fair-quality observational studies from Mexico, Canada, and the United States reported the diagnostic accuracy of syphilis screening tests (Appendixes C3 and C4).60-62 These studies were limited by minimal demographic information and small sample sizes (N=198 to 674). Two studies compared treponemal EIA tests as a screening assay when followed by a second confirmatory test,60,61 and one study compared the treponemal TPPA test with VDRL testing followed by FTA-ABS.62 The prior reviews mostly included studies of diagnostic accuracy conducted in populations and settings not applicable to this review (symptomatic persons, pregnant women, or patients in developing countries).1 Other methodological differences included studies lacking comparison groups or testing performed on stored serum samples.

A cross-sectional U.S. study of remnant sera collected from the San Francisco municipal sexually transmitted disease clinic compared a treponemal EIA screening test with a traditional nontreponemal VDRL test as an initial screening examination, and used a TPPA assay as a confirmatory test. Tests were run on remnant sera from patients of unspecified age groups presenting to an STI clinic with a reported syphilis prevalence of 9.4 percent and high rates of patients living with HIV (16.6%) and MSM (69.3%).60 The samples used in this study reflected higher syphilis prevalence than in the general population at the clinic, with a positive test rate of 39.7 percent after both the screening and confirmatory tests were completed. In this population, screening with the EIA test in conjunction with a confirmatory TPPA test was slightly less sensitive than when the VDRL was used as the screening test (98.0% vs. 98.6%) but was more specific (98.6% vs. 91.1%).

A study from Canada tested EIA as a screening test followed by confirmatory tests (TPPA, FTA-ABS, line immunoassay) in serum specimens submitted to a reference laboratory for confirmation or further evaluation. Of these specimens, 5.6 percent tested positive for syphilis when screened using conventional screening tests (RPR and VDRL).61 Use of the Trep-Chek EIA as a screening test followed by confirmatory testing resulted in a sensitivity of 85.3 percent and a specificity of 95.6 percent compared with samples screened with conventional tests (RPR, VDRL, TPPA, and FTA-ABS). This study is limited by the lack of no-antigen control wells for the EIA, the small number of positive cases tested, and the lack of demographic data specifying the ages of patients who provided samples submitted for testing.

A cohort study compared the diagnostic accuracy of the treponemal TPPA test with VDRL testing followed by FTA-ABS in a population of 198 female sex workers (15.7% prevalence, ages not specified) at an STI clinic in Mexico.62 The study reported 100 percent specificity but lower sensitivity (87.1%) for the samples from the STI clinic compared with standard VDRL testing.

#### Screening Strategies

Two fair-quality observational studies compared traditional screening strategies with reverse screening strategies (Appendixes C4 and C5). In both studies, initial screening using an automated treponemal test resulted in a higher rate of false-positives at the screening stage than when RPR testing was used for screening. Both studies also identified additional positive tests that would not have been identified using conventional methods. Methodological limitations included minimal demographic information or unclear descriptions of sampling methods.

A large (n=3,092,938 samples) retrospective time-series study in Canada evaluated a reverse screening algorithm by comparing laboratory results from a higher-prevalence metropolitan area (incidence rate ratio of 1.69 to 1.80 relative to surrounding suburban areas) using RPR or EIA as the initial screening test on samples submitted for syphilis serology.63 Samples were considered positive after undergoing a confirmatory test.

Results indicated an increase in the detection rate of positive tests when using EIA as the initial screen versus RPR (1.98% vs. 0.46% confirmed positive). Notably, 69.6 percent of all confirmed positives during the EIA screening period were associated with a negative RPR test. The proportion of confirmed positive EIA tests with a negative RPR test result was higher when samples were limited to those from asymptomatic patients (74.7% [95% CI, 73.6 to 75.8]), patients with no risk factors for syphilis (71.5% [95% CI, 70.4 to 72.5]), or intravenous drug users (69.9% [95% CI, 66.3 to 73.3]); and slightly lower for MSM (69% [95% CI, 66.9 to 71.0]) and MSM who are also intravenous drug users (68% [95% CI, 60.0 to 75.4]). Statistical analysis of the test performance indicated that the increase in syphilis detection during the EIA screening period was not only the result of increased prevalence in the community at the time of testing.

A prospective cohort study from the United States (n=1,000 samples) directly compared reverse and traditional syphilis screening algorithms in a low-prevalence population using the BioPlex® 2200 Syphilis IgG (MFI) (Bio-Rad Laboratories, Inc., Hercules, CA). For the reverse sequence, initial MFI testing was followed by RPR testing and TPPA confirmation testing and conventional RPR screening was followed by confirmatory TPPA.28 When screened with MFI, 15 samples were reactive by reverse screening compared with four samples that reacted with RPR or traditional screening (1.5% vs. 0.4%; p=0.01). All four samples that tested positive with the RPR test were confirmed positive by TPPA and were also positive with MFI or reverse screening. Further review revealed that three of 11 samples not detected by RPR represented previously treated syphilis infection, six were interpreted as false-positive screening results based on negative TPPA results and alternative diagnosis, and two cases of probable latent syphilis were identified and treated. Based on these results, reverse screening yielded a higher false-positive rate than traditional testing (0.6% vs. 0%; p=0.03) but two patients with possible latent syphilis that were undetected by RPR were identified using the reverse screening algorithm.

## Key Question 4 What Are the Harms of Screening?

Consistent with prior reviews, there were no studies addressing the harms of screening for syphilis.

## Contextual Question 1 Which Population Subgroups, Including MSM, Are at Highest Risk for Incident Syphilis Infection?

### MSM

According to the CDC, the rate of primary and secondary syphilis infection has been increasing in MSM since 2000, with this group accounting for 61 percent of all primary and secondary cases reported in 2014.^8^ Of these cases, 37.6 percent were white men, 31.8 percent were black men, 21.8 percent were Hispanic men, and 8.8 percent were men of other races.

### Persons Living With HIV

In the United States in 2014, 51.2 percent of MSM with syphilis infections also had HIV infections, compared with 10.7 percent of men who have sex with women, and 5.9 percent of women in general across all racial/ethnic groups.8 The proportion of MSM who presented to STI Surveillance Network clinics with primary and secondary syphilis infections who were also infected with HIV ranged from 9.1 percent in Los Angeles to 53.2 percent in Baltimore.8

An observational study (n=4,256) of patient data from the Kaiser Permanente system in northern California from 1995 to 2005 reported similar results, with HIV coinfection occurring in 57.9 percent of primary syphilis cases, 32.4 percent of secondary syphilis cases, and 9.1 percent of tertiary cases (Table 5).64 This study also reported that MSM represented 81 percent of those who were coinfected with syphilis and HIV. The adjusted rate ratio of a syphilis infection among HIV-infected cases was 86.0 (95% CI, 78.6 to 94.1), and the rate of syphilis among the HIV-infected population was 12.4 per 1,000 population compared with 0.2 per 1,000 population in the group without HIV infection.

Table 5 Observational Studies of Syphilis and HIV Coinfection

Study, Location | Population | Setting | Results
CDC, 2015 (data from 2013-2014)8 | Diagnosis: Syphilis N: 19,999 Male: 91% MSM: 61% Race: 36% black, 34% white, 20% Hispanic | All U.S. hospitals and clinics reporting STIs | Proportion coinfected with HIV: MSM: 51.2% MSW: 10.7% Females: 5.9%
Baffi, 2010 (data from 2004-2007)65 | Diagnosis: HIV N: 1,544 Male: 76% MSM: 57% Race: 49% black, 49% white | University of Alabama HIV/AIDS clinic | Proportion diagnosed with HIV and coinfected with syphilis: 2.6% Adjusted OR of syphilis diagnosis among HIV-infected patients: Black/other race: 2.26 (95% CI, 1.12 to 4.59) Increasing age by 10 years: 0.62 (95% CI, 0.44 to 0.87)
Hoover, 2010 (data from 2004-2006)66 | Diagnosis: HIV N: 1,334 Male: 100% MSM: 100% Race: 36% white, 28% Hispanic, 18% black | 8 large HIV clinics in 6 U.S. states | Proportion coinfected with syphilis: Documented confirmed diagnosis: 1.7% Presumptive syphilis diagnosis: 1.1%
Horberg, 2010 (data from 1995-2005)64 | Diagnosis: Syphilis N: 4,246 HIV infected vs. HIV uninfected: Male: 97% vs. 50% MSM: not reported Black: 23% vs. 37% White: 49% vs. 27% | Kaiser Permanente Northern California database to identify patients with incident syphilis | Rate of syphilis: HIV infected: 12.4/1,000 person-years HIV uninfected: 0.2/1,000 person-years Adjusted RR of syphilis infection: HIV infected: 86.0 (95% CI, 78.6 to 94.1) Proportion coinfected with HIV: Primary cases: 57.9% Secondary cases: 32.4% Tertiary cases: 9.1% MSM: 81%
Mayer, 2012 (data from 2004-2006)17 SUN study | Diagnosis: HIV N: 557 Male: 79% MSM: 66% Race: 61% white, 26% black, 10% Hispanic | 7 HIV clinics in 4 U.S. cities | Proportion coinfected with syphilis: MSM: 1% MSW: 0% Women: 0%
Mayer, 2014 (data from 2009-2010)67 | Not based on diagnosis, but enrolled patients screening for STIs N: 1,553 Male: 100% MSM: 100% Race: 100% black | HIV Prevention Trials Network in 6 U.S. cities | Proportion coinfected with HIV: Newly diagnosed with HIV: 11% Previously diagnosed with HIV: 4%
Yang, 2013 (data from 2008-2012)68 | Diagnosis: HIV N: 3,170 Male: 100% MSM: 58% Race: 45% black, 29% white, 25% Hispanic | Enhanced HIV/AIDS Reporting System in Houston, Texas | Proportion coinfected with syphilis: 6.3% Adjusted HRs of syphilis diagnosis: MSM: 5.24 (95% CI, 3.41 to 8.05) vs. nonMSM Ages 13-19 years: 4.06 (95% CI, 2.18 to 7.55) vs. >40 years Blacks: 1.59 (95% CI, 1.11 to 2.26) vs. whites

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; HR=hazard ratio; MSM=men who have sex with men; MSW=men who have sex with women; OR=odds ratio; RR=rate ratio; STI= sexually transmitted infection.

Another observational study conducted among black MSM in six U.S. cities enrolled patients attending an STI clinic for screening (n=1,553). Eleven percent of diagnosed syphilis cases were also newly diagnosed HIV cases and 4 percent were previously diagnosed with HIV (Table 5).67 Four other observational studies enrolled predominately MSM living with HIV and tested them for syphilis.17,65,66,68 All of the studies reported that less than 7 percent (range, 0% to 6.3%) of the HIV-infected population was also coinfected with syphilis.

A large observational study (n=3,170) reporting the highest proportion of HIV coinfection among MSM was a population study of men from Houston, Texas (Table 5).68 This study conducted additional analyses on the risk of syphilis associated with HIV infection and reported high hazard ratios (HRs) for MSM (5.24 [95% CI, 3.41 to 8.05] vs. nonMSM), males ages 13 to 19 years (4.06 [95% CI, 2.18 to 7.55] vs. age >40 years), and black men (1.59 [95% CI, 1.11 to 2.26] vs. white men).68 Another study conducted at an HIV clinic in Alabama also reported a high odds ratio (OR) of syphilis infection for black individuals and other races (2.26 [95% CI, 1.12 to 4.59] vs. white individuals) and a lower OR with each 10 years of increasing age (0.62 [95% CI, 0.44 to 0.87]).65

### Young Adult Men

Rates of syphilis infection among men ages 20 to 24 years have increased each consecutive year since 2002, from 5.2 to 31.1 cases per 100,000 in 2014. Rates have also increased among men ages 25 to 29 years since 2008, from 16.9 to 34.0 cases per 100,000.^8^ In addition to MSM, the rate of primary and secondary syphilis infection has been increasing among men ages 20 to 24 years and 25 to 29 years by 60.1 percent and 65.7 percent, respectively, from 2008 to 2013. This is a shift from 2006, when the rate was highest in men ages 35 to 39 years.69 Rates of all syphilis infections increased for all age groups between the ages of 15 and 64 years in 2014; 11.6 percent for ages 15 to 19 years, 13.1 percent for ages 20 to 24 years, 23.4 percent for ages 25 to 29 years, 18.3 percent for ages 30 to 34 years, 13.0 percent for ages 35 to 39 years, 3.7 percent for ages 40 to 44 years, 13.3 percent for ages 45 to 54 years, and 21.1 percent for ages 55 to 64 years.8

### Racial Minorities

While the rate for primary and secondary syphilis infection has decreased for black individuals overall, the rate among black males ages 20 to 29 years remains the highest reported for all subgroups (106.3 to 121.3 cases per 100,000), with black males ages 30 to 39 years having the second highest prevalence for all subgroups (44.4 to 72.4 cases per 100,000). Young Native Hawaiian/Pacific Islander men ages 20 to 29 years also had high rates of primary and secondary syphilis infection in 2014 (21.0 to 44.8 cases per 100,000). There are wide racial/ethnic disparities among young men ages 20 to 24 years and 25 to 29 years, with the rate of primary and secondary syphilis cases 8.5 and 7.9 times higher in black men, 3.5 and 1.4 times higher in Native Hawaiian/Pacific Islander men, and 2.6 and 2.2 times higher in Hispanic men compared with white men. The disparity is also present in males ages 15 to 19 years, with black males having 12.5 times higher rates of primary and secondary syphilis infection than white males and 2.7 times higher than Hispanic males. For black females ages 15 to 19 years, the rate of primary and secondary syphilis infection was 14.7 times higher than for white females and 6.0 times higher than for Hispanic females. Table 6 provides additional details on prevalence rates by subgroup.

Table 6 Rates of Primary and Secondary Syphilis Infection by Population Subgroups^*^

Subgroup | Male | Female
Race by age (years) | (rate per 100,000) | (rate per 100,000)
All races combined; ages combined | 11.7 | 1.1
15-19 | 7.0 | 2.5
20-24 | 31.1 | 4.5
25-29 | 34.0 | 3.4
30-34 | 24.7 | 2.3
35-39 | 19.1 | 1.8
Black; ages combined | 34.5 | 4.6
15-19 | 23.7 | 10.3
20-24 | 106.3 | 18.8
25-29 | 121.3 | 11.9
30-34 | 72.4 | 16.3
35-39 | 44.4 | 5.4
Native Hawaiians/Pacific Islander; ages combined | 12.0 | 0.8
15-19 | 9.9 | 0.0
20-24 | 44.8 | 0.0
25-29 | 21.0 | 4.4
30-34 | 31.9 | 0.0
35-39 | 10.6 | 0.0
Hispanic; ages combined | 13.9 | 1.1
15-19 | 8.6 | 1.7
20-24 | 32.0 | 3.3
25-29 | 34.0 | 3.2
30-34 | 25.2 | 2.1
35-39 | 22.8 | 1.6
White; ages combined | 6.5 | 0.5
15-19 | 1.9 | 0.7
20-24 | 12.5 | 1.5
25-29 | 15.4 | 1.6
30-34 | 14.3 | 1.2
35-39 | 12.2 | 1.0
American Indian/Alaskan Native; ages combined | 10.5 | 4.8
15-19 | 8.7 | 13.7
20-24 | 24.0 | 9.8
25-29 | 31.1 | 12.5
30-34 | 32.5 | 6.7
35-39 | 17.8 | 14.4
Asian; ages combined | 5.6 | 0.2
15-19 | 1.7 | 0.0
20-24 | 13.8 | 0.3
25-29 | 15.7 | 0.4
30-34 | 10.7 | 0.1
35-39 | 9.1 | 0.4
Multirace; ages combined | 9.5 | 0.5
15-19 | 3.2 | 0.3
20-24 | 21.4 | 1.2
25-29 | 26.9 | 1.5
30-34 | 32.1 | 2.2
35-39 | 30.8 | 1.3
Region of United States, followed by states and cities with the highest rates
Entire United States | 11.7 | 1.1
West | 14.6 | 1.2
California (San Francisco) | 18.4 (32.8) | 1.7 (1.5)
Nevada (Las Vegas) | 23.8 (29.6) | 1.7 (1.7)
Oregon (Portland) | 12.9 (17.2) | 1.1 (0.8)
South | 12.4 | 1.5
Georgia (Atlanta) | 23.3 (35.0) | 1.9 (2.0)
Louisiana (New Orleans) | 19.6 (33.7) | 5.6 (2.8)
Florida (Miami-Fort Lauderdale) | 16.8 (27.5) | 1.4 (1.5)
Northeast | 10.7 | 0.5
District of Columbia | 34.6 | 1.5
New York (New York City) | 17.6 (17.3) | 0.5 (0.5)
Maryland (Baltimore) | 13.9 (18.0) | 1.6 (2.9)
Midwest | 7.9 | 0.9
Illinois (Chicago) | 12.4 (15.7) | 1.2 (1.6)
Michigan (Detroit) | 8.0 (14.1) | 0.6 (1.0)
Missouri (Kansas City) | 10.7 (19.5) | 1.1 (02.2)

* Rates per 100,000 population; taken from the Centers for Disease Control and Prevention. Sexually transmitted disease surveillance 2014. Atlanta, GA. Department of Health and Human Services. 2015. Available at: http://www.cdc.gov/std/stats14/surv-2014-print.pdf. .

From 2010 to 2014, the rate of primary and secondary syphilis infection increased for all races, and between 2013 and 2014 the rate increased the most among American Indian/Alaska Native individuals (68.8%) and those who identified as multiple races (47.3%). During 2013 and 2014, rates increased for all groups, except Native Hawaiian/Pacific Islander individuals.8 In 2014, 38.1 percent of all primary and secondary cases of syphilis reported to the CDC were among black individuals and 34.0 percent were among white individuals.19

### Sex Workers

The risk of STIs in general is high among persons who exchange sexual activity for income, employment, or nonmonetary items, such as food, drugs, and shelter. Sex workers frequently encounter barriers to seeking care or reducing risk for STIs because of other social factors, such as poverty.19 Although sex workers have been previously identified as a group at higher risk for syphilis, there were no U.S.-based studies published in the last 10 years reporting information about syphilis risk factors or prevalence among sex workers.

### Adults in Correctional Facilities

A study of syphilis screening in arrested individuals reported higher rates of syphilis infection among women charged with prostitution than for other crimes.70 Another study reported seroprevalence rates of 11 percent among women tested in jails compared with 3 percent among women tested in hospital delivery rooms.71 In some locations, a high proportion of early syphilis cases are reported from correctional facilities.72 In 2011, reports of primary and secondary syphilis cases from correctional facilities accounted for 6 percent of primary and secondary syphilis cases among men, 3 percent among women, and 1 percent among MSM.19

### Residents of Specific Regions

The rate of primary and secondary syphilis infection in 2014 for the 50 most populous metropolitan statistical areas was 8.7 cases per 100,000 population; which was a 13.0 percent increase since 2013, and exceeded the overall rate for the United States (6.3 cases per 100,000 population).8 The southern states continue to have the highest number of reported cases (40.6% of all reported cases); however, the rate in the West (7.9 cases per 100,000 population) continued to exceed the rate in the South (6.9 cases per 100,000 population).8

## Contextual Question 2 Which Population Subgroups Are at Highest Risk for Syphilis-Related Morbidity and Mortality?

No studies were identified that address morbidity and mortality among population subgroups.