# Methods

## Key Questions and Analytic Framework

This systematic review followed a standard protocol consistent with the Agency for Healthcare Research and Quality (AHRQ) methods for systematic reviews.54,55 Based on evidence gaps identified from the prior review,1 in collaboration with the USPSTF and AHRQ, investigators determined the scope and Key Questions of the report. In addition, two contextual questions were requested by the USPSTF. Contextual questions address topics important to the USPSTF recommendations, but are reviewed by summarizing evidence from key informative studies rather than by using systematic review methodology. Key Questions and contextual questions are listed below. Investigators created an analytic framework incorporating the Key Questions and outlining the patient populations, interventions, outcomes, and potential adverse effects (Figure 2). The target population includes asymptomatic, sexually active men and nonpregnant women, including adolescents. All Key Questions include studies of high- and low-risk populations unless otherwise specified. A research plan was externally reviewed and modified.

Figure 2 Analytic Framework

Figure 2 is an analytic framework that depicts the process and outcomes of screening for syphilis in asymptomatic, nonpregnant adolescents and adults. The screening process includes risk assessment to determine which individuals are at high or low risk for infection, and testing to determine if individuals are positive or negative for syphilis. Infected individuals undergo treatment that can lead to reduced complications of syphilis as well as reduced transmission or acquisition of infection. During screening, individuals may also experience harms. Key Questions examine published research studies linked to aspects of screening and outcomes, including reduction in complications of syphilis and transmission or acquisition of infection (Key Question 1); effectiveness of methods that identify individuals at increased risk for syphilis (Key Question 2); accuracy of screening tests that detect syphilis infection (Key Question 3); and potential harms (Key Question 4).

### Key Questions

1. What is the effectiveness of screening for syphilis in reducing complications of the disease and transmission or acquisition of other STIs in asymptomatic, nonpregnant, sexually active adults and adolescents? What is the effectiveness of specific screening intervals and screening among population subgroups?
2. What is the effectiveness of risk assessment instruments or other risk stratification methods for identifying individuals who are at increased risk for syphilis?
3. What is the accuracy of currently used screening tests and strategies (e.g., sequence of tests) for detecting syphilis infection?
4. What are the harms of screening (e.g., labeling and false-positive or false-negative results)?

### Contextual Questions

1. Which population subgroups, including MSM, are at highest risk for incident syphilis infection?
2. Which population subgroups are at highest risk for syphilis-related morbidity and mortality?

## Search Strategies

This review includes studies published since the prior (2004) USPSTF review of this topic.1 The Cochrane Central Register of Controlled Trials (to March 11, 2016), Cochrane Database of Systematic Reviews (to March 11, 2016), and Ovid MEDLINE (January 2004 to March 11, 2016) were searched for relevant studies and systematic reviews. Search strategies are described in Appendix B1. Investigators also manually reviewed reference lists of relevant articles.

## Study Selection

Two reviewers independently evaluated each study to determine its inclusion eligibility based on predetermined inclusion and exclusion criteria developed for each Key Question (Appendix B2). In addition, abstracts were selected for full-text review if they included asymptomatic, sexually active men and women, including adolescents, and were applicable to clinical settings and practices in the United States. Applicability was determined by the clinical relevance of participants and health care services and the use of screening tests that are currently available and cleared by the FDA for clinical use in the United States. Non-English–language articles and studies published as abstracts were not included.

Studies of screening effectiveness (Key Question 1) were included if they provided direct evidence of the effectiveness of screening for syphilis, comparing health outcomes of screened versus unscreened asymptomatic individuals. Relevant outcomes included reduced complications of syphilis infection and reduced transmission or acquisition of STIs. Only randomized, controlled trials (RCTs), controlled observational studies, and ecological studies were included to evaluate the effectiveness of screening. Studies were included if they described the study population (number screened, sex, age range, setting, and absence of symptoms), features of the screening program (duration, type of strategy, and followup), and outcome measures. Inclusion criteria for effectiveness studies were less restrictive than criteria for diagnostic accuracy studies regarding the screening methods because the main comparison concerned outcomes related to the overall approach of screening versus not screening, the intervals of screening, and screening strategies among specific population subgroups, not the individual tests themselves.

Indirectly, the effectiveness and accuracy of different screening approaches and tests for identifying syphilis can be ascertained as a step toward the prevention of serious health outcomes, given foundational evidence on the effectiveness of treatment and the known morbidity and mortality of syphilis infections. Links in the chain of indirect evidence include the accuracy of screening for identifying individuals with syphilis, the effectiveness of interventions for reducing the incidence of complications, the association between improvements in intermediate outcomes and clinical health outcomes, and harms associated with screening. Implicit in the indirect chain of evidence is that to understand benefits and harms of screening, it is necessary, but not sufficient, to show that individuals with syphilis can be identified. It is also necessary to show that there are effective treatments for those identified. Not all of the indirect links are included in this update because some of the links, such as treatment efficacy, are already considered established.

Studies of the effectiveness of risk assessment instruments or other risk stratification methods (Key Question 2) were included if they evaluated clinic tools or methods to identify populations or individuals at high risk of syphilis infection. Studies of diagnostic accuracy (Key Question 3) were included if they evaluated the performance of diagnostic tests in asymptomatic persons using technologies and methods that have been cleared by the FDA and are available for clinical practice in the United States. These inclusion criteria reflect the scope of the USPSTF recommendations regarding technologies and medications. Based on these criteria, specimens obtained in nonclinical settings and most point of care or in-house tests were excluded. Included studies used credible reference standards, described the study population (number screened, sex, age range, setting, and absence of symptoms), defined positive screening test results, and reported performance characteristics (sensitivity, specificity, positive predictive value, negative predictive value, positive likelihood ratio, and negative likelihood ratio) or provided data to calculate them.

For studies of harms of screening (Key Question 4), searches focused on trials or studies that compared the harms of screening (labeling, false-negative and false-positive diagnoses and related harms, including psychosocial harms) with an unscreened population.

The selection of studies is summarized in the literature flow diagram (Appendix B3). Appendix B4 lists studies excluded at the full-text level, with reasons for exclusion.

## Data Abstraction and Quality Rating

A single investigator abstracted details about study design, patient population, comparison groups, setting, screening method, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. By using prespecified criteria developed by the USPSTF55 for RCTs, cohort studies, and diagnostic accuracy studies, two investigators independently rated the quality of studies (good, fair, or poor) and resolved discrepancies by consensus (Appendix B5).

## Data Synthesis

Two independent reviewers assessed the internal validity (quality) of the body of evidence for the new studies for each Key Question using methods developed by the USPSTF, based on the number, quality, and size of studies; consistency of results between studies; and directness of evidence.55 Statistical meta-analysis was not performed because of methodological limitations of the studies and heterogeneity in study designs, interventions, populations, and other factors. Studies included in prior reviews were reviewed for consistency with current results; however, lack of studies and differences in scope, Key Questions, and inclusion criteria limited aggregate synthesis with the updated evidence.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Medical Officers, and collaborative partners (Appendix B6).

## Response to Public Comment

A draft version of the evidence review was posted for public comment on the USPSTF Web site from December 15, 2015 to January 18, 2016. Comments from three contributors were directly relevant to the systematic review, while comments from other contributors concerned the recommendation statement. Comments were minor and only required that the CDC information be updated with current data.