# Introduction

## Purpose and Previous U.S. Preventive Services Task Force Recommendation

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2004 recommendation on screening for syphilis infection in nonpregnant adolescents and adults. It focuses on studies published since the prior USPSTF systematic review of this topic.1 Appendix A provides a description of terms and abbreviations used in this report.

In 2004, the USPSTF issued an A recommendation to screen for syphilis in all persons at increased risk.2 Populations at increased risk, based on incidence rates, include men who have sex with men (MSM) and engage in high-risk sexual behavior; commercial sex workers; persons who exchange sex for drugs; and adults in correctional facilities. The USPSTF recommended against routine screening in asymptomatic men and nonpregnant women not at increased risk of infection (D recommendation), and did not find evidence to support an optimal screening interval for persons at increased risk.

## Condition Definition

Syphilis is a chronic, systemic, infectious disease caused by sexual or vertical transmission (i.e., acquired during pregnancy or delivery) of the bacterium Treponema pallidum. Syphilis causes a variety of symptoms corresponding to stages of infection that can occur in an individual over time. Stages include primary, secondary, early and late latent, and late syphilis. Case definitions for these stages were updated in January 2014 by the Centers for Disease Control and Prevention (CDC) (Table 1).3

Table 1 2014 CDC Case Definitions for Syphilis3

Stage | Clinical Symptoms | Diagnostic Criteria
Syphilis, primary | One or more ulcerative lesions (e.g., chancre), which might differ considerably in clinical appearance. | Meets the clinical description of primary syphilis with a reactive serologic test (nontreponemal: VDRL, RPR, or equivalent serologic methods; treponemal: FTA-ABS, TPPA, EIA, CIA, or equivalent serologic methods). These treponemal tests supersede older testing technologies, including MHA-TP. Although not required for diagnosis, demonstration of T. pallidum in clinical specimens by darkfield microscopy or by PCR or equivalent direct molecular methods may be present.
Syphilis, secondary | Localized or diffuse mucocutaneous lesions (e.g., rash, such as nonpruritic macular, maculopapular, papular, or pustular lesions), often with generalized lymphadenopathy. Other symptoms include mucous patches, condyloma lata, and alopecia. The primary ulcerative lesion may still be present. | Meets the clinical description of secondary syphilis with a nontreponemal (VDRL, RPR, or equivalent serologic methods) titer ≥4 AND a reactive treponemal test (FTA-ABS, TPPA, EIA, CIA, or equivalent serologic methods). Although not required for diagnosis, demonstration of T. pallidum in clinical specimens by darkfield microscopy or by PCR or equivalent direct molecular methods may be present.
Syphilis, early latent | A subcategory of latent syphilis (a stage of infection caused by T. pallidum in which organisms persist in the body of the infected individual without causing symptoms or signs) when initial infection has occurred within the previous 12 months. | No clinical signs or symptoms of syphilis, but has one of the following:; - No past diagnosis of syphilis, AND a reactive nontreponemal test (e.g., VDRL, RPR, or equivalent serologic methods), AND a reactive treponemal test (e.g., FTA-ABS, TPPA, EIA, CIA, or equivalent serologic methods); OR; - A current nontreponemal test titer demonstrating fourfold or greater increase from the last nontreponemal test titer; AND; - Evidence of having acquired the infection within the previous 12 months based on one or more of the following:; ○ Documented seroconversion or fourfold or greater increase in titer of a nontreponemal test during the previous 12 months; ○ Documented seroconversion of a treponemal test during the previous 12 months; ○ A history of symptoms consistent with primary or secondary syphilis during the previous 12 months; ○ A history of sexual exposure to a partner within the previous 12 months who had primary, secondary, or early latent syphilis (documented independently as duration <12 months); ○ Only sexual contact was within the last 12 months (sexual debut)
Syphilis, late latent | A subcategory of latent syphilis (a stage of infection caused by T. pallidum in which organisms persist in the body of the infected individual without causing symptoms or signs) when initial infection has occurred >12 months previously. | No clinical signs or symptoms of syphilis, but has one of the following:; - No past diagnosis of syphilis, AND a reactive nontreponemal test (e.g., VDRL, RPR, or equivalent serologic methods), AND a reactive treponemal test (e.g., FTA-ABS, TPPA, EIA, CIA, or equivalent serologic methods); OR; - A past history of syphilis therapy and a current nontreponemal test titer demonstrating fourfold or greater increase from the last nontreponemal test titer; AND; - No evidence of having acquired the disease within the previous 12 months (see Syphilis, early latent)
Syphilis, late, with clinical manifestations (including late benign syphilis and cardiovascular syphilis) | Inflammatory lesions of the cardiovascular system (e.g., aortitis, coronary vessel disease), skin (e.g., gummatous lesions), bone (e.g., osteitis) or other tissue. Rarely, other structures (e.g., the upper and lower respiratory tracts, mouth, eye, abdominal organs, reproductive organs, lymph nodes, and skeletal muscle) may be involved. Late syphilis usually becomes clinically manifest only after a period of 15–30 years of untreated infection. If only neurologic manifestations of syphilis (e.g., tabes dorsalis, dementia) are present and infection occurred >12 months ago, should be reported as “late syphilis.” | Characteristic abnormalities or lesions of the cardiovascular system (e.g., aortitis, coronary vessel disease), skin (e.g., gummatous lesions), bone (e.g., osteitis), or other tissue AND a reactive treponemal test (e.g., FTA-ABS, TPPA, EIA, CIA, or equivalent serologic methods), in the absence of other known causes of these abnormalities. CSF abnormalities and clinical symptoms or signs consistent with neurologic manifestations of syphilis might be present. Although not required for diagnosis, demonstration of T. pallidum in late lesions by special stains or equivalent methods, or by PCR or equivalent direct molecular methods may be present.
Neurosyphilis (can occur at any stage) | Infection of the central nervous system with T. pallidum, as evidenced by manifestations such as syphilitic meningitis, meningovascular syphilis, optical involvement (including interstitial keratitis and uveitis), general paresis (including dementia), and tabes dorsalis. | A reactive VDRL in CSF and 1) a reactive serologic test for syphilis (treponemal or nontreponemal) OR 2) if the VDRL test in CSF is negative, a reactive serologic test for syphilis (treponemal or nontreponemal) AND both an elevated CSF protein (or leukocyte count) AND clinical symptoms or signs consistent with neurosyphilis, without other known causes for these abnormalities.

Abbreviations: CDC=Centers for Disease Control and Prevention; CIA=chemiluminescence immunoassay; CSF=cerebrospinal fluid; EIA=enzyme immunoassay; FTA-ABS=fluorescent treponemal antibody absorption assay; MHA-TP=microhemagglutination assay for antibody to T. pallidum; PCR=polymerase chain reaction; RPR=rapid plasma reagin; TPPA=T. pallidum particle agglutination; VDRL=Venereal Disease Research Laboratory.

The clinical manifestation of primary syphilis usually consists of a painless local chancre. Although the chancre usually heals without treatment within a few weeks, the disease quickly becomes systemic. Secondary syphilis may present as rash, fever, headache, malaise, anorexia, diffuse lymphadenopathy, or diminished visual acuity. These symptoms usually resolve without therapy, but some patients experience relapse up to 5 years after the initial episode.4 Untreated patients with primary syphilis will progress to the secondary stage of syphilis, and untreated patients with secondary syphilis will progress to early latent syphilis. Twenty-five percent of untreated patients in early latent syphilis may experience a relapse back to secondary syphilis.5

Latent syphilis occurs when a patient has evidence of infection based on positive serologic tests but is asymptomatic. The updated case definitions distinguish between early and late latent syphilis based on the duration of infection.3 Early latent syphilis includes infections with evidence that they were acquired within 12 months, while late latent infections have no such evidence.3,4,6 Late stage syphilis may affect cardiovascular function and can also produce lesions in other organs, especially skin and bones. These can appear from 1 to 30 years after the primary infection.4 In addition, syphilis can infect the nervous system at any stage and present as a spectrum of symptoms from none to headache, altered behavior, movement disorders, and dementia.7

## Prevalence

Early syphilis is defined as an infection present for less than 1 year in duration, and is a reportable infection in the United States because it spreads easily to sexual partners. Data on incidence and prevalence are most often based on cases reported to state health departments and are summarized by the CDC. Reported rates likely underestimate true rates because sexually transmitted infection (STI) screening and case reporting may be low in practice.1

From 2013 to 2014, the total number of syphilis cases in all stages reported to the CDC increased 12.3 percent, from 56,482 to 63,450 cases.8 During this period, reported cases of primary and secondary syphilis increased by 15.1 percent, cases of early latent syphilis increased by 14.8 percent, and cases of late and late latent syphilis increased by 7.9 percent. In 2014, the case count (19,999 cases) and rate (6.3 cases per 100,000 persons) of primary and secondary syphilis were the highest reported since 1995.

Increased rates of primary and secondary syphilis infection have occurred primarily among men, increasing from 2013 to 2014 from 10.3 to 11.7 cases per 100,000 men.8 Rates among women also increased during this same period from 0.9 to 1.1 cases per 100,000 women.

## Etiology, Natural History, and Burden of Disease

Nearly all newly acquired syphilis infections occur through sexual transmission, except for cases resulting from vertical transmission. Syphilis infection is characterized by several clinical stages and varying periods of infectivity and can affect any tissue or vascular organ.6 Syphilis is transmissible during early stages (primary and secondary syphilis), and requires exposure to open lesions with organisms present or contact of infected secretions with almost any tissue. The efficiency of transmission, or average risk of infection per exposure,9 ranges from 15.9 to 30.3 percent based on reports of partner transmission from patients with untreated early syphilis.10,11 Vertical transmission can occur during any stage. Syphilis infection is associated with HIV infection and increases risks for acquiring or spreading the HIV virus if exposed.8 The presence of syphilis infection in persons living with HIV increases HIV viral load and decreases CD4 cell count, consequently increasing the risk of HIV transmission.12-14

Specific population subgroups are disproportionally affected by syphilis infection. Studies describing prevalence rates for these groups are summarized under Contextual Question 1 in the Results section. The estimated total direct costs of treating adults with syphilis in the United States in 2010 was $39.3 million (range, $19.6 to $58.9 million).15

## Risk Factors

Several studies and the CDC have reported risk factors that may increase a person's risk for syphilis infection.8,16-18 These include previous syphilis infection, having a partner with a syphilis infection, current HIV infection, and having more than four sex partners in the preceding year.16,17 In addition, increased prevalence rates have been associated with several sociodemographic groups. These include MSM, young adult men, sex workers, adults in correctional facilities, and individuals who are of black race or live in metropolitan areas, particularly in southern and western States.19-21 Studies describing prevalence rates for these groups are summarized under Contextual Question 1 in the Results section.

## Rationale for Screening and Screening Strategies

Identification of persons with undiagnosed syphilis infections reduces the severity of complications from untreated disease as well as disease transmission.6 The availability of accurate screening tests and effective treatment make syphilis screening clinically feasible.22 Since syphilis has been associated with HIV coinfection, identification of persons infected with syphilis may also reduce rates of HIV infection.22

Screening strategies include universal or targeted screening in high-prevalence areas. Most guidelines currently recommend targeted screening based on a person's risk for infection. A study conducted in an area of high syphilis incidence demonstrated that screening for and treatment of syphilis among female inmates reduced syphilis in the general community, suggesting that targeted screening of high-risk groups may impact general population infection rates.23

Syphilis testing is particularly complicated because there is no gold standard, and testing is almost always testing for antibody, not infection. Traditionally, screening for syphilis infection is a two-step process that involves an initial nontreponemal test (Venereal Disease Research Laboratory [VDRL] or Rapid Plasma Reagin [RPR])24 followed by a confirmatory treponemal test (fluorescent treponemal antibody absorbed [FTA-ABS] or T. pallidum particle agglutination [TPPA]) (Table 2). Sensitivity of the RPR and VDRL tests are estimated to be 78 to 86 percent for detecting primary syphilis infection and 100 percent for detecting secondary infection (Table 3).1 Specificity ranges from 85 to 99 percent and may be reduced in persons who have preexisting conditions that produce false-positive results (i.e., collagen vascular disease, pregnancy, intravenous drug use, advanced malignancy, tuberculosis, malaria, and viral and rickettsia diseases). The FTA-ABS test has a reported sensitivity of 84 percent for detecting primary syphilis infection and almost 100 percent sensitivity for detecting syphilis infection in other stages, and a specificity of 97 percent.25 The TPPA test has a reported sensitivity of 88 percent for primary syphilis and 94 to 100 percent in the later stages, with a specificity of 96 percent (Table 3).25

Table 2 Tests for Syphilis26–28

Test | Use | Characteristics
Antibody tests
Nontreponemal Antibody Tests: Venereal Disease Research Laboratory (VDRL), rapid plasma reagin (RPR) | To evaluate disease activity;guide treatment; VDRL used to detect neurosyphilis | Highly sensitive; positive results must be confirmed with treponemal antibody test because it can be positive in other conditions. Nontreponemal antibodies generally disappear with treatment after 3 years.
Treponemal Antibody Tests: Fluorescent treponemal antibody absorbed (FTA-ABS), T. pallidum particle agglutination (TPPA), enzyme immunoassay (EIA), chemiluminescence immunoassay (CIA), multiplex flow immunoassay (MFI), Syphilis Health Check | Screen or confirm a positive nontreponemal antibody test | Highly specific; positive results must be followed by nontreponemal antibody test to differentiate between active and past infection. Treponemal antibodies remain positive for life, even after treatment.
Direct detection methods (less common)
Microscopic or darkfield exam: Sample from chancre is placed on a slide and examined with a special microscope | Diagnose syphilis in primary stage | Syphilis is diagnosed if bacteria are seen.
Polymerase chain reaction (PCR) | Detects genetic material of bacteria in chancre, blood, or cerebrospinal fluid | Positive test result indicates presence of T. pallidum nucleic acid

Table 3 Sensitivity and Specificity of Commonly Used Syphilis Tests^*,25,29–32^

Syphilis screening test | Mixed | Sensitivity by stage of untreated syphilis, % (range)^†^ | | | | Specificity % (range)^†^
Syphilis screening test | Mixed | | | | | Specificity % (range)^†^
Syphilis screening test | Mixed | Primary | Secondary | Latent | Tertiary | Specificity % (range)^†^
Nontreponemal
VDRL^‡^ | | 78 (74-87) | 100 | 96 (88-100) | 71 (37-94) | 98 (96-99)
RPR^‡^ | | 86 (77-99) | 100 | 98 (95-100) | 73 | 98 (93-99)
TRUST^‡^ | | 85 (77-86) | 100 | 98 (95-100) | | 99 (98-99)
USR^‡^ | | 80 (72-88) | 100 | 95 (88-100) | | 99
Treponemal
FTA-ABS^‡^ | | 84 (70-100) | 100 | 100 | 96 | 97 (84-100)
TPPA^‡^ | | 88 (86-100) | 100 | 97 (97-100) | 94 | 96 (95-100)
EIA: | | (77-100) | (85-100) | (64-100) | NA | (99-100)
Trep-Chek | 95.9^§^ | | | | | 98.5^§^
Trep-Sure | 96.9^§^ | | | | | 95.4^§^
CIA: | | 98 | 100 | 100 | 100 | 99
LIAISONǁ | 99.2 | | | | | 99.9
MFI:
BioPlex 2200 Syphilis IgG | 96.9^§^ | | | | | 98.0^§^
Syphilis Health Check | 95.6^¶^, 98.5^**^ | | | | | 90.5^¶^, 97.4^**^

* This is not a comprehensive list of tests available in the United States.

† Sensitivity and specificity of tests also depends on the disease prevalence in the population tested, and may vary considerably by manufacturer or the standard used as a comparison.

‡ Unknown reference standard.

§ When compared with FTA-ABS test results.

ǁ When compared with results from western blotting.

¶ When compared with nontreponemal test results.

** When compared with treponemal test results.

Abbreviations: CIA=chemiluminescence immunoassay; EIA=enzyme immunoassay; FTA-ABS=fluorescent treponemal antibody absorption; IgG=immunoglobulin G; MFI=multiplex flow immunoassay; NA=not applicable; RPR=rapid plasma reagin; TPPA=Treponema pallidum particle agglutination; TRUST=toluidine red unheated serum test; USR=unheated serum reagin; VDRL= Venereal Disease Research Laboratory.

Several new screening tests are currently being studied, including the immunochromatographic strip,33 line immunoassay, and rapid syphilis tests.1 Recently, the U.S. Food and Drug Administration (FDA) granted a waiver under the Clinical Laboratory Improvements Amendment allowing the distribution of a rapid screening test, the Syphilis Health Check™ test (Diagnostics Direct, LLC, Cape May, NJ), to nontraditional laboratory sites in the United States and the administration of the test by untrained operators. This test allows initial screening results from whole blood obtained from a finger stick within 12 minutes, though positive results need to be followed up with additional serology. 27 New experimental diagnostic approaches, including using the B-cell-attracting chemokine (C-X-C motif) ligand 13 as a cerebrospinal fluid (CSF) marker, may help identify suspected neurosyphilis cases. Nontreponemal screening tests followed by treponemal confirmatory tests continue to be the standard algorithm; however, interpreting false-negative and false-positive test results can be challenging due to prozone phenomena or serofast reactions (Appendix A).

In addition, variations in the sequence of testing have been proposed to reduce the time and labor involved with syphilis screening (Figure 1). The reverse sequence screening algorithm employs treponemal tests that allow automation, such as the enzyme immunoassay (EIA) or multiplex flow immunoassay (MFI), as initial screening tests, followed by supplemental nontreponemal tests for reactive specimens.34 Discordant samples (positive by the treponemal screening test, but negative by the nontreponemal supplemental test) should be tested by an additional treponemal test, preferably one that utilizes different antigens to confirm the original positive screen. When using the reverse screening approach, the positive predictive value of the treponemal screening test may be lower in populations with low prevalence of syphilis.6 Notably, reverse sequence screening identifies previously treated syphilis infections in addition to untreated or incompletely treated syphilis.

Figure 1 Screening Test Algorithms

Abbreviations: CIA=chemiluminescence immunoassay; EIA=enzyme immunoassay; FTA-ABS=fluorescent treponemal antibody absorption; RPR=rapid plasma reagin; TPPA=Treponema pallidium partical agglutianation test; VDRL=Venereal Disease Research Laboratories.

Adapted from: Centers for Disease and Prevention. Discordant results from reverse sequence syphilis screening--five laboratories, United States, 2006-2010. MMWR Morb Mortal Wkly Rep. 2011;60(5):133-7. [pmid: 21307823]. .

Figure 1 is a flow diagram depicting both the traditional and reverse sequence screening test algorithms. The algorithms are separated into three sections: screening, confirmation, and second test for discordant samples (only used in reverse sequence algorithm). The algorithms and flow diagram are further described in the text.

The yield of screening using a two-step process (RPR followed by confirmatory FTA-ABS) can be estimated using test characteristics and the incidence of syphilis infection in a given population.1 For example, in the general population (assuming a prevalence of 5 cases per 100,000 persons, an RPR sensitivity of 91% and specificity of 95%, and FTA-ABS sensitivity of 92% and specificity of 96%), more than 24,000 persons would need to be screened to detect a single case of syphilis. In a high-risk population of incarcerated women (assuming a prevalence of 12%, an RPR sensitivity of 91% and specificity of 95%, and FTA-ABS sensitivity of 92% and specificity of 96%), 10 women would need to be screened to detect a single case of syphilis.6

## Interventions and Treatment

Antibiotics are effective for treating and curing syphilis infection.3,35,36 Penicillin G, administered through injection, is the preferred drug for treating all stages of syphilis. The preparation used (i.e., benzathine, aqueous procaine, or aqueous crystalline), the dosage, and the length of treatment depend on the stage and symptoms of the disease. Selection of the appropriate penicillin preparation is important, because T. pallidum can reside in sequestered sites (e.g., the central nervous system and aqueous humor) that are poorly accessed by some forms of penicillin. Nearly all the recommendations for the treatment of syphilis are based on clinical trials and observational studies, and almost 50 years of clinical experience that support the efficacy of penicillin.6 Close followup is necessary to ensure treatment success.37 Patients with penicillin allergies whose compliance with therapy or followup cannot be ensured can be desensitized and treated with benzathine penicillin. Skin testing for penicillin allergy might be useful in some circumstances in which the reagents and expertise are available to perform the test adequately.19

Data to support the use of alternatives to penicillin in the treatment of early syphilis are limited. However, several therapies might be effective in nonpregnant, penicillin-allergic patients who have primary or secondary syphilis, including doxycycline and tetracycline.6,38,39 Compliance is likely to be better with doxycycline than tetracycline because tetracycline can cause gastrointestinal side effects. Limited clinical studies, along with biologic and pharmacologic evidence, suggest that ceftriaxone can be effective for treating early syphilis, although the optimal dose and duration of ceftriaxone therapy have not been defined.40 Azithromycin administered as a single 2-g oral dose can be effective for treating early syphilis.41-43 However, T. pallidum chromosomal mutations associated with azithromycin resistance and treatment failures have been documented in several geographical areas in the United States.44-46 As such, azithromycin should be used with caution only when treatment with penicillin or doxycycline is not feasible. Azithromycin is not recommended in MSM due to macrolide resistance patterns44 and in pregnant women due to concerns about therapeutic efficacy.47 Close followup of patients receiving alternative therapies is essential.6

Assessing response to treatment can be difficult, and definitive criteria for cure or failure have not been established. In addition, nontreponemal test titers might decline more slowly for persons who had previous syphilis infections.48 Clinical and serologic evaluations should be performed 6 and 12 months after treatment, and more frequent evaluations might be necessary if followup is uncertain and in specific subpopulations.6 For example, it is recommended that followup occurs at 3, 6, 9, 12, and 24 months after persons living with HIV are treated for primary or secondary syphilis.6 Patients with persistent signs or symptoms of recurrence with a sustained fourfold increase in nontreponemal test titer (i.e., compared with the maximum or baseline titer at the time of treatment) could have failed treatment or experienced reinfection. These patients should be retreated and reevaluated for HIV infection. Because treatment failure usually cannot be reliably distinguished from reinfection with T. pallidum, a CSF analysis should be performed.

Central nervous system involvement can occur during any stage of syphilis. However, CSF laboratory abnormalities are common with early syphilis, even in the absence of clinical neurological findings. If clinical evidence of neurologic involvement is observed (e.g., cognitive dysfunction, motor or sensory deficits, ophthalmic or auditory symptoms, cranial nerve palsies, and symptoms or signs of meningitis), a CSF examination should be performed. Patients who have neurosyphilis or syphilitic eye disease (e.g., uveitis, neuroretinitis, and optic neuritis) should be treated with the recommended regimen for neurosyphilis; those with eye disease should be managed in collaboration with an ophthalmologist. A CSF examination should be performed for all patients with syphilitic eye disease to identify those with abnormalities. Patients found to have abnormal CSF test results should be provided followup CSF examinations to assess treatment response.49

Harms of treatment include adverse drug-related effects, the most severe of which is anaphylaxis. The Jarisch-Herxheimer reaction is an acute febrile reaction usually occurring within the first 24 hours after the initiation of any therapy for syphilis and is often accompanied by headache, myalgia, fever, and other symptoms.3 Most commonly, this reaction occurs in patients with early syphilis and can be managed with antipyretics.

## Current Clinical Practice

Clinical practice may not follow screening guidelines. A review of the health care claims of 4,296 male and female patients presenting for general medical or gynecological examinations from 2000 to 2003 found that almost none had diagnostic codes for HIV, syphilis, chlamydial, or gonococcal infection, regardless of their high-risk sexual behavior status, although the high-risk sexual behavior code was generally underutilized.50 Limited use of the high-risk sexual behaviors code may reflect reluctance by patients to report these behaviors, a reluctance by providers to bill for or discuss these behaviors, or a genuinely lower rate of high-risk sexual behaviors in the analyzed population compared with general or high-risk populations. However, even among patients claiming high-risk sexual behaviors, only 25 to 39 percent were tested for syphilis infection.

## Recommendations of Other Groups

The CDC recommends universal screening based on local prevalence of early syphilis infection and advises at least annual screening in sexually active MSM. Recommendations of the American Academy of Family Physicians closely follow the USPSTF guidelines for screening in persons at increased risk, while the American Congress of Obstetricians and Gynecologists and the U.S. Department of Health and Human Services' HIV/AIDS program mirror the CDC guidelines. The Department of Health and Human Services further recommends more frequent testing for MSM who have multiple partners, and the Infectious Diseases Society of America recommends initial screening in persons with new HIV diagnoses and periodic, risk-based screening in persons living with HIV thereafter. Recommendations from the CDC and other professional groups are summarized in Table 4.

Table 4 Recommendations of Other Groups

Organization | Recommendation/Clinical Guidance
Centers for Disease Control and Prevention6 | Recommends at least annual screening in sexually active MSM using syphilis serology and confirmatory testing for those with reactive screening tests; screening in correctional facilities on the basis of local area and institutional prevalence of early infectious syphilis. HIV-infected individuals should be screened at least annually; more frequent screening may be appropriate based on individual risk behaviors and local epidemiology.
American Academy of Family Physicians51 | Strongly recommends that clinicians screen individuals at increased risk for syphilis infection. Refers to the USPSTF syphilis screening recommendations to define those at risk, which include MSM and individuals engaging in high-risk sexual behavior like commercial sex workers or individuals who exchange sex for drugs, as well as adults in correctional facilities. Recommends against routine screening of asymptomatic individuals who are not at increased risk for syphilis infection.
American Congress of Obstetricians and Gynecologists52 | Screening recommendations should be based on local area and syphilis prevalence within correctional facilities since individuals entering correctional facilities have high STI rates. Since syphilis transmission (likely through oral sex) between female sex partners can occur, providers should consider screening all females for syphilis, regardless of reported same-sex behavior.
U.S. Department of Health and Human Services HIV/AIDS Program53 | Sexually active persons with HIV who are at risk of acquiring syphilis should be screened at least annually. MSM with multiple partners should be tested every 3 to 6 months.
Infectious Diseases Society of America, HIV Medicine Association74 | All patients with HIV should be screened for syphilis upon initiation of care and periodically thereafter, depending on risk.

Abbreviations: MSM=men who have sex with men; STI=sexually transmitted infection; USPSTF=U.S. Preventive Services Task Force.