# Evidence and Quality Tables

## Appendix C1 Observational Studies of Screening Intervals for Syphilis and Screening Among Population Subgroups

Author, Year | Population, n | Interventions | Duration | Attrition | Outcomes | Quality
Bissessor et al, 2010^56^ (see text) | 1,031 MSM attending a public STI clinic in Australia, offering HIV care to 20% of men in the region | Routine syphilis screening every 3 months as part of HIV monitoring vs. annual screening (control) | 1 year | NR | [underlined: Proportion of HIV+ MSM attending the HIV clinic diagnosed with early syphilis:] Screened: 8.1% (48/587) Control: 3.1% (14/444) p=0.001 [underlined: Proportion of asymptomatic with early syphilis:] Screened: 85% (41/48) Control: 21% (3/14) p=0.006 | Fair
Bissessor et al, 2011^59^ | 6,789 consultations with MSM attending public STI clinic in Australia, offering HIV care to 20% of men in the region | A computer alert system aimed at clinicians to screen higher risk MSM (>10 partners in 12 months) for syphilis every 3 months vs. annually (control) | 1 year | NR | [underlined: Proportion of higher risk MSM diagnosed with early syphilis that are asymptomatic:] Screened: 53% (31/58) Control: 16% (5/31) p=0.001 [underlined: Proportion of lower risk MSM diagnosed with early syphilis that are asymptomatic:] Screened: 19% (3/16) Control: 10% (1/10) No difference, p=0.6 | Fair
Cohen et al, 2005^57^ | 2,389 HIV patients in the UK with newly positive syphilis serology, asymptomatic at the time of screening | Routine syphilis screening every 3 months vs. annual screening (control) | 1 year | NR | [underlined: Event rate of early asymptomatic infection, per 1,000 patient-years:] Screened: 7.3 (CI, 5.2 to 9.9) Controls: 2.8 (CI, 1.8 to 4.0) p<0.05 | Fair
Zou et al, 2013^58^ | 4,514 MSM attending public STI clinic in Australia, opting to receive clinical reminders | 3, 6, or 12 month clinical reminders vs. control | 18 months | NR | [underlined: Proportion of MSM diagnosed with syphilis at least once, n (%):] Early syphilis 3: 19 (3.2); p=0.025 6: 5 (1.9); p=0.680 3, 6, or 12: 25 (2.8); p=0.060 Control: 15 (1.5) Early, latent syphilis 3: 10 (1.7); p=0.008 6: 2 (0.8); p=0.469 3, 6, or 12: 12 (1.4); p=0.028 Control: 4 (0.4) [underlined: Proportion of all tests positive in subsequent visits, n (%):] Early syphilis 3: 22 (3.0); p=0.530 6: 5 (2.5); p=0.982 3, 6, or 12: 28 (3.0); p=0.568 Control: 15 (2.5) | Fair

Abbreviations: CI=confidence interval; HIV=human immunodeficiency virus; MSM=men who have sex with men; NR=not reported; STI=sexually transmitted infection; UK=United Kingdom.

## Appendix C2 Quality Ratings of Included Cohort Studies

Author, Year | KQ? | Did the study attempt to enroll a random sample or consecutive patients meeting inclusion criteria (inception cohort)? | Were the groups comparable at baseline? | Did the study use accurate methods for ascertaining exposures, potential confounders, and outcomes? | Were outcome assessors and/or data analysts blinded to treatment? | Did the article report attrition? | Did the study perform appropriate statistical analyses on potential confounders? | Is there important differential loss to followup or overall high loss to followup? | Were outcomes prespecified and defined, and ascertained using accurate methods? | Quality
Bissessor et al, 2010^56^ | KQ1 | Yes-- consecutive | Yes | Yes | No | No | Unclear | Unclear | Yes | Fair
Bissessor et al, 2011^59^ | KQ1 | Yes-- consecutive | Yes | Yes | No | No | Unclear | Unclear | Yes | Fair
Cohen et al, 2005^57^ | KQ1 | Yes-- consecutive | Yes | Yes | No | No | Unclear | Unclear | Yes | Fair
Zou et al, 2013^58^ | KQ1 | Yes | Yes | Yes | No | No | Yes | Unclear | Yes | Fair

Abbreviation: KQ=key question.

## Appendix C3 Diagnostic Accuracy of Syphilis Testing

Study, year | Screening test | Definition of a positive screening test | Reference standard(s) | Country, setting
Juárez-Figueroa et al, 2007^62^ | TPPA | Samples that tested positive to VDRL and FTA-ABS were defined as serologically active syphilis | VDRL screening with FTA-ABS confirmation | Mexico STI clinic
Wong et al, 2011^60^ | Trep-Sure EIA | Samples that tested positive by TPPA confirmation test | VDRL screening with TPPA confirmation | U.S. Routine syphilis testing
Tsang et al, 2007^61^ | Trep-Check IgG EIA | Consensus results were derived from conventional serologic tests, both screening (RPR, VDRL, or EIA) and confirmatory (FTA-ABS, INNO-LIA, or TPPA). Probable past syphilis infection was indicated if samples were negative by screening EIA but positive by confirmatory treponemal assay. Probable active syphilis infection was indicated if samples were positive by both the screening EIA and confirmatory treponemal assay. | RPR, VDRL, or EIA screening with FTA-ABS, INNO-LIA, or TPPA confirmation | Canada National Microbiology Laboratory

Study, year | Population characteristics | Sample size, Proportion with condition | Proportion unexaminable by screening test | Analysis of screening failures
Juárez-Figueroa et al, 2007^62^ | Asymptomatic female sex workers | 198 31/198 (15.7%) tested positive | False-positive results, defined as VDRL positive with negative FTA-ABS, or previously treated syphilis were not included in the analysis | NR
Wong et al, 2011^60^ | Patients presenting to the San Francisco municipal sexually transmitted diseases clinic. Population at this clinic is 69.3% MSM, 16.6% HIV positive. | 674 samples 39.7% tested positive for syphilis Clinic has a 9.4% prevalence rate | 0/674 | Uncategorized samples confirmed via Western blot and/or EIA for antibodies to specific treponemal antigens. These confirmatory tests are not approved for use in testing patient specimens.
Tsang et al, 2007^61^ | Specimens from local hospitals or provincial public health laboratories submitted for confirmation of local test results or for further evaluation of serologic status. | 34/604 (5.6%) | NA | Discordant test results also examined with INNO-LIA immunoassay.

Study, year | Proportion included in analysis | Sensitivity, Specificity, PPV, NPV (95% CI) | False-positives, False-negatives
Juárez-Figueroa et al, 2007^62^ | 185/198 (93%) | Sensitivity: 87.1% (70.2% to 96.3%)^*^ Specificity: 100% (97.6% to 100%)^*^ PPV: 100% (87.1% to 100%)^*^ NPV: 97.5% (93.6% to 99.3%)^*^ | FP: 0 FN: 4/185
Wong et al, 2011^60^ | 673/674 samples included in analysis. One sample did not have adequate volume for confirmation testing and was excluded. | Sensitivity: 98.0% (95.8% to 99.3%)^*^ Specificity: 98.6% (96.9% to 99.6%)^*^ PPV: 98.4% (96.2% to 99.5%)^*^ NPV: 98.4% (96.5% to 99.4%)^*^ | FP: 5/673 FN: 6/673
Tsang et al, 2007^61^ | 100% | Sensitivity: 85.3% (68.9% to 95.1%)^*^ Specificity: 95.6% (93.6% to 97.1%)^*^ PPV: 53.7% (39.6% to 67.4%)^*^ NPV: 99.1% (97.9% to 99.7%)^*^ | FP: 25/604 FN: 5/604

* Calculated.

Abbreviations: EIA=enzyme immunoassay; FN=false-negative; FP=false-positive; FTA-ABS=fluorescent treponemal antibody absorption; IgG=immunoglobulin G; MSM=men who have sex with men; NA=not available; NPV=negative predictive value; NR=not relevant; PPV=positive predictive value; RPR=rapid plasma reagin; STI=sexually transmitted infection; TPPA=Treponema pallidium partical agglutination; TRUST=toluidine red unheated serum test; VDRL=Venereal Disease Research Laboratory.

## Appendix C4 Quality Ratings of Diagnostic Accuracy Studies

Study, year | Representative spectrum | Random or consecutive sample | Screening test adequately described | Screening cutoffs predefined | Credible reference standard | Reference standard applied to and analysis includes all patients, or a random subset | Same reference standard applied to all patients | Reference standard and screening examination interpreted independently | High rate of uninterpretable results or non-compliance with screening test | Analysis includes patients with uninterpretable results or non-compliance | Quality score
Binnicker et al, 2012^28^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | No | Yes | Fair
Juárez-Figueroa et al, 2007^62^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Fair
Mishra et al, 2011^63^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | No | Yes | Fair
Tsang et al, 2007^61^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | No | Unclear | Fair
Wong et al, 2011^60^ | No | No | Yes | No | Yes | Yes | Yes | Unclear | No | Yes | Fair

## Appendix C5 Comparison of Traditional and Reverse Algorithms for Syphilis Testing

Study, year | Reverse screening algorithm | Traditional screening algorithm | Definition of a positive screening exam | Type of study | Country Setting
Mishra et al, 2011^63^ | August 2005-July 2008 EIA screening followed by RPR testing and an alternate treponemal confirmatory test. | August 1998-July 2005 RPR screening and confirmatory treponemal test | Screen-positive samples defined as reactive RPR or positive/indeterminate EIA on >1 duplicate tests of sample. Confirmed positive if a treponemal test (TPPA, FTA-ABS, or microhemagglutination assay) was positive. | Retrospective cohort | Canada Laboratory
Binnicker et al, 2012^28^ | MFI followed by RPR and TPPA for positive samples. If MFI and RPR positive, the titer of the serum sample was determined to an endpoint. | RPR screening followed by TPPA | Reverse algorithm: MFI+/RPR or TPPA+ Traditional algorithm: RPR+/TPPA+ | Prospective cohort study | U.S. Laboratory

Study, year | Population Characteristics | Sample size Proportion with condition | Analysis of screening failures | Results from traditional screening algorithm
Mishra et al, 2011^63^ | Samples submitted for syphilis screening from testing centers in the greater Toronto area between August 1998 and July 2008 were included unless they were repeat submissions after an initial positive result for a patient, or samples submitted as blood donor screening. | Total samples: 3,092,938 RPR screening samples: 2,055,913 with 0.46% prevalence EIA screening samples: 1,037,025 with 1.98% prevalence | NR | 0.59% of samples screened positive and 0.46% of samples were confirmed positive
Binnicker et al, 2012^28^ | Low-prevalence patient population | n=1,000 samples submitted for routine syphilis testing | 1 patient with an underlying HIV infection was treated for neurosyphilis based on a positive VDRL result from a cerebrospinal fluid sample. Chart reviews were conducted for final clinical interpretation of unclear results. | 4/1,000 (0.4%) samples tested positive by RPR and were confirmed by TPPA. These samples represented 1 case of newly diagnosed neurosyphilis, and 3 patients whose sera were submitted to monitor response to therapy.

Study, year | Results from reverse screening algorithm | Outcomes | Quality rating
Mishra et al, 2011^63^ | 2.24% of samples screened positive, 1.98% of samples confirmed positive. 69.6% of all confirmed positives were RPR negative. Following EIA implementation, the monthly rate of confirmed positives increased from 3.2 to 13.5 per 100,000 population (p<0.001). | Screening with EIA resulted in an increased diagnosis of syphilis which would not have been detected under screening with RPR. 74.7% (95% CI, 73.6% to 75.8%) of asymptomatic samples screened using EIA as a screening test were RPR negative. Proportion of confirmed positive tests during EIA screening that were RPR negative in patients with risk factors (%): MSM: 69.0% Intravenous drug use: 69.9% MSM and intravenous drug use: 68.0% | Fair
Binnicker et al, 2012^28^ | 15/1,000 (1.5%) samples tested positive by MFI screening. 11/15 samples would not have been detected by traditional screening. After chart review, 3 patients had a history of previously treated syphilis, 6 patients were interpreted as false-positive screening results based on alternative diagnosis and/or negative TPPA results, and 2 patients were diagnosed with possible latent syphilis. | Reverse screening in a low-prevalence population results in a higher false-positive rate compared with traditional testing (0.6% vs. 0.0%; p=0.03); however, reverse screening detected 2 patients with possible latent syphilis who were not detected by the traditional screening algorithm. | Fair

Abbreviations: EIA=enzyme immunoassay; FTA-ABS=fluorescent treponemal antibody absorption; MFI=multiplex flow immunoassay; MSM=men who have sex with men; NR=not reported; RPR=rapid plasma reagin; TPPA=Treponema pallidum particle agglutination; VDRL= Venereal Disease Research Laboratory.