# Detailed Methods

## Appendix B1 Search Strategies

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp Treponema pallidum/
2. exp Syphilis/ or syphili$.mp.
3. 1 or 2
4. exp mass screening/ or screen$.mp.
5. 3 and 4
6. limit 5 to english language
7. limit 5 to abstracts
8. 6 or 7

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp Treponema pallidum/
2. exp Syphilis/ep, et, pc, px, tm
3. 1 or 2
4. exp risk/
5. ((assess$ or stratif$ or quantif$ or identif$) adj7 risk$).mp.
6. 4 or 5
7. 3 and 6

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp Treponema pallidum/
2. exp Syphilis/di
3. 1 or 2
4. exp “Sensitivity and Specificity”/
5. 3 and 4
6. exp Diagnostic Errors/
7. 3 and 6
8. 5 or 7
9. (fals$ adj3 (positiv$ or negativ$)).mp.
10. 3 and 9
11. (accura$ or inaccura$ or (predict$ adj5 (value$ or able or abilit$ or capab$ or effectiv$ or unable or inabilit$ or incapab$ or ineffect$ or correct$))).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
12. 3 and 11
13. 8 or 10 or 12

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. screen$.mp.
4. exp Mass Screening/
5. 3 or 4
6. 1 or 2
7. 5 and 6

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. 1 or 2
4. exp Risk/
5. risk$.mp.
6. 4 or 5
7. 3 and 6

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. 1 or 2
4. exp “Sensitivity and Specificity”/
5. exp Diagnostic Errors/
6. (diagnos$ adj3 (mistak$ or error$ or erroneous$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7. (fals$ adj3 (positiv$ or negativ$)).mp.
8. (accura$ or inaccura$ or (predict$ adj5 (value$ or able or abilit$ or capab$ or effectiv$ or unable or inabilit$ or incapab$ or ineffect$ or correct$))).mp.
9. 4 or 5 or 6 or 7 or 8
10. 3 and 9

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. screen$.mp.
4. [exp Mass Screening/]
5. 3 or 4
6. 1 or 2
7. 5 and 6

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. 1 or 2
4. [exp Risk/]
5. risk$.mp.
6. 4 or 5
7. 3 and 6

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. 1 or 2
4. [exp “Sensitivity and Specificity”/]
5. [exp Diagnostic Errors/]
6. (diagnos$ adj3 (mistak$ or error$ or erroneous$)).mp. [mp=title, abstract, full text, keywords, caption text]
7. (fals$ adj3 (positiv$ or negativ$)).mp.
8. (accura$ or inaccura$ or (predict$ adj5 (value$ or able or abilit$ or capab$ or effectiv$ or unable or inabilit$ or incapab$ or ineffect$ or correct$))).mp.
9. 4 or 5 or 6 or 7 or 8
10. 3 and 9

Database: EBM Reviews - Database of Abstracts of Reviews of Effects

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. screen$.mp.
4. [exp Mass Screening/]
5. 3 or 4
6. 1 or 2
7. 5 and 6

Database: EBM Reviews - Database of Abstracts of Reviews of Effects

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. 1 or 2
4. [exp Risk/]
5. risk$.mp.
6. 4 or 5
7. 3 and 6

Database: EBM Reviews - Database of Abstracts of Reviews of Effects

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. 1 or 2
4. [exp “Sensitivity and Specificity”/]
5. [exp Diagnostic Errors/]
6. (diagnos$ adj3 (mistak$ or error$ or erroneous$)).mp. [mp=title, full text, keywords]
7. (fals$ adj3 (positiv$ or negativ$)).mp.
8. (accura$ or inaccura$ or (predict$ adj5 (value$ or able or abilit$ or capab$ or effectiv$ or unable or inabilit$ or incapab$ or ineffect$ or correct$))).mp.
9. 4 or 5 or 6 or 7 or 8
10. 3 and 9

Database: EBM Reviews - NHS Economic Evaluation Database

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. screen$.mp.
4. exp Mass Screening/
5. 3 or 4
6. 1 or 2
7. 5 and 6

Database: EBM Reviews - NHS Economic Evaluation Database

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. 1 or 2
4. exp Risk/
5. risk$.mp.
6. 4 or 5
7. 3 and 6

Database: EBM Reviews - NHS Economic Evaluation Database

Search Strategy:

--------------------------------------------------------------------------------

1. syphil$.mp.
2. treponema pallidum.mp.
3. 1 or 2
4. exp “Sensitivity and Specificity”/
5. exp Diagnostic Errors/
6. (diagnos$ adj3 (mistak$ or error$ or erroneous$)).mp. [mp=title, text, subject heading word]
7. (fals$ adj3 (positiv$ or negativ$)).mp.
8. (accura$ or inaccura$ or (predict$ adj5 (value$ or able or abilit$ or capab$ or effectiv$ or unable or inabilit$ or incapab$ or ineffect$ or correct$))).mp.
9. 4 or 5 or 6 or 7 or 8
10. 3 and 9

## Appendix B2 Inclusion and Exclusion Criteria

| Include | Exclude
Definition of Disease | Positive for syphilis on any test modality
Populations | Asymptomatic, nonpregnant adults and adolescents, including those who are coinfected with other STIs, including HIV | Symptomatic patients; neonates, infants, and children; pregnant women; contacts of cases; studies of HIV patients for whom syphilis testing is disease management rather than a screening intervention
Interventions
KQs 1, 4 | Screening effectiveness including effectiveness of different screening intervals
KQs 2 | Risk assessment instruments and other risk stratification methods that identify individuals at increased risk for syphilis infection
KQs 3 | FDA cleared tests available in the United States that detect syphilis in biological specimens including varying testing strategies (e.g., traditional, reverse sequence)
Comparators
KQs 1, 4 | No screening or alternate screening strategy or methods | No comparison
KQ 2 | True disease status | No comparison
KQs 3 | Study-specific comparator or gold standard, as determined by the study itself (e.g., an enzyme-linked immunosorbent assay technique could be evaluated by comparing its sensitivity and specificity with that of MHA-TP and FTA-ABS tests) | No comparison
Outcomes
KQ 1 | Reduction in: Complications of syphilis (e.g., neurosyphilis, symptomatic neurosyphilis, tertiary syphilis, congenital syphilis) Disease transmission, including HIV transmission Other clinical outcomes, rates of infection and other similar measures of infection | Outcomes that are not directly related to health outcomes (e.g., laboratory studies)
KQ 2 | Detection of infection
KQ 3 | Diagnostic accuracy (i.e., measures of the test's sensitivity, specificity, positive and negative predictive values, and other related measures)
KQ 4 | Harms from screening (e.g., labeling, false-negative, false-positive, harms related to false-positive and false negative tests, including psychosocial harms) | Harms related to true positive and true negative tests, including psychosocial harms
Setting | Primary care and primary care–referable settings (e.g., correctional facilities and community care, such as schools, family planning clinics, obstetrics and gynecology clinics, emergency departments, and STI clinics)
Study Designs
All KQs | Good-quality systematic reviews
Benefits | RCTs, observational studies with comparison groups, including ecological studies | Observational studies without comparison groups, case reports
Harms | RCTs, observational studies including cross-sectional studies and ecological studies | Case studies

Abbreviations: FDA=U.S. Food and Drug Administration; KQ=key question; RCT=randomized, controlled trial; STI=sexually transmitted infection.

## Appendix B3 Literature Flow by Key Question

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Other sources include reference lists and experts.

Appendix B3 is a flow diagram that summarizes the search and selection of articles. There were 2,000 citations identified by searching MEDLINE, the Cochrane databases, and other sources including reference lists, hand searching, and suggestions by experts. Of these, 1,552 were excluded at the abstract level because they did not address a Key Question or only addressed background information. The remaining 448 articles were retrieved and reviewed for relevance to the Key Questions. There were 439 full-text articles excluded for the following reasons: wrong population, wrong intervention, wrong outcomes, wrong study design for the Key Question, wrong publication type, only available in a foreign language, a study included in an included systematic review, wrong comparison, no or inadequate reference standard used, a review not meeting inclusion criteria, or population not applicable to a U.S. population. Some studies may have addressed more than one Key Question. A total of 9 studies were included. For Key Question 1, 4 observational studies were included. For Key Questions 2 and 4, no studies were found. For Key Question 3, 2 observational studies were included relating to testing sequence and 3 observational studies were included relating to test accuracy.

## Appendix B4 List of Excluded Studies

Adolf R, Bercht F, Aronis ML, et al. Prevalence and risk factors associated with syphilis in a cohort of HIV positive individuals in Brazil. AIDS Care. 2012;24:252-8. Exclusion: Population not applicable to U.S. population. [pmid: 21780954].
Agmon-Levin N, Elbirt D, Asher I, et al. Syphilis and HIV co-infection in an Israeli HIV clinic: incidence and outcome. Int J STD AIDS. 2010;21(4):249-52. Exclusion: Population not applicable to U.S. population. [pmid: 20378895].
Aktas G, Young H, Moyes A, et al. Evaluation of the serodia Treponema pallidum particle agglutination, the Murex Syphilis ICE and the Enzywell TP tests for serodiagnosis of syphilis. Int J STD AIDS. 2005;16(4):294-8. Exclusion: Wrong population. [pmid: 15899082].
Aktas G, Young H, Moyes A, et al. Evaluation of the fluorescent treponemal antibody absorption test for detection of antibodies (immunoglobulins G and M) to Treponema pallidum in serologic diagnosis of syphilis. Int J STD AIDS. 2007;18(4):255-60. Exclusion: Wrong population. [pmid: 17509177].
Alim A, Artan MO, Baykan Z, et al. Seroprevalence of hepatitis B and C viruses, HIV, and syphilis infections among engaged couples. Saudi Med J. 2009;30(4):541-5. Exclusion: Wrong outcomes. [pmid: 19370284].
Allen K, Guy R, Leslie D, et al. The rise of infectious syphilis in Victoria and the impact of enhanced clinical testing. Aust N Z J Public Health. 2008;32(1):38-42. Exclusion: Wrong outcomes. [pmid: 18290912].
American Association for Clinical Chemistry. Syphilis Tests. Available at: http://labtestsonline.org/understanding/analytes/syphilis/tab/test. June 22, 2015. Exclusion: custom 7.
Amin AK, Manuel RJ, Ison CA, et al. Audit of laboratory diagnostic methods for syphilis in England and Wales. Sex Transm Infect. 2009;85(2):88-91. Exclusion: Wrong outcomes. [pmid: 19004864].
Araujo CL, Shimizu HE, Sousa AI, et al. Incidence of congenital syphilis in Brazil and its relationship with the Family Health Strategy. Rev Saude Publica. 2012;46(3):479-86. Exclusion: Wrong population. [pmid: 22635036].
Armed Forces Health Surveillance Center. Sexually transmitted infections, active component, U.S. Armed Forces, 2000-2012. MSMR. 2013;20(2):5-10. Exclusion: Wrong outcomes.
Armstrong H, Fernando I. An audit of partner notification for syphilis and HIV. Int J STD AIDS. 2012;23(11):825-6. Exclusion: Wrong study design for Key Question. [pmid: 23155105].
Arnold CA, Limketkai BN, Illei PB, et al. Syphilitic and lymphogranuloma venereum (LGV) proctocolitis: clues to a frequently missed diagnosis. Am J Surg Pathol. 2013;37(1):38-46. Exclusion: Wrong outcomes. [pmid: 23095509].
Arora C, Mishra B, Malik JS. Study of STD pattern and its associated risk factors--a hospital study. J Commun Dis. 2006;38(1):70-3. Exclusion: Wrong outcomes. [pmid: 17370691].
Artz L, Macaluso M, Meinzen-Derr J, et al. A randomized trial of clinician-delivered interventions promoting barrier contraception for sexually transmitted disease prevention. Sex Transm Dis. 2005;32(11):672-9. Exclusion: Wrong intervention. [pmid: 16254541].
Arumainayagam J, Pallan MJ, Buckley E, et al. Syphilis outbreak in Walsall, UK: lessons for control and prevention. Int J STD AIDS. 2007;18(1):55-7. Exclusion: Wrong outcomes. [pmid: 17326864].
Augenbraun M, French A, Glesby M, et al. Hepatitis C virus infection and biological false-positive syphilis tests. Sex Transm Infect. 2010;86(2):97-8. Exclusion: Wrong outcomes. [pmid: 20332367].
Aung WW, Thant M, Wai KT, et al. Sexually transmitted infections among male highway coach drivers in Myanmar. Southeast Asian J Trop Med Public Health. 2013;44(3):436-47. Exclusion: Wrong outcomes. [pmid: 24050075].
Azariah S. An audit of patients treated for syphilis at Auckland Sexual Health Service. N Z Med J. 2010;123(1315):55-64. Exclusion: Wrong outcomes. [pmid: 20581931].
Azariah S, Perkins N. Prevalence of sexually transmitted infections in men who have sex with men presenting to Auckland Sexual Health Service. N Z Med J. 2010;123(1322):46-54. Exclusion: Wrong study design for Key Question. [pmid: 20930891].
Azariah S, Perkins N, Austin P, et al. Increase in incidence of infectious syphilis in Auckland, New Zealand: results from an enhanced surveillance survey. Sex Health. 2008;5(3):303-4. Exclusion: Wrong outcomes. [pmid: 18771648].
Baffi CW, Aban I, Willig JH, et al. New syphilis cases and concurrent STI screening in a southeastern U.S. HIV clinic: a call to action. AIDS Patient Care STDS. 2010;24(1):23-9. Exclusion: Included for contextual questions only. [pmid: 20095902].
Baguley SD, Horner PJ, Maple PA, et al. An oral fluid test for syphilis. Int J STD AIDS. 2005;16(4):299-301. Exclusion: Wrong population. [pmid: 15899083].
Balba GP, Kumar PN, James AN, et al. Ocular syphilis in HIV-positive patients receiving highly active antiretroviral therapy. Am J Med. 2006;119(5):448.e21-5. Exclusion: Wrong outcomes. [pmid: 16651059].
Behrhof W, Springer E, Brauninger W, et al. PCR testing for Treponema pallidum in paraffin-embedded skin biopsy specimens: test design and impact on the diagnosis of syphilis. J Clin Pathol. 2008;61(3):390-5. Exclusion: Wrong intervention. [pmid: 17557863].
Beltrami JF, Williams S, Valentine J. STD screening and treatment during jail intake: the National Syphilis Elimination perspective. Sex Transm Dis. 2007;34(2):120-1. Exclusion: Wrong publication type. [pmid: 17251753].
Benson PA, Hergenroeder AC. Bacterial sexually transmitted infections in gay, lesbian, and bisexual adolescents: medical and public health perspectives. Semin Pediatr Infect Dis. 2005;16(3):181-91. Exclusion: Wrong publication type. [pmid: 16044392].
Benzaken AS, Bazzo ML, Galban E, et al. External quality assurance with dried tube specimens (DTS) for point-of-care syphilis and HIV tests: experience in an indigenous populations screening programme in the Brazilian Amazon. Sex Transm Infect. 2014;90(1):14-8. Exclusion: Wrong outcomes. [pmid: 24031029].
Benzaken AS, Galban Garcia E, Sardinha JC, et al. Rapid tests for diagnosing syphilis: validation in an STD clinic in the Amazon Region, Brazil. Cad Saude Publica. 2007;23(Suppl 3):S456-64. Exclusion: Wrong intervention. [pmid: 17992351].
Benzaken AS, Sabido M, Galban EG, et al. Field evaluation of the performance and testing costs of a rapid point-of-care test for syphilis in a red-light district of Manaus, Brazil. Sex Transm Infect. 2008;84(4):297-302. Exclusion: Wrong intervention. [pmid: 18305119].
Beraud G, Pierre-Francois S, Theodose R, et al. Anicteric cholestasis among HIV infected patients with syphilis. Scand J Infect Dis. 2009;41(6-7):524-7. Exclusion: Wrong outcomes. [pmid: 19263273].
Bibi I, Devrajani BR, Shah SZ, et al. Frequency of syphilis in female sex workers at red light area of Hyderabad, Pakistan. J Pak Med Assoc. 2010;60(5):353-6. Exclusion: Wrong outcomes. [pmid: 20527605].
Binnicker MJ, Yao JD, Cockerill FR 3rd. Non-treponemal serologic tests: a supplemental, not confirmatory testing approach. Clin Infect Dis. 2011;52(2):274-5. author reply 5-6. Exclusion: Wrong publication type. [pmid: 21288856].
Blank S, Gallagher K, Washburn K, et al. Reaching out to boys at bars: utilizing community partnerships to employ a wellness strategy for syphilis control among men who have sex with men in New York City. Sex Transm Dis. 2005;32(10 Suppl):S65-72. Exclusion: Wrong outcomes. [pmid: 16205296].
Blank S, McDonnell DD, Rubin SR, et al. New approaches to syphilis control. Finding opportunities for syphilis treatment and congenital syphilis prevention in a women's correctional setting. Sex Transm Dis. 1997;24(4):218-26. Exclusion: Wrong publication type. [pmid: 9101633].
Borelli S, Monn A, Meyer J, et al. Evaluation of a particle gel immunoassay as a screening test for syphilis. Infection. 2009;37(1):26-8. Exclusion: Wrong intervention. [pmid: 19169636].
Borghi J, Gorter A, Sandiford P, et al. The cost-effectiveness of a competitive voucher scheme to reduce sexually transmitted infections in high-risk groups in Nicaragua. Health Policy Plan. 2005;20(4):222-31. Exclusion: Wrong outcomes. [pmid: 15965034].
Bosshard PP. Usefulness of IgM-specific enzyme immunoassays for serodiagnosis of syphilis: comparative evaluation of three different assays. J Infect. 2013;67(1):35-42. Exclusion: Wrong population. [pmid: 23542782].
Botham SJ, Ressler KA, Bourne C, et al. Epidemic infectious syphilis in inner Sydney--strengthening enhanced surveillance. Aust N Z J Public Health. 2006;30(6):529-33. Exclusion: Wrong outcomes. [pmid: 17209268].
Bourne C, Knight V, Guy R, et al. Short message service reminder intervention doubles sexually transmitted infection/HIV re-testing rates among men who have sex with men. Sex Transm Infect. 2011;87(3):229-31. Exclusion: Wrong outcomes. [pmid: 21296796].
Bowden FJ, O'Keefe EJ, Primrose R, et al. Sexually transmitted infections, blood-borne viruses and risk behaviour in an Australian senior high school population--the SHLiRP study. Sex Health. 2005;2(4):229-36. Exclusion: Wrong outcomes. [pmid: 16402670].
Bradshaw CS, Pierce LI, Tabrizi SN, et al. Screening injecting drug users for sexually transmitted infections and blood borne viruses using street outreach and self collected sampling. Sex Transm Infect. 2005;81(1):53-8. Exclusion: Wrong outcomes. [pmid: 15681724].
Branger J, van der Meer JT, van Ketel RJ, et al. High incidence of asymptomatic syphilis in HIV-infected MSM justifies routine screening. Sex Transm Dis. 2009;36(2):84-5. Exclusion: Included for contextual questions only. [pmid: 18971797].
Brewer DD. Case-finding effectiveness of partner notification and cluster investigation for sexually transmitted diseases/HIV. Sex Transm Dis. 2005;32(2):78-83. Exclusion: Wrong study design for Key Question. [pmid: 15668612].
Brewer TH, Peterman TA, Newman DR, et al. Reinfections during the Florida syphilis epidemic, 2000-2008. Sex Transm Dis. 2011;38(1):12-7. Exclusion: Wrong outcomes. [pmid: 20739912].
Brodsky JL, Samuel MC, Mohle-Boetani JC, et al. Syphilis outbreak at a California men's prison, 2007-2008: propagation by lapses in clinical management, case management, and public health surveillance. J Correct Health Care. 2013;19(1):54-64. Exclusion: Included for contextual questions only. [pmid: 22989493].
Brosh-Nissimov T, Mor Z, Avramovich E, et al. Syphilis outbreak among men who have sex with men, Tel Aviv, Israel, 2008-2009. Isr Med Assoc J. 2012;14(3):152-6. Exclusion: Wrong outcomes. [pmid: 22675853].
Buchacz K, Klausner JD, Kerndt PR, et al. HIV incidence among men diagnosed with early syphilis in Atlanta, San Francisco, and Los Angeles, 2004 to 2005. J Acquir Immune Defic Syndr. 2008;47(2):234-40. Exclusion: Wrong outcomes. [pmid: 18340654].
Buchacz KA, Siller JE, Bandy DW, et al. HIV and syphilis testing among men who have sex with men attending sex clubs and adult bookstores--San Francisco, 2003. J Acquir Immune Defic Syndr. 2004;37(2):1324-6. Exclusion: Wrong publication type. [pmid: 15385742].
Buffet M, Grange PA, Gerhardt P, et al. Diagnosing Treponema pallidum in secondary syphilis by PCR and immunohistochemistry. J Invest Dermatol. 2007;127(10):2345-50. Exclusion: Wrong population. [pmid: 17554371].
Burchell AN, Allen VG, Gardner SL, et al. High incidence of diagnosis with syphilis co-infection among men who have sex with men in an HIV cohort in Ontario, Canada. BMC Infect Dis. 2015;15:356. Exclusion: Wrong study design for Key Question. [pmid: 26289937].
Burchell AN, Allen VG, Moravan V, et al. Patterns of syphilis testing in a large cohort of HIV patients in Ontario, Canada, 2000-2009. BMC Infect Dis. 2013;13:246. Exclusion: Wrong outcomes. [pmid: 23710699].
Burke R, Rhodes J. Lessons learned on the implementation of jail syphilis screening in Nashville, Davidson County Jail, 1999-2005. Sex Transm Dis. 2009;36(2 Suppl):S14-6. Exclusion: Wrong outcomes. [pmid: 17898676].
Busse C, Navid MH, Strubel A, et al. Evaluation of a new recombinant antigen-based Virotech Treponema pallidum screen ELISA for diagnosis of syphilis. Clin Lab. 2013;59(5-6):523-9. Exclusion: Wrong population. [pmid: 23865350].
Cade JE, Boozer CH, Leigh JE. Seropositivity of the rapid plasma reagin (RPR) test in a dental school patient population: a retrospective study. J Public Health Dent. 2003;63(1):61-3. Exclusion: Wrong outcomes. [pmid: 12597587].
Cai R, Tan JG, Chen L, et al. Prevalence and risk factors of syphilis infection among female sex workers in Shenzhen, China: an observational study (2009-2012). Trop Med Int Health. 2013;18(12):1531-8. Exclusion: Population not applicable to U.S. population. [pmid: 24118535].
Callander D, Baker D, Chen M, et al. Including syphilis testing as part of standard HIV management checks and improved syphilis screening in primary care. Sex Transm Dis. 2013;40(4):338-40. Exclusion: Wrong outcomes. [pmid: 23486501].
Callegari FM, Pinto-Neto LF, Medeiros CJ, et al. Syphilis and HIV co-infection in patients who attend an AIDS outpatient clinic in Vitoria, Brazil. AIDS Behav. 2014;18(Suppl 1):S104-9. Exclusion: Population not applicable to U.S. population. [pmid: 23732958].
Campos LN, Guimaraes MD, Carmo RA, et al. HIV, syphilis, and hepatitis B and C prevalence among patients with mental illness: a review of the literature. Cad Saude Publica. 2008;24(Suppl 4):s607-20. Exclusion: Review not meeting inclusion criteria. [pmid: 18797734].
Campos PE, Buffardi AL, Carcamo CP, et al. Reaching the unreachable: providing STI control services to female sex workers via mobile team outreach. PLoS One. 2013;8(11):e81041. Exclusion: Population not applicable to U.S. population. [pmid: 24282565].
Campos PE, Buffardi AL, Chiappe M, et al. Utility of the Determine Syphilis TP rapid test in commercial sex venues in Peru. Sex Transm Infect. 2006;82(Suppl 5):v22-5. Exclusion: Wrong intervention. [pmid: 17116642].
Cao Z, Xu J, Zhang H, et al. Risk factors for syphilis among married men who have sex with men in China. Sex Transm Dis. 2014;41(2):98-102. Exclusion: Population not applicable to U.S. population. [pmid: 24413488].
Carcamo CP, Campos PE, Garcia PJ, et al. Prevalences of sexually transmitted infections in young adults and female sex workers in Peru: a national population-based survey. Lancet Infect Dis. 2012;12(10):765-73. Exclusion: Population not applicable to U.S. population. [pmid: 22878023].
Castro AR, Esfandiari J, Kumar S, et al. Novel point-of-care test for simultaneous detection of nontreponemal and treponemal antibodies in patients with syphilis. J Clin Microbiol. 2010;48(12):4615-9. Exclusion: Wrong population. [pmid: 20881177].
Castro R, Lopes A, da Luz Martins Pereira F. Evaluation of an immunochromatographic point-of-care test for the simultaneous detection of nontreponemal and treponemal antibodies in patients with syphilis. Sex Transm Dis. 2014;41(8):467-9. Exclusion: Wrong population. [pmid: 25013972].
Castro R, Prieto ES, Aguas MJ, et al. Evaluation of the Treponema pallidum particle agglutination technique (TP.PA) in the diagnosis of neurosyphilis. J Clin Lab Anal. 2006;20(6):233-8. Exclusion: Wrong population. [pmid: 17115423].
Castro R, Prieto ES, da Luz Martins Pereira F. Nontreponemal tests in the diagnosis of neurosyphilis: an evaluation of the Venereal Disease Research Laboratory (VDRL) and the rapid plasma reagin (RPR) tests. J Clin Lab Anal. 2008;22(4):257-61. Exclusion: Wrong population. [pmid: 18623120].
Causer LM, Kaldor JM, Fairley CK, et al. A laboratory-based evaluation of four rapid point-of-care tests for syphilis. PLoS One. 2014;9(3):e91504. Exclusion: Wrong population. [pmid: 24618681].
Centers for Disease Control and Prevention. Primary and secondary syphilis--Jefferson County, Alabama, 2002-2007. MMWR Morb Mortal Wkly Rep. 2009;58(17):463-7. Exclusion: Wrong study design for Key Question. [pmid: 19444149].
Centers for Disease Control and Prevention. Syphilis outbreak among American Indians--Arizona, 2007-2009. MMWR Morb Mortal Wkly Rep. 2010;59(6):158-61. Exclusion: Wrong outcomes. [pmid: 20168294].
Centers for Disease Control and Prevention. STD surveillance case definitions. Available at: http://www.cdc.gov/std/stats/CaseDefinitions-2014.pdf. February 27, 2015. Exclusion: custom 7.
Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2011. Atlanta, GA. Department of Health and Human Services. 2012. http://www.cdc.gov/std/stats11/Surv2011.pdf. January 14, 2015. Exclusion: Custom 7.
Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2013. Atlanta, GA. Department of Health and Human Services. 2014. http://www.cdc.gov/std/stats13/surv2013-print.pdf. April 3, 2015. Exclusion: Custom 7.
Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2014. Atlanta, GA. Department of Health and Human Services. 2015. http://www.cdc.gov/std/stats14/surv-2014-print.pdf. March 9, 2016. Exclusion: Custom 7.
Champenois K, Cousien A, Ndiaye B, et al. Risk factors for syphilis infection in men who have sex with men: results of a case-control study in Lille, France. Sex Transm Infect. 2013;89(2):128-32. Exclusion: Wrong outcomes. [pmid: 22679099].
Chang CC, Leslie DE, Spelman D, et al. Symptomatic and asymptomatic early neurosyphilis in HIV-infected men who have sex with men: a retrospective case series from 2000 to 2007. Sex Health. 2011;8(2):207-13. Exclusion: Wrong population. [pmid: 21592435].
Chauhan M, Serisha B, Sankar KN, et al. Audit of the use of benzathine penicillin, post-treatment syphilis serology and partner notification of patients with early infectious syphilis. Int J STD AIDS. 2006;17(3):200-2. Exclusion: Wrong study design for Key Question. [pmid: 16510011].
Chen JL, Bovee MC, Kerndt PR. Sexually transmitted diseases surveillance among incarcerated men who have sex with men--an opportunity for HIV prevention. AIDS Educ Prev. 2003;15(1 Suppl A):117-26. Exclusion: Wrong outcomes. [pmid: 12630604].
Chen XS, Wang QQ, Yin YP, et al. Prevalence of syphilis infection in different tiers of female sex workers in China: implications for surveillance and interventions. BMC Infect Dis. 2012;12:84. Exclusion: Population not applicable to U.S. population. [pmid: 22475187].
Cheung KK, Montgomery D, Benjamins LJ. Prevalence of sexually transmitted infections among adolescents entering Child Protective Services. J Pediatr Adolesc Gynecol. 2015;28(5):324-6. Exclusion: Wrong study design for Key Question. [pmid: 26094906].
Choe PG, Song JS, Song KH, et al. Usefulness of routine lumbar puncture in non-HIV patients with latent syphilis of unknown duration. Sex Transm Infect. 2010;86(1):39-40. Exclusion: Wrong intervention. [pmid: 19837729].
Choi KH, Ning Z, Gregorich SE, et al. The influence of social and sexual networks in the spread of HIV and syphilis among men who have sex with men in Shanghai, China. J Acquir Immune Defic Syndr. 2007;45(1):77-84. Exclusion: Population not applicable to U.S. population. [pmid: 17325608].
Chow EP, Wilson DP, Zhang L. HIV and syphilis co-infection increasing among men who have sex with men in China: a systematic review and meta-analysis. PLoS One. 2011;6(8):e22768. Exclusion: Wrong outcomes. [pmid: 21857952].
Ciesielski C, Kahn RH, Taylor M, et al. Control of syphilis outbreaks in men who have sex with men: the role of screening in nonmedical settings. Sex Transm Dis. 2005;32(10 Suppl):S37-42. Exclusion: Wrong outcomes. [pmid: 16205290].
Clement ME, Hicks CB. RPR and the serologic diagnosis of syphilis. JAMA. 2014;312(18):1922-3. Exclusion: Wrong study design for Key Question. [pmid: 25387191].
Cohen CE, Winston A, Asboe D, et al. Screening for syphilis in HIV-positive men who have sex with men (MSM). Int J STD AIDS. 2006;17(2):142. Exclusion: Wrong publication type. [pmid: 16464283].
Cohen RS, Xiong SC, Sakamoto P. Retrospective review of serological testing of potential human milk donors. Arch Dis Child Fetal Neonatal Ed. 2010;95(2):F118-20. Exclusion: Wrong outcomes. [pmid: 20231217].
Cohen SE, Chew Ng RA, Katz KA, et al. Repeat syphilis among men who have sex with men in California, 2002-2006: implications for syphilis elimination efforts. Am J Public Health. 2012;102(1):e1-8. Exclusion: Wrong population. [pmid: 22095364].
Cohen SE, Klausner JD, Engelman J, et al. Syphilis in the modern era: an update for physicians. Infect Dis Clin North Am. 2013;27(4):705-22. Exclusion: Wrong publication type. [pmid: 24275265].
Colletti JE, Giudice EL. Syphilis screening in a high-risk, inner-city adolescent population. Am J Emerg Med. 2005;23(2):225-6. Exclusion: Wrong population. [pmid: 15765357].
Cornish N. A new reflex testing algorithm for syphilis screening. MLO Med Lab Obs. 2011;43(6):40-1. Exclusion: Wrong publication type. [pmid: 21882763].
Couture MC, Soto JC, Akom E, et al. Clients of female sex workers in Gonaives and St-Marc, Haiti: characteristics, sexually transmitted infection prevalence and risk factors. Sex Transm Dis. 2008;35(10):849-55. Exclusion: Population not applicable to U.S. population. [pmid: 18580821].
Cowan S. Syphilis in Denmark--outbreak among MSM in Copenhagen, 2003-2004. Euro Surveill. 2004;9(12):25-7. Exclusion: Wrong study design for Key Question. [pmid: 15677850].
Coyne KM, Banks A, Heggie C, et al. Sexual health of adults working in pornographic films. Int J STD AIDS. 2009;20(7):508-9. Exclusion: Wrong outcomes. [pmid: 19541897].
Creegan L, Bauer HM, Samuel MC, et al. An evaluation of the relative sensitivities of the Venereal Disease Research Laboratory test and the Treponema pallidum particle agglutination test among patients diagnosed with primary syphilis. Sex Transm Dis. 2007;34(12):1016-8. Exclusion: Wrong population. [pmid: 18080352].
Cronin M, Domegan L, Thornton L, et al. The epidemiology of infectious syphilis in the Republic of Ireland. Euro Surveill. 2004;9(12):14-7. Exclusion: Wrong outcomes. [pmid: 15677853].
Cunningham SD, Olthoff G, Burnett P, et al. Evidence of heterosexual bridging among syphilis-positive men who have sex with men. Sex Transm Infect. 2006;82(6):444-5. Exclusion: Wrong outcomes. [pmid: 17151030].
Dai S, Chi P, Lin Y, et al. Improved reverse screening algorithm for Treponema pallidum antibody using signal-to-cutoff ratios from chemiluminescence microparticle immunoassay. Sex Transm Dis. 2014;41(1):29-34. Exclusion: Wrong population. [pmid: 24326578].
Davies SC, Madjid B, Pardohudoyo S, et al. Prevalence of sexually transmissible infections (STI) among male patients with STI in Denpasar and Makassar, Indonesia: are symptoms of urethritis sufficient to guide syndromic treatment?. Sex Health. 2007;4(3):213-5. Exclusion: Population not applicable to U.S. population. [pmid: 17931536].
de Larranaga G, Trombetta L, Wingeyer SP, et al. False positive reactions in confirmatory tests for syphilis in presence of antiphospholipid antibodies: misdiagnosis with prognostic and social consequences. Dermatol Online J. 2006;12(4):22. Exclusion: Wrong study design for Key Question. [pmid: 17083877].
Debattista J, Dwyer J, Anderson R, et al. Screening for syphilis among men who have sex with men in various clinical settings. Sex Transm Infect. 2004;80(6):505-8. Exclusion: Wrong population. [pmid: 15572624].
Dhairyawan R, Creighton S, Sivyour L, et al. Testing the fathers: carrying out HIV and STI tests on partners of pregnant women. Sex Transm Infect. 2012;88(3):184-6. Exclusion: Wrong comparison. [pmid: 22199134].
Diagnostics Direct LLC. 510(k) Substantial equivalence determination decision summary #K102400. http://www.accessdata.fda.gov/cdrh_docs/reviews/k102400.pdf. May 19, 2015. Exclusion: custom 7.
Diaz T, Almeida MG, Georg I, et al. Evaluation of the Determine Rapid Syphilis TP assay using sera. Clin Diagn Lab Immunol. 2004;11(1):98-101. Exclusion: Wrong population. [pmid: 14715552].
Dissemination CfRa. The efficacy of clinic-based interventions aimed at increasing screening for bacterial sexually transmitted infections among men who have sex with men: a systematic review. (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014;(4). Exclusion: Wrong publication type.
Dlamini NR, Phili R, Connolly C. Evaluation of rapid syphilis tests in KwaZulu-Natal. J Clin Lab Anal. 2014;28(1):77-81. Exclusion: Wrong population. [pmid: 24395488].
Dodge B, Reece M, Herbenick D, et al. Relations between sexually transmitted infection diagnosis and sexual compulsivity in a community-based sample of men who have sex with men. Sex Transm Infect. 2008;84(4):324-7. Exclusion: Wrong outcomes. [pmid: 18096648].
Donkers A, Levy HR, Letens-van Vliet A. Syphilis detection using the Siemens ADVIA Centaur syphilis treponemal assay. Clin Chim Acta. 2014;433:84-7. Exclusion: Wrong population. [pmid: 24513542].
Dorigo-Zetsma JW, Belewu D, Meless H, et al. Performance of routine syphilis serology in the Ethiopian cohort on HIV/AIDS. Sex Transm Infect. 2004;80(2):96-9. Exclusion: Population not applicable to U.S. population. [pmid: 15054167].
Enders M, Hunjet A, Gleich M, et al. Performance evaluation of the Elecsys syphilis assay for the detection of total antibodies to Treponema pallidum. Clin Vaccine Immunol. 2015;22(1):17-26. Exclusion: Wrong population. [pmid: 25355799].
Engelgau MM, Woernle CH, Rolfs RT, et al. Control of epidemic early syphilis: the results of an intervention campaign using social networks. Sex Transm Dis. 1995;22(4):203-9. Exclusion: Wrong intervention. [pmid: 7482101].
Fairley CK, Law M, Chen MY. Eradicating syphilis, hepatitis C and HIV in MSM through frequent testing strategies. Curr Opin Infect Dis. 2014;27(1):56-61. Exclusion: Review not meeting inclusion criteria. [pmid: 24275695].
Farhi D, Zizi N, Grange P, et al. The epidemiological and clinical presentation of syphilis in a venereal disease centre in Paris, France. A cohort study of 284 consecutive cases over the period 2000-2007. Eur J Dermatol. 2009;19(5):484-9. Exclusion: Wrong outcomes. [pmid: 19703802].
Farley TA, Cohen DA, Kahn RH, et al. The acceptability and behavioral effects of antibiotic prophylaxis for syphilis prevention. Sex Transm Dis. 2003;30(11):844-9. Exclusion: Wrong intervention. [pmid: 14603093].
Fernandes FR, Zanini PB, Rezende GR, et al. Syphilis infection, sexual practices and bisexual behaviour among men who have sex with men and transgender women: a cross-sectional study. Sex Transm Infect. 2015;91(2):142-9. Exclusion: Population not applicable to U.S. population. [pmid: 25301711].
Finelli L, Farley TP, Gibson JJ, et al. Prevalence monitoring in syphilis surveillance: results from a multicenter research program. Sex Transm Dis. 2002;29(12):769-74. Exclusion: Included for contextual questions only. [pmid: 12466718].
Fisher DG, Reynolds GL, Creekmur B, et al. Reliability and criterion-related validity of self-report of syphilis. Sex Transm Dis. 2007;34(6):389-91. Exclusion: Wrong outcomes. [pmid: 17108850].
Forbes KM, Davis P, Sarner L. Introduction of a nurse-led sexual health service for HIV-positive men. Int J STD AIDS. 2009;20(1):54-5. Exclusion: Wrong comparison. [pmid: 19103895].
Gayet-Ageron A, Lautenschlager S, Ninet B, et al. Sensitivity, specificity and likelihood ratios of PCR in the diagnosis of syphilis: a systematic review and meta-analysis. Sex Transm Infect. 2013;89(3):251-6. Exclusion: Wrong population. [pmid: 23024223].
Gayet-Ageron AS, Lautenschlager S, Ferry T, et al. Use of Treponema pallidum PCR in testing of ulcers for diagnosis of primary syphilis. Emerg Infect Dis. 2015;21(1):127-9. Exclusion: Wrong population. [pmid: 25531672].
Geusau A, Kittler H, Hein U, et al. Biological false-positive tests comprise a high proportion of Venereal Disease Research Laboratory reactions in an analysis of 300,000 sera. Int J STD AIDS. 2005;16(11):722-6. Exclusion: Wrong population. [pmid: 16303064].
Ghanem KG, Erbelding EJ, Wiener ZS, et al. Serological response to syphilis treatment in HIV-positive and HIV-negative patients attending sexually transmitted diseases clinics. Sex Transm Infect. 2007;83(2):97-101. Exclusion: Wrong population. [pmid: 16943224].
Ghanem KG, Moore RD, Rompalo AM, et al. Antiretroviral therapy is associated with reduced serologic failure rates for syphilis among HIV-infected patients. Clin Infect Dis. 2008;47(2):258-65. Exclusion: Wrong outcomes. [pmid: 18532887].
Ghanem KG, Moore RD, Rompalo AM, et al. Lumbar puncture in HIV-infected patients with syphilis and no neurologic symptoms. Clin Infect Dis. 2009;48(6):816-21. Exclusion: Wrong population. [pmid: 19187028].
Gianino MM, Dal Conte I, Sciole K, et al. Performance and costs of a rapid syphilis test in an urban population at high risk for sexually transmitted infections. J Prev Med Hyg. 2007;48(4):118-22. Exclusion: Wrong intervention. [pmid: 18557305].
Gift TL, Hogben M. Emergency department sexually transmitted disease and human immunodeficiency virus screening: findings from a national survey. Acad Emerg Med. 2006;13(9):993-6. Exclusion: Wrong outcomes. [pmid: 16894003].
Glatz M, Juricevic N, Altwegg M, et al. A multicenter prospective trial to asses a new real-time polymerase chain reaction for detection of Treponema pallidum, herpes simplex-1/2 and Haemophilus ducreyi in genital, anal and oropharyngeal ulcers. Clin Microbiol Infect. 2014;20(12):O1020-7. Exclusion: Wrong intervention. [pmid: 24909546].
Goel N, Sharma M, Gupta N, et al. Rapid immunochromatographic test for syphilis. Indian J Med Microbiol. 2005;23(2):142-3. Exclusion: Wrong population. [pmid: 15928451].
Goh BT. Syphilis in adults. Sex Transm Infect. 2005;81(6):448-52. Exclusion: Wrong publication type. [pmid: 16326843].
Gomez E, Jespersen DJ, Harring JA, et al. Evaluation of the Bio-Rad BioPlex 2200 syphilis multiplex flow immunoassay for the detection of IgM- and IgG-class antitreponemal antibodies. Clin Vaccine Immunol. 2010;17(6):966-8. Exclusion: Wrong population. [pmid: 20427627].
Goswami ND, Stout JE, Miller WC, et al. The footprint of old syphilis: using a reverse screening algorithm for syphilis testing in a U.S. Geographic Information Systems-Based Community Outreach Program. Sex Transm Dis. 2013;40(11):839-41. Exclusion: Wrong comparison. [pmid: 24113403].
Grange PA, Gressier L, Dion PL, et al. Evaluation of a PCR test for detection of Treponema pallidum in swabs and blood. J Clin Microbiol. 2012;50(3):546-52. Exclusion: Wrong population. [pmid: 22219306].
Gratrix J, Plitt S, Lee BE, et al. Impact of reverse sequence syphilis screening on new diagnoses of late latent syphilis in Edmonton, Canada. Sex Transm Dis. 2012;39(7):528-30. Exclusion: Wrong outcomes. [pmid: 22706214].
Gratzer B, Pohl D, Hotton AL. Evaluation of diagnostic serological results in cases of suspected primary syphilis infection. Sex Transm Dis. 2014;41(5):285-9. Exclusion: Wrong population. [pmid: 24722379].
Gray RT, Hoare A, Prestage GP, et al. Frequent testing of highly sexually active gay men is required to control syphilis. Sex Transm Dis. 2010;37(5):298-305. Exclusion: Wrong study design for Key Question. [pmid: 20393383].
Grewal R, Allen VG, Tan DH, et al. Enhanced syphilis screening among HIV-positive men: evaluation of a clinic-based intervention. Can J Infect Dis Med Microbiol. 2015;26(Suppl B):90B. Exclusion: Wrong population. [pmid: 26015791].
Guarner J, Jost H, Pillay A, et al. Evaluation of treponemal serum tests performed on cerebrospinal fluid for diagnosis of neurosyphilis. Am J Clin Pathol. 2015;143(4):479-84. Exclusion: Wrong population. [pmid: 25779998].
Guimaraes Nebenzahl H, Lopes A, Castro R, et al. Prevalence of human immunodeficiency virus, hepatitis C virus, hepatitis B virus and syphilis among individuals attending anonymous testing for HIV in Luanda, Angola. S Afr Med J. 2013;103(3):186-8. Exclusion: Population not applicable to U.S. population. [pmid: 23472697].
Guinard J, Prazuck T, Pere H, et al. Usefulness in clinical practice of a point-of-care rapid test for simultaneous detection of nontreponemal and Treponema pallidum-specific antibodies in patients suffering from documented syphilis. Int J STD AIDS. 2013;24(12):944-50. Exclusion: Wrong population. [pmid: 23999937].
Gupta SM, Bala M, Muralidhar S, et al. Evaluation of test results of microbiology laboratories of North India for standard tests for syphilis under an external quality assurance scheme. Eur J Clin Microbiol Infect Dis. 2009;28(5):461-8. Exclusion: Wrong population. [pmid: 19015902].
Gupte S, Daly C, Agarwal V, et al. Introduction of rapid tests for large-scale syphilis screening among female, male, and transgender sex workers in Mumbai, India. Sex Transm Dis. 2011;38(6):499-502. Exclusion: Wrong outcomes. [pmid: 21183861].
Guy R, El-Hayek C, Fairley CK, et al. Opt-out and opt-in testing increases syphilis screening of HIV-positive men who have sex with men in Australia. PLoS One. 2013;8(8):e71436. Exclusion: Wrong outcomes. [pmid: 24009661].
Guy R, Wand H, Holt M, et al. High annual syphilis testing rates among gay men in Australia, but insufficient retesting. Sex Transm Dis. 2012;39(4):268-75. Exclusion: Wrong outcomes. [pmid: 22421692].
Halling VW, Jones MF, Bestrom JE, et al. Clinical comparison of the Treponema pallidum CAPTIA syphilis-G enzyme immunoassay with the fluorescent treponemal antibody absorption immunoglobulin G assay for syphilis testing. J Clin Microbiol. 1999;37(10):3233-4. Exclusion: Wrong population. [pmid: 10488183].
Hammett TM. Sexually transmitted diseases and incarceration. Curr Opin Infect Dis. 2009;22(1):77-81. Exclusion: Review not meeting inclusion criteria. [pmid: 19532084].
Harding AS, Ghanem KG. The performance of cerebrospinal fluid treponemal-specific antibody tests in neurosyphilis: a systematic review. Sex Transm Dis. 2012;39(4):291-7. Exclusion: Review not meeting inclusion criteria. [pmid: 22421696].
Heffelfinger JD, Swint EB, Berman SM, et al. Trends in primary and secondary syphilis among men who have sex with men in the United States. Am J Public Health. 2007;97(6):1076-83. Exclusion: Wrong outcomes. [pmid: 17463387].
Heijman TL, Van der Bij AK, De Vries HJ, et al. Effectiveness of a risk-based visitor-prioritizing system at a sexually transmitted infection outpatient clinic. Sex Transm Dis. 2007;34(7):508-12. Exclusion: Wrong comparison. [pmid: 17179775].
Heiligenberg M, Rijnders B, Schim van der Loeff MF, et al. High prevalence of sexually transmitted infections in HIV-infected men during routine outpatient visits in the Netherlands. Sex Transm Dis. 2012;39(1):8-15. Exclusion: Wrong outcomes. [pmid: 22183837].
Heiligenberg M, van der Loeff MF, de Vries HJ, et al. Low prevalence of asymptomatic sexually transmitted infections in HIV-infected heterosexuals visiting an HIV clinic in the Netherlands. AIDS. 2012;26(5):646-9. Exclusion: Wrong outcomes. [pmid: 22210633].
Herremans M, Notermans DW, Mommers M, et al. Comparison of a Treponema pallidum IgM immunoblot with a 19S fluorescent treponemal antibody absorption test for the diagnosis of congenital syphilis. Diagn Microbiol Infect Dis. 2007;59(1):61-6. Exclusion: Wrong population. [pmid: 17662551].
Herring A, Ballard R, Mabey D, et al. Evaluation of rapid diagnostic tests: syphilis. Nat Rev Microbiol. 2006;4(12 Suppl):S33-40. Exclusion: Wrong publication type. [pmid: 17366685].
Heymans R, van der Helm JJ, de Vries HJ, et al. Clinical value of Treponema pallidum real-time PCR for diagnosis of syphilis. J Clin Microbiol. 2010;48(2):497-502. Exclusion: Wrong population. [pmid: 20007388].
Hladun O, Grau A, Esteban E, et al. Results from screening immigrants of low-income countries: data from a public primary health care. J Travel Med. 2014;21(2):92-8. Exclusion: Wrong outcomes. [pmid: 24571720].
Ho EL, Tantalo LC, Jones T, et al. Point-of-care treponemal tests for neurosyphilis diagnosis. Sex Transm Dis. 2015;42(1):48-52. Exclusion: Wrong intervention. [pmid: 25504301].
Hoang MP, High WA, Molberg KH. Secondary syphilis: a histologic and immunohistochemical evaluation. J Cutan Pathol. 2004;31(9):595-9. Exclusion: Wrong population. [pmid: 15330990].
Holman KM, Carr JA, Baddley JW, et al. Sexual history taking and sexually transmitted infection screening in patients initiating erectile dysfunction medication therapy. Sex Transm Dis. 2013;40(11):836-8. Exclusion: Wrong outcomes. [pmid: 24113402].
Hook EW 3rd, Behets F, Van Damme K, et al. A phase III equivalence trial of azithromycin versus benzathine penicillin for treatment of early syphilis. J Infect Dis. 2010;201(11):1729-35. Exclusion: Wrong outcomes. [pmid: 20402591].
Hoover KW, Butler M, Workowski K, et al. STD screening of HIV-infected MSM in HIV clinics. Sex Transm Dis. 2010;37(12):771-6. Exclusion: Included for contextual questions only. [pmid: 20585275].
Horberg MA, Ranatunga DK, Quesenberry CP, et al. Syphilis epidemiology and clinical outcomes in HIV-infected and HIV-uninfected patients in Kaiser Permanente Northern California. Sex Transm Dis. 2010;37(1):53-8. Exclusion: Included for contextual questions only. [pmid: 19734820].
Hotton AL, Gratzer B, Pohl D, et al. Factors associated with repeat syphilis testing at a large urban LGBT health clinic: Chicago, IL 2002-2008. Sex Transm Dis. 2011;38(3):205-9. Exclusion: Wrong outcomes. [pmid: 20871493].
Huang Q, Lan X, Tong T, et al. Dot-immunogold filtration assay as a screening test for syphilis. J Clin Microbiol. 1996;34(8):2011-3. Exclusion: Wrong population. [pmid: 8818901].
Huang YF, Nelson KE, Lin YT, et al. Syphilis among men who have sex with men (MSM) in Taiwan: its association with HIV prevalence, awareness of HIV status, and use of antiretroviral therapy. AIDS Behav. 2013;17(4):1406-14. Exclusion: Population not applicable to U.S. population. [pmid: 23297086].
Hussain T, Kulshreshtha KK, Sinha S, et al. HIV, HBV, HCV, and syphilis co-infections among patients attending the STD clinics of district hospitals in Northern India. Int J Infect Dis. 2006;10(5):358-63. Exclusion: Population not applicable to U.S. population. [pmid: 16678462].
Imrie J, Lambert N, Mercer CH, et al. Refocusing health promotion for syphilis prevention: results of a case-control study of men who have sex with men on England's south coast. Sex Transm Infect. 2006;82(1):80-3. Exclusion: Wrong outcomes. [pmid: 16461613].
Issa BA, Fadeyi A, Durotoye IA, et al. Sero-prevalence of syphilis among patients with mental illness: comparison with blood donors. West Afr J Med. 2013;32(3):210-5. Exclusion: Wrong population. [pmid: 24122688].
Ivens D, Patel M. Incidence and presentation of early syphilis diagnosed in HIV-positive gay men attending a central London outpatients' department. Int J STD AIDS. 2005;16(3):201-2. Exclusion: Wrong comparison. [pmid: 15829019].
Jafari Y, Peeling RW, Shivkumar S, et al. Are Treponema pallidum specific rapid and point-of-care tests for syphilis accurate enough for screening in resource limited settings? Evidence from a meta-analysis. PLoS One. 2013;8(2):e54695. Exclusion: Review not meeting inclusion criteria. [pmid: 23468842].
Javanbakht M, Murphy R, Harawa NT, et al. Sexually transmitted infections and HIV prevalence among incarcerated men who have sex with men, 2000-2005. Sex Transm Dis. 2009;36(2 Suppl):S17-21. Exclusion: Wrong outcomes. [pmid: 19125146].
Jayaraman GC, Read RR, Singh A. Characteristics of individuals with male-to-male and heterosexually acquired infectious syphilis during an outbreak in Calgary, Alberta, Canada. Sex Transm Dis. 2003;30(4):315-9. Exclusion: Wrong outcomes. [pmid: 12671551].
Jin F, Prestage GP, Kippax SC, et al. Epidemic syphilis among homosexually active men in Sydney. Med J Aust. 2005;183(4):179-83. Exclusion: Wrong outcomes. [pmid: 16097913].
Jin F, Prestage GP, Zablotska I, et al. High incidence of syphilis in HIV-positive homosexual men: data from two community-based cohort studies. Sex Health. 2009;6(4):281-4. Exclusion: Wrong outcomes. [pmid: 19917195].
Jin F, Prestage GP, Zablotska I, et al. High rates of sexually transmitted infections in HIV positive homosexual men: data from two community based cohorts. Sex Transm Infect. 2007;83(5):397-9. Exclusion: Wrong outcomes. [pmid: 17556503].
Johnson BK. Sexually transmitted infections and older adults. J Gerontol Nurs. 2013;39(11):53-60. Exclusion: Review not meeting inclusion criteria. [pmid: 24066789].
Jozkowski K, Rosenberger JG, Schick V, et al. Relations between circumcision status, sexually transmitted infection history, and HIV serostatus among a national sample of men who have sex with men in the United States. AIDS Patient Care STDS. 2010;24(8):465-70. Exclusion: Wrong study design for Key Question. [pmid: 20666578].
Jun L, He-Yi Z. Characteristics of patients with primary and late latent syphilis who were initially non-reactive to the rapid plasma reagin test. Jpn J Infect Dis. 2013;66(1):36-40. Exclusion: Population not applicable to U.S. population. [pmid: 23429083].
Kahle E, Zhang Q, Golden M, et al. Trends in evaluation for sexually transmitted infections among HIV-infected people, King County, Washington. Sex Transm Dis. 2007;34(12):940-6. Exclusion: Wrong comparison. [pmid: 18077843].
Kahn RH, Moseley KE, Thilges JN, et al. Community-based screening and treatment for STDs: results from a mobile clinic initiative. Sex Transm Dis. 2003;30(8):654-8. Exclusion: Wrong outcomes. [pmid: 12897689].
Kahn RH, Peterman TA, Arno J, et al. Identifying likely syphilis transmitters: implications for control and evaluation. Sex Transm Dis. 2006;33(10):630-5. Exclusion: Included for contextual questions only. [pmid: 16601660].
Kahn RH, Voigt RF, Swint E, et al. Early syphilis in the United States identified in corrections facilities, 1999-2002. Sex Transm Dis. 2004;31(6):360-4. Exclusion: Included for contextual questions only. [pmid: 15167646].
Katz KA, Lee MA, Gray T, et al. Repeat syphilis among men who have sex with men--San Diego County, 2004-2009. Sex Transm Dis. 2011;38(4):349-52. Exclusion: Wrong outcomes. [pmid: 21099734].
Katz KA, Raymond HF, Bernstein KT, et al. Knowledge, attitudes, and practices regarding syphilis screening among men who have sex with men in San Francisco. Sex Transm Dis. 2013;40(4):318-22. Exclusion: Wrong outcomes. [pmid: 23486497].
Katz LM. A test that won't die: the serologic test for syphilis. Transfusion. 2009;49(4):617-9. Exclusion: Wrong publication type. [pmid: 19335375].
Kay NS, Peeling RW, Mabey DC. State of the art syphilis diagnostics: rapid point-of-care tests. Expert Rev Anti Infect Ther. 2014;12(1):63-73. Exclusion: Wrong publication type. [pmid: 24308715].
Kazi AM, Shah SA, Jenkins CA, et al. Risk factors and prevalence of tuberculosis, human immunodeficiency virus, syphilis, hepatitis B virus, and hepatitis C virus among prisoners in Pakistan. Int J Infect Dis. 2010;14(Suppl 3):e60-6. Exclusion: Population not applicable to U.S. population. [pmid: 20189863].
Keiser O, Martinez de Tejada B, Wunder D, et al. Frequency of gynecologic follow-up and cervical cancer screening in the Swiss HIV cohort study. J Acquir Immune Defic Syndr. 2006;43(5):550-5. Exclusion: Wrong outcomes. [pmid: 17133212].
Kerani RP, Handsfield HH, Stenger MS, et al. Rising rates of syphilis in the era of syphilis elimination. Sex Transm Dis. 2007;34(3):154-61. Exclusion: Wrong outcomes. [pmid: 17179773].
Kim J, Kim WH, Cho C, et al. Evaluation of automated architect syphilis TP as a diagnostic laboratory screening test for syphilis. Korean J Lab Med. 2008;28(6):475-82. Exclusion: Wrong population. [pmid: 19127113].
Kim YJ, Cho SY, Kim MJ, et al. Investigation of concordance in two automated rapid plasma reagin assays and conventional manual card method. Clin Lab. 2015;61(7):861-3. Exclusion: Wrong publication type. [pmid: 26299090].
Kim YS, Lee J, Lee HK, et al. Comparison of quantitative results among two automated rapid plasma reagin (RPR) assays and a manual RPR test. Korean J Lab Med. 2009;29(4):331-7. Exclusion: Wrong population. [pmid: 19726896].
Kitahata MM, Dillingham PW, Chaiyakunapruk N, et al. Electronic human immunodeficiency virus (HIV) clinical reminder system improves adherence to practice guidelines among the University of Washington HIV Study Cohort. Clin Infect Dis. 2003;36(6):803-11. Exclusion: Wrong outcomes. [pmid: 12627367].
Kizito D, Woodburn PW, Kesande B, et al. Uptake of HIV and syphilis testing of pregnant women and their male partners in a programme for prevention of mother-to-child HIV transmission in Uganda. Trop Med Int Health. 2008;13(5):680-2. Exclusion: Wrong population. [pmid: 18331533].
Klausner JD. Frequency of syphilis testing in HIV-infected patients: more and more often. Sex Transm Dis. 2009;36(2):86-7. Exclusion: Wrong publication type. [pmid: 19098689].
Klausner JD, Kent CK, Wong W, et al. The public health response to epidemic syphilis, San Francisco, 1999-2004. Sex Transm Dis. 2005;32(10 Suppl):S11-8. Exclusion: Wrong study design for Key Question. [pmid: 16205286].
Knight CS, Crum MA, Hardy RW. Evaluation of the LIAISON chemiluminescence immunoassay for diagnosis of syphilis. Clin Vaccine Immunol. 2007;14(6):710-3. Exclusion: Wrong population. [pmid: 17460119].
Ko NY, Liu HY, Lee HC, et al. One-year follow-up of relapse to risky behaviors and incidence of syphilis among patients enrolled in the HIV case management program. AIDS Behav. 2011;15(5):1067-74. Exclusion: Population not applicable to U.S. population. [pmid: 20976537].
Koek AG, Bruisten SM, Dierdorp M, et al. Specific and sensitive diagnosis of syphilis using a real-time PCR for Treponema pallidum. Clin Microbiol Infect. 2006;12(12):1233-6. Exclusion: Wrong population. [pmid: 17121633].
Koekenbier RH, Davidovich U, van Leent EJ, et al. Online-mediated syphilis testing: feasibility, efficacy, and usage. Sex Transm Dis. 2008;35(8):764-9. Exclusion: Wrong outcomes. [pmid: 18496472].
Kotnik V, Jordan K, Stopinsek S, et al. Intrathecal antitreponemal antibody synthesis determination using the INNO-LIA syphilis score. Acta Dermatovenerol Alp Pannonica Adriat. 2007;16(4):135-41. Exclusion: Wrong outcomes. [pmid: 18204743].
Kourbatova EV, Akovbyan VA, Chesson HW, et al. Assessment of the routine, occupation-based gonorrhea and syphilis screening program in Moscow, Russia: an analysis of sexually transmitted infection prevalence and cost-effectiveness. Sex Transm Dis. 2008;35(5):453-60. Exclusion: Wrong outcomes. [pmid: 18434940].
Kudo T, Kido A, Nishiyama Y, et al. Whole-blood counting immunoassay as a short-turnaround test for detection of hepatitis B surface antigen, anti-hepatitis C virus antibodies, and anti-Treponema pallidum antibodies. J Clin Microbiol. 2004;42(9):4250-2. Exclusion: Wrong outcomes. [pmid: 15365019].
Kunkel J, Schurmann D, Pleyer U, et al. Ocular syphilis--indicator of previously unknown HIV-infection. J Infect. 2009;58(1):32-6. Exclusion: Wrong population. [pmid: 19081634].
Lam TK, Lau HY, Lee YP, et al. Comparative evaluation of the INNO-LIA syphilis score and the MarDx Treponema pallidum immunoglobulin G Marblot test assays for the serological diagnosis of syphilis. Int J STD AIDS. 2010;21(2):110-3. Exclusion: Wrong population. [pmid: 20089996].
Lam TK, Lau HY, Lee YP, et al. Use of the INNO-LIA syphilis score assay in the resolution of discordant positive screening enzyme immunoassay results for the serological diagnosis of syphilis. Int J STD AIDS. 2014;25(1):52-6. Exclusion: Wrong intervention. [pmid: 23970631].
Lambert NL, Fisher M, Imrie J, et al. Community based syphilis screening: feasibility, acceptability, and effectiveness in case finding. Sex Transm Infect. 2005;81(3):213-6. Exclusion: Wrong outcomes. [pmid: 15923287].
Lee JH, Lim CS, Lee MG, et al. Comparison of an automated rapid plasma reagin (RPR) test with the conventional RPR card test in syphilis testing. BMJ Open. 2014;4(12):e005664. Exclusion: Wrong publication type.
Lee K, Park H, Roh EY, et al. Characterization of sera with discordant results from reverse sequence screening for syphilis. Biomed Res Int. 2013;2013:269347. Exclusion: Wrong population. [pmid: 23509699].
Leslie DE, Azzato F, Karapanagiotidis T, et al. Development of a real-time PCR assay to detect Treponema pallidum in clinical specimens and assessment of the assay's performance by comparison with serological testing. J Clin Microbiol. 2007;45(1):93-6. Exclusion: Wrong population. [pmid: 17065262].
Leuridan E, Wouters K, Stalpaert M, et al. Male sex workers in Antwerp, Belgium: a descriptive study. Int J STD AIDS. 2005;16(11):744-8. Exclusion: Population not applicable to U.S. population. [pmid: 16303070].
Lewis FM, Schillinger JA, Taylor M, et al. Needle in a haystack: the yield of syphilis outreach screening at 5 US sites--2000 to 2007. J Public Health Manag Pract. 2011;17(6):513-21. Exclusion: Wrong outcomes. [pmid: 21964362].
Li D, Jia Y, Ruan Y, et al. Correlates of incident infections for HIV, syphilis, and hepatitis B virus in a cohort of men who have sex with men in Beijing. AIDS Patient Care STDS. 2010;24(9):595-602. Exclusion: Population not applicable to U.S. population. [pmid: 20731610].
Li J, Chen XS, Merli MG, et al. Systematic differences in risk behaviors and syphilis prevalence across types of female sex workers: a preliminary study in Liuzhou, China. Sex Transm Dis. 2012;39(3):195-200. Exclusion: Population not applicable to U.S. population. [pmid: 22337106].
Li J, Zheng HY, Wang LN, et al. Clinical evaluation of four recombinant Treponema pallidum antigen-based rapid diagnostic tests for syphilis. J Eur Acad Dermatol Venereol. 2009;23(6):648-50. Exclusion: Wrong population. [pmid: 19470078].
Lim RB, Tan MT, Young B, et al. Risk factors and time-trends of cytomegalovirus (CMV), syphilis, toxoplasmosis and viral hepatitis infection and seroprevalence in human immunodeficiency virus (HIV) infected patients. Ann Acad Med Singapore. 2013;42(12):667-73. Exclusion: Population not applicable to U.S. population. [pmid: 24463828].
Lin LR, Fu ZG, Dan B, et al. Development of a colloidal gold-immunochromatography assay to detect immunoglobulin G antibodies to Treponema pallidum with TPN17 and TPN47. Diagn Microbiol Infect Dis. 2010;68(3):193-200. Exclusion: Wrong population. [pmid: 20846810].
Lin LR, Tong ML, Fu ZG, et al. Evaluation of a colloidal gold immunochromatography assay in the detection of Treponema pallidum specific IgM antibody in syphilis serofast reaction patients: a serologic marker for the relapse and infection of syphilis. Diagn Microbiol Infect Dis. 2011;70(1):10-6. Exclusion: Wrong population. [pmid: 21388769].
Lipinsky D, Schreiber L, Kopel V, et al. Validation of reverse sequence screening for syphilis. J Clin Microbiol. 2012;50(4):1501. Exclusion: Wrong publication type. [pmid: 22259212].
Liu C, Ou Q, Chen H, et al. The diagnostic value and performance evaluation of five serological tests for the detection of Treponema pallidum. J Clin Lab Anal. 2014;28(3):204-9. Exclusion: Wrong comparison. [pmid: 24478062].
Liu F, Liu LL, Guo XJ, et al. Characterization of the classical biological false-positive reaction in the serological test for syphilis in the modern era. Int Immunopharmacol. 2014;20(2):331-6. Exclusion: Wrong outcomes. [pmid: 24690532].
Liu LL, Zheng WH, Tong ML, et al. Ischemic stroke as a primary symptom of neurosyphilis among HIV-negative emergency patients. J Neurol Sci. 2012;317(1-2):35-9. Exclusion: Wrong population. [pmid: 22482824].
Ljubojevic S, Lipozencic J. Sexually transmitted infections and adolescence. Acta Dermatovenerol Croat. 2010;18(4):305-10. Exclusion: Review not meeting inclusion criteria. [pmid: 21251451].
Loeffelholz MJ, Binnicker MJ. It is time to use treponema-specific antibody screening tests for diagnosis of syphilis. J Clin Microbiol. 2012;50(1):2-6. Exclusion: Wrong publication type. [pmid: 22090405].
Loeffelholz MJ, Wen T, Patel JA. Analysis of BioPlex syphilis IgG quantitative results in different patient populations. Clin Vaccine Immunol. 2011;18(11):2005-6. Exclusion: Wrong population. [pmid: 21880852].
Long CM, Klausner JD, Leon S, et al. Syphilis treatment and HIV infection in a population-based study of persons at high risk for sexually transmitted disease/HIV infection in Lima, Peru. Sex Transm Dis. 2006;33(3):151-5. Exclusion: Wrong outcomes. [pmid: 16508525].
Lukehart SA, Godornes C, Molini BJ, et al. Macrolide resistance in Treponema pallidum in the United States and Ireland. N Engl J Med. 2004;351(2):154-8. Exclusion: Wrong outcomes. [pmid: 15247355].
Lynn WA, Lightman S. Syphilis and HIV: a dangerous combination. Lancet Infect Dis. 2004;4(7):456-66. Exclusion: Wrong publication type. [pmid: 15219556].
Mabey D, Peeling RW, Ballard R, et al. Prospective, multi-centre clinic-based evaluation of four rapid diagnostic tests for syphilis. Sex Transm Infect. 2006;82(Suppl 5):v13-6. Exclusion: Wrong population. [pmid: 17215274].
Macnow T, Hum RS, Soren K. Screening for syphilis in adolescents: how useful is it?. Clin Pediatr (Phila). 2014;53(8):800-3. Exclusion: Wrong population. [pmid: 23872347].
MacPherson DW, Gushulak BD. Syphilis in immigrants and the Canadian immigration medical examination. J Immigr Minor Health. 2008;10(1):1-6. Exclusion: Wrong study design for Key Question. [pmid: 17562180].
Manavi K, Bhaduri S, Tariq A, et al. Audit on the success of partner notification for sexually transmitted infections in the West Midlands. Int J STD AIDS. 2008;19(12):856-8. Exclusion: Wrong intervention. [pmid: 19050219].
Manavi K, Luo PL, McMillan A. The three-year positivity rate of sexually transmitted infections among a group of HIV-infected men attending the Department of Genitourinary Medicine, Edinburgh, UK. Int J STD AIDS. 2005;16(11):730-2. Exclusion: Wrong outcomes. [pmid: 16303066].
Manavi K, Williams G, Newton R. The uptake of HIV and syphilis testing in a nurse-delivered service during Gay Pride events. Int J STD AIDS. 2012;23(12):887-9. Exclusion: Wrong outcomes. [pmid: 23258830].
Manavi K, Young H, McMillan A. The sensitivity of syphilis assays in detecting different stages of early syphilis. Int J STD AIDS. 2006;17(11):768-71. Exclusion: Wrong study design for Key Question. [pmid: 17062183].
Manzardo C, Trevino B, Gomez i Prat J, et al. Communicable diseases in the immigrant population attended to in a tropical medicine unit: epidemiological aspects and public health issues. Travel Med Infect Dis. 2008;6(1-2):4-11. Exclusion: Wrong outcomes. [pmid: 18342267].
Maple PA, Simms I, Kafatos G, et al. Application of a noninvasive oral fluid test for detection of treponemal IgG in a predominantly HIV-infected population. Eur J Clin Microbiol Infect Dis. 2006;25(12):743-9. Exclusion: Wrong intervention. [pmid: 17061098].
Marangoni A, Moroni A, Accardo S, et al. Laboratory diagnosis of syphilis with automated immunoassays. J Clin Lab Anal. 2009;23(1):1-6. Exclusion: Wrong population. [pmid: 19140205].
Marangoni A, Nardini P, Foschi C, et al. Evaluation of the BioPlex 2200 syphilis system as a first-line method of reverse-sequence screening for syphilis diagnosis. Clin Vaccine Immunol. 2013;20(7):1084-8. Exclusion: Wrong population. [pmid: 23697575].
Marangoni A, Sambri V, Accardo S, et al. Evaluation of LIAISON Treponema Screen, a novel recombinant antigen-based chemiluminescence immunoassay for laboratory diagnosis of syphilis. Clin Diagn Lab Immunol. 2005;12(10):1231-4. Exclusion: Wrong population. [pmid: 16210488].
Marcus JL, Katz KA, Bernstein KT, et al. Syphilis testing behavior following diagnosis with early syphilis among men who have sex with men--San Francisco, 2005-2008. Sex Transm Dis. 2011;38(1):24-9. Exclusion: Wrong outcomes. [pmid: 20679965].
Marcus U, Bremer V, Hamouda O. Syphilis surveillance and trends of the syphilis epidemic in Germany since the mid-90s. Euro Surveill. 2004;9(12):11-4. Exclusion: Wrong publication type. [pmid: 15677854].
Marques NM, Margalho R, Melo MJ, et al. Seroepidemiological survey of transmissible infectious diseases in a Portuguese prison establishment. Braz J Infect Dis. 2011;15(3):272-5. Exclusion: Wrong outcomes. [pmid: 21670930].
Marra CM, Tantalo LC, Maxwell CL, et al. Alternative cerebrospinal fluid tests to diagnose neurosyphilis in HIV-infected individuals. Neurology. 2004;63(1):85-8. Exclusion: Wrong population. [pmid: 15249615].
Marra CM, Tantalo LC, Maxwell CL, et al. The rapid plasma reagin test cannot replace the Venereal Disease Research Laboratory test for neurosyphilis diagnosis. Sex Transm Dis. 2012;39(6):453-7. Exclusion: Wrong population. [pmid: 22592831].
Marrazzo J. Sexually transmitted diseases in the HIV care setting: what's really going on down there?. Top HIV Med. 2004;12(2):57-60. Exclusion: Wrong publication type. [pmid: 15184712].
Martin IE, Lau A, Sawatzky P, et al. Serological diagnosis of syphilis: enzyme-linked immunosorbent assay to measure antibodies to individual recombinant Treponema pallidum antigens. J Immunoassay Immunochem. 2008;29(2):143-51. Exclusion: Wrong population. [pmid: 18360809].
Martin JA, Mak DB. Changing faces: a review of infectious disease screening of refugees by the Migrant Health Unit, Western Australia in 2003 and 2004. Med J Aust. 2006;185(11-12):607-10. Exclusion: Wrong outcomes. [pmid: 17181502].
Matteelli A, Schlagenhauf P, Carvalho AC, et al. Travel-associated sexually transmitted infections: an observational cross-sectional study of the GeoSentinel surveillance database. Lancet Infect Dis. 2013;13(3):205-13. Exclusion: Wrong outcomes. [pmid: 23182931].
Mattei PL, Beachkofsky TM, Gilson RT, et al. Syphilis: a reemerging infection. Am Fam Physician. 2012;86(5):433-40. Exclusion: Wrong publication type. [pmid: 22963062].
Mayer KH. Sexually transmitted diseases in men who have sex with men. Clin Infect Dis. 2011;53(Suppl 3):S79-83. Exclusion: Review not meeting inclusion criteria. [pmid: 22080272].
Mayer KH, Bush T, Henry K, et al. Ongoing sexually transmitted disease acquisition and risk-taking behavior among US HIV-infected patients in primary care: implications for prevention interventions. Sex Transm Dis. 2012;39(1):1-7. Exclusion: Included for contextual questions only. [pmid: 22183836].
Mayer KH, Ducharme R, Zaller ND, et al. Unprotected sex, underestimated risk, undiagnosed HIV and sexually transmitted diseases among men who have sex with men accessing testing services in a New England bathhouse. J Acquir Immune Defic Syndr. 2012;59(2):194-8. Exclusion: Wrong outcomes. [pmid: 22027871].
Mayer KH, Wang L, Koblin B, et al. Concomitant socioeconomic, behavioral, and biological factors associated with the disproportionate HIV infection burden among black men who have sex with men in 6 U.S. cities. PLoS One. 2014;9(1):e87298. Exclusion: Included for contextual questions only. [pmid: 24498067].
McLean CA, Kohl K, Baker MA, et al. The syphilis reactor grid: help or hindrance for syphilis surveillance?. Sex Transm Dis. 2003;30(8):650-3. Exclusion: Wrong outcomes. [pmid: 12897688].
McMillan A, Young H. Qualitative and quantitative aspects of the serological diagnosis of early syphilis. Int J STD AIDS. 2008;19(9):620-4. Exclusion: Wrong population. [pmid: 18725554].
Medhi GK, Mahanta J, Kermode M, et al. Factors associated with history of drug use among female sex workers (FSW) in a high HIV prevalence state of India. BMC Public Health. 2012;12:273. Exclusion: Wrong outcomes. [pmid: 22480208].
Mejia A, Bautista CT, Leal L, et al. Syphilis infection among female sex workers in Colombia. J Immigr Minor Health. 2009;11(2):92-8. Exclusion: Wrong outcomes. [pmid: 17934887].
Miller M, Liao Y, Wagner M, et al. HIV, the clustering of sexually transmitted infections, and sex risk among African American women who use drugs. Sex Transm Dis. 2008;35(7):696-702. Exclusion: Wrong outcomes. [pmid: 18418289].
Mimiaga MJ, Helms DJ, Reisner SL, et al. Gonococcal, chlamydia, and syphilis infection positivity among MSM attending a large primary care clinic, Boston, 2003 to 2004. Sex Transm Dis. 2009;36(8):507-11. Exclusion: Wrong outcomes. [pmid: 19455081].
Mimiaga MJ, Reisner SL, Vanderwarker R, et al. Polysubstance use and HIV/STD risk behavior among Massachusetts men who have sex with men accessing Department of Public Health mobile van services: implications for intervention development. AIDS Patient Care STDS. 2008;22(9):745-51. Exclusion: Wrong outcomes. [pmid: 18754704].
Miranda AE, Figueiredo NC, Pinto VM, et al. Risk factors for syphilis in young women attending a family health program in Vitoria, Brazil. An Bras Dermatol. 2012;87(1):76-83. Exclusion: Population not applicable to U.S. population. [pmid: 22481654].
Mishra S, Naik B, Venugopal B, et al. Syphilis screening among female sex workers in Bangalore, India: comparison of point-of-care testing and traditional serological approaches. Sex Transm Infect. 2010;86(3):193-8. Exclusion: Wrong intervention. [pmid: 19965800].
Mitchell SJ, Engelman J, Kent CK, et al. Azithromycin-resistant syphilis infection: San Francisco, California, 2000-2004. Clin Infect Dis. 2006;42(3):337-45. Exclusion: Wrong outcomes. [pmid: 16392078].
Mo X, Jin Y, Yang Y, et al. Evaluation of a new chemiluminescence immunoassay for diagnosis of syphilis. Eur J Med Res. 2010;15(2):66-9. Exclusion: Wrong population. [pmid: 20452886].
Moore MB Jr, Price EV, Knox JM, et al. Epidemiologic treatment of contacts to infectious syphilis. Public health reports. (Washington, DC: 1974). 1963;78:966-70. Exclusion: Wrong publication type. [pmid: 14084872].
Morshed MG. Current trend on syphilis diagnosis: issues and challenges. Adv Exp Med Biol. 2014;808:51-64. Exclusion: Wrong publication type. [pmid: 24595610].
Muller H, Eisendle K, Brauninger W, et al. Comparative analysis of immunohistochemistry, polymerase chain reaction and focus-floating microscopy for the detection of Treponema pallidum in mucocutaneous lesions of primary, secondary and tertiary syphilis. Br J Dermatol. 2011;165(1):50-60. Exclusion: Wrong population. [pmid: 21410678].
Muller I, Brade V, Hagedorn HJ, et al. Is serological testing a reliable tool in laboratory diagnosis of syphilis? Meta-analysis of eight external quality control surveys performed by the German infection serology proficiency testing program. J Clin Microbiol. 2006;44(4):1335-41. Exclusion: Wrong intervention. [pmid: 16597859].
Mullick S, Broutet N, Htun Y, et al. Controlling congenital syphilis in the era of HIV/AIDS. Bull World Health Organ. 2004;82(6):431-2. Exclusion: Wrong publication type. [pmid: 15356935].
Munday PE, Allan A, Hearne S, et al. The role of the nurse in screening asymptomatic male and female patients in a sexual health clinic. Int J STD AIDS. 2005;16(4):281-3. Exclusion: Wrong outcomes. [pmid: 15899078].
Mustikawati DE, Morineau G, Nurhayati, et al. Sexual risk taking, sexually transmitted infections and HIV prevalence among four “high-risk” occupational groups of Indonesian men. Sex Transm Infect. 2009;85(5):391-6. Exclusion: Population not applicable to U.S. population. [pmid: 19273478].
Muzny CA, Sunesara IR, Martin DH, et al. Sexually transmitted infections and risk behaviors among African American women who have sex with women: does sex with men make a difference?. Sex Transm Dis. 2011;38(12):1118-25. Exclusion: Wrong outcomes. [pmid: 22082722].
Naaber P, Makoid E, Aus A, et al. Evaluation of ID-PaGIA syphilis antibody test. Indian J Dermatol Venereol Leprol. 2009;75(5):492-4. Exclusion: Wrong population. [pmid: 19736429].
Nessa K, Alam A, Chawdhury FA, et al. Field evaluation of simple rapid tests in the diagnosis of syphilis. Int J STD AIDS. 2008;19(5):316-20. Exclusion: Population not applicable to U.S. population. [pmid: 18482961].
Nessa K, Waris SA, Alam A, et al. Sexually transmitted infections among brothel-based sex workers in Bangladesh: high prevalence of asymptomatic infection. Sex Transm Dis. 2005;32(1):13-9. Exclusion: Wrong outcomes. [pmid: 15614116].
Noh J, Ko HH, Yun Y, et al. Evaluation of performance and false positivity of Mediace RPR test that uses a chemistry autoanalyzer. Korean J Lab Med. 2008;28(4):312-8. Exclusion: Wrong population. [pmid: 18728382].
Nyamwamu LB, Gicheru MM, Sharma RR, et al. Evaluation of the immunochromatographic strip test for the rapid diagnosis of antenatal syphilis in women in Eldoret, Kenya. J Nanjing Med Univ. 2009;23(5):317-21. Exclusion: Wrong population.
O'Connor EA, Lin JS, Burda BU, et al. Behavioral sexual risk-reduction counseling in primary care to prevent sexually transmitted infections: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2014;161(12):874-83. Exclusion: Wrong outcomes. [pmid: 25243895].
Ortega KL, Rezende NP, Magalhaes MH. Diagnosing secondary syphilis in a patient with HIV. Br J Oral Maxillofac Surg. 2009;47(2):169-70. Exclusion: Wrong study design for Key Question. [pmid: 18801603].
Owusu-Edusei K Jr, Koski KA, Ballard RC. The tale of two serologic tests to screen for syphilis--treponemal and nontreponemal: does the order matter?. Sex Transm Dis. 2011;38(5):448-56. Exclusion: Wrong study design for Key Question. [pmid: 21183862].
Owusu-Edusei K Jr, Peterman TA, Ballard RC. Serologic testing for syphilis in the United States: a cost-effectiveness analysis of two screening algorithms. Sex Transm Dis. 2011;38(1):1-7. Exclusion: Wrong outcomes. [pmid: 20739911].
Oxman GL, Doyle L. A comparison of the case-finding effectiveness and average costs of screening and partner notification. Sex Transm Dis. 1996;23(1):51-7. Exclusion: Wrong outcomes. [pmid: 8801644].
Palmer HM, Higgins SP, Herring AJ, et al. Use of PCR in the diagnosis of early syphilis in the United Kingdom. Sex Transm Infect. 2003;79(6):479-83. Exclusion: Wrong population. [pmid: 14663125].
Park IU, Chow JM, Bolan G, et al. Screening for syphilis with the treponemal immunoassay: analysis of discordant serology results and implications for clinical management. J Infect Dis. 2011;204(9):1297-304. Exclusion: Wrong comparison. [pmid: 21930610].
Park Y, Park Y, Joo SY, et al. Evaluation of a fully automated treponemal test and comparison with conventional VDRL and FTA-ABS tests. Am J Clin Pathol. 2011;136(5):705-10. Exclusion: Wrong population. [pmid: 22031308].
Parthasarathy MR, Narayanan P, Das A, et al. Integrating syphilis screening in a large-scale HIV prevention program for key populations: the Avahan experience from India. J Infect Dev Ctries. 2013;7(6):484-8. Exclusion: Wrong outcomes. [pmid: 23771292].
Pathela P, Braunstein SL, Schillinger JA, et al. Men who have sex with men have a 140-fold higher risk for newly diagnosed HIV and syphilis compared with heterosexual men in New York City. J Acquir Immune Defic Syndr. 2011;58(4):408-16. Exclusion: Wrong outcomes. [pmid: 21857351].
Patterson D, Vilensky JA, Robertson WM, et al. Treatment and diagnostic accuracy of neurosyphilis at Boston City Hospital's Neurological Unit, 1930-1979. J Neurol Sci. 2012;314(1-2):1-4. Exclusion: Wrong outcomes. [pmid: 22129939].
Paz-Bailey G, Teran S, Levine W, et al. Syphilis outbreak among Hispanic immigrants in Decatur, Alabama: association with commercial sex. Sex Transm Dis. 2004;31(1):20-5. Exclusion: Wrong outcomes. [pmid: 14695954].
Peate I. Syphilis: clinical presentation, diagnosis and treatment. Nurs Stand. 2007;22(10):48-55. Exclusion: Wrong publication type. [pmid: 18069500].
Peeling RW, Mabey DC. Syphilis. Nat Rev Microbiol. 2004;2(6):448-9. Exclusion: Wrong publication type. [pmid: 15181902].
Perry M, Iveson H, White J. Assessment of the performance of a rapid point of care syphilis test in a London genitourinary medicine clinic. Int J STD AIDS. 2014;25(13):967-8. Exclusion: Wrong publication type. [pmid: 25318854].
Person AK, Blain ML, Jiang H, et al. Text messaging for enhancement of testing and treatment for tuberculosis, human immunodeficiency virus, and syphilis: a survey of attitudes toward cellular phones and healthcare. Telemed J E Health. 2011;17(3):189-95. Exclusion: Wrong outcomes. [pmid: 21457085].
Peterman TA, Furness BW. The resurgence of syphilis among men who have sex with men. Curr Opin Infect Dis. 2007;20(1):54-9. Exclusion: Review not meeting inclusion criteria. [pmid: 17197882].
Peterman TA, Heffelfinger JD, Swint EB, et al. The changing epidemiology of syphilis. Sex Transm Dis. 2005;32(10 Suppl):S4-10. Exclusion: Review not meeting inclusion criteria. [pmid: 16205291].
Peterman TA, Su J, Bernstein KT, et al. Syphilis in the United States: on the rise?. Expert Rev Anti Infect Ther. 2015;13(2):161-8. Exclusion: Wrong publication type. [pmid: 25487961].
Phipps W, Kent CK, Kohn R, et al. Risk factors for repeat syphilis in men who have sex with men, San Francisco. Sex Transm Dis. 2009;36(6):331-5. Exclusion: Wrong outcomes. [pmid: 19556925].
Phipps W, Stanley H, Kohn R, et al. Syphilis, chlamydia, and gonorrhea screening in HIV-infected patients in primary care, San Francisco, California, 2003. AIDS Patient Care STDS. 2005;19(8):495-8. Exclusion: Wrong outcomes. [pmid: 16124843].
American Academy of Family Physicians. Syphilis. http://www.aafp.org/patient-care/clinical-recommendations/all/syphilis.html. June 22, 2015. Exclusion: custom 7.
Pintye J, Baeten JM, Manhart LE, et al. Association between male circumcision and incidence of syphilis in men and women: a prospective study in HIV-1 serodiscordant heterosexual African couples. Lancet Glob Health. 2014;2(11):e664-e71. Exclusion: Population not applicable to U.S. population. [pmid: 25442691].
Pittrof R, McLellan J. Test Not Talk screening for asymptomatic men. Int J STD AIDS. 2007;18(4):274-5. Exclusion: Wrong study design for Key Question. [pmid: 17509179].
Plant A, Javanbakht M, Montoya JA, et al. Check Yourself: a social marketing campaign to increase syphilis screening in Los Angeles County. Sex Transm Dis. 2014;41(1):50-7. Exclusion: Wrong outcomes. [pmid: 24326583].
Platt L, Rhodes T, Judd A, et al. Effects of sex work on the prevalence of syphilis among injection drug users in 3 Russian cities. Am J Public Health. 2007;97(3):478-85. Exclusion: Population not applicable to U.S. population. [pmid: 17018827].
Platteau T, Wouters K, Apers L, et al. Voluntary outreach counselling and testing for HIV and STI among men who have sex with men in Antwerp. Acta Clin Belg. 2012;67(3):172-6. Exclusion: Wrong outcomes. [pmid: 22897064].
Pope V. Use of treponemal tests to screen for syphilis. Infect Med. 2004;21(8):399-402. Exclusion: Wrong publication type.
Qin JB, Feng TJ, Yang TB, et al. Maternal and paternal factors associated with congenital syphilis in Shenzhen, China: a prospective cohort study. Eur J Clin Microbiol Infect Dis. 2014;33(2):221-32. Exclusion: Wrong outcomes. [pmid: 23948753].
Quaglio G, Lugoboni F, Pattaro C, et al. Patients in long-term maintenance therapy for drug use in Italy: analysis of some parameters of social integration and serological status for infectious diseases in a cohort of 1091 patients. BMC Public Health. 2006;6:216. Exclusion: Wrong outcomes. [pmid: 16928267].
Qyra ST, Basho M, Bani R, et al. Behavioral risk factors and prevalence of HIV and other STIs among female sex workers in Tirana, Albania. New Microbiol. 2011;34(1):105-8. Exclusion: Population not applicable to U.S. population. [pmid: 21344155].
Rajapure V, Tirwa R, Poudyal H, et al. Prevalence and risk factors associated with sexually transmitted diseases (STDs) in Sikkim. J Community Health. 2013;38(1):156-62. Exclusion: Population not applicable to U.S. population. [pmid: 22811073].
Rajaram SP, Banandur P, Thammattoor UK, et al. Two cross-sectional studies in south India assessing the effect of an HIV prevention programme for female sex workers on reducing syphilis among their clients. Sex Transm Infect. 2014;90(7):556-62. Exclusion: Wrong outcomes. [pmid: 24812406].
Ratnam S. The laboratory diagnosis of syphilis. Can J Infect Dis Med Microbiol. 2005;16(1):45-51. Exclusion: Wrong publication type. [pmid: 18159528].
Reynolds GL, Fisher DG, Napper LE, et al. Results from a multiple morbidities testing program offering rapid HIV testing bundled with hepatitis and sexually transmitted infection testing. Public Health Rep. 2008;123(Suppl 3):63-9. Exclusion: Wrong outcomes. [pmid: 19166090].
Reynolds SJ, Shepherd ME, Risbud AR, et al. Male circumcision and risk of HIV-1 and other sexually transmitted infections in India. Lancet. 2004;363(9414):1039-40. Exclusion: Population not applicable to U.S. population. [pmid: 15051285].
Reynolds SL, Kapadia AS, Leonard L, et al. Examining the direct costs and effectiveness of syphilis detection by selective screening and partner notification. J Public Health Med. 2001;23(4):339-45. Exclusion: Wrong outcomes. [pmid: 11873899].
Ribeiro D, Rezende EF, Pinto VM, et al. Prevalence of and risk factors for syphilis in Brazilian armed forces conscripts. Sex Transm Infect. 2012;88(1):32-4. Exclusion: Population not applicable to U.S. population. [pmid: 22037855].
Riedner G, Hoffmann O, Rusizoka M, et al. Decline in sexually transmitted infection prevalence and HIV incidence in female barworkers attending prevention and care services in Mbeya Region, Tanzania. AIDS. 2006;20(4):609-15. Exclusion: Wrong outcomes. [pmid: 16470126].
Rieg G, Lewis RJ, Miller LG, et al. Asymptomatic sexually transmitted infections in HIV-infected men who have sex with men: prevalence, incidence, predictors, and screening strategies. AIDS Patient Care STDS. 2008;22(12):947-54. Exclusion: Wrong comparison. [pmid: 19072101].
Righarts AA, Simms I, Wallace L, et al. Syphilis surveillance and epidemiology in the United Kingdom. Euro Surveill. 2004;9(12):21-5. Exclusion: Wrong study design for Key Question. [pmid: 15677851].
Rogstad KE, Simms I, Fenton KA, et al. Screening, diagnosis and management of early syphilis in genitourinary medicine clinics in the UK. Int J STD AIDS. 2005;16(5):348-52. Exclusion: Wrong outcomes. [pmid: 15949063].
Rosenman M, Wang J, Dexter P, et al. Computerized reminders for syphilis screening in an urban emergency department. Annual Symposium Proceedings/AMIA Symposium. 2003:987. Exclusion: Wrong intervention.
Rosenman MB, Kraft SK, Harezlak J, et al. Syphilis testing in association with gonorrhea/chlamydia testing during a syphilis outbreak. Am J Public Health. 2004;94(7):1124-6. Exclusion: Wrong outcomes. [pmid: 15226131].
Ross MW, Risser J, Peters RJ, et al. Cocaine use and syphilis trends: findings from the arrestee drug abuse monitoring (ADAM) program and syphilis epidemiology in Houston. Am J Addict. 2006;15(6):473-7. Exclusion: Wrong outcomes. [pmid: 17182451].
Rotty J, Anderson D, Garcia M, et al. Preliminary assessment of Treponema pallidum-specific IgM antibody detection and a new rapid point-of-care assay for the diagnosis of syphilis in human immunodeficiency virus-1-infected patients. Int J STD AIDS. 2010;21(11):758-64. Exclusion: Wrong population. [pmid: 21187358].
Ruan Y, Cao X, Qian HZ, et al. Syphilis among female sex workers in southwestern China: potential for HIV transmission. Sex Transm Dis. 2006;33(12):719-23. Exclusion: Population not applicable to U.S. population. [pmid: 16708055].
Ruan Y, Jia Y, Zhang X, et al. Incidence of HIV-1, syphilis, hepatitis B, and hepatitis C virus infections and predictors associated with retention in a 12-month follow-up study among men who have sex with men in Beijing, China. J Acquir Immune Defic Syndr. 2009;52(5):604-10. Exclusion: Wrong outcomes. [pmid: 19710617].
Ruan Y, Luo F, Jia Y, et al. Risk factors for syphilis and prevalence of HIV, hepatitis B and C among men who have sex with men in Beijing, China: implications for HIV prevention. AIDS Behav. 2009;13(4):663-70. Exclusion: Population not applicable to U.S. population. [pmid: 19082879].
Ruger JP, Abdallah AB, Ng NY, et al. Cost-effectiveness of interventions to prevent HIV and STDs among women: a randomized controlled trial. AIDS Behav. 2014;18(10):1913-23. Exclusion: Wrong intervention. [pmid: 24699712].
Rust G, Minor P, Jordan N, et al. Do clinicians screen Medicaid patients for syphilis or HIV when they diagnose other sexually transmitted diseases?. Sex Transm Dis. 2003;30(9):723-7. Exclusion: Wrong outcomes. [pmid: 12972797].
Ryder N, Bourne C, Rohrsheim R. Clinical audit: adherence to sexually transmitted infection screening guidelines for men who have sex with men. Int J STD AIDS. 2005;16(6):446-9. Exclusion: Wrong outcomes. [pmid: 15969782].
Samaranayake A, Chen M, Hocking J, et al. Legislation requiring monthly testing of sex workers with low rates of sexually transmitted infections restricts access to services for higher-risk individuals. Sex Transm Infect. 2009;85(7):540-2. Exclusion: Wrong outcomes. [pmid: 19703842].
Sanchez J, Campos PE, Courtois B, et al. Prevention of sexually transmitted diseases (STDs) in female sex workers: prospective evaluation of condom promotion and strengthened STD services. Sex Transm Dis. 2003;30(4):273-9. Exclusion: Wrong outcomes. [pmid: 12671544].
Sasidharanpillai S, Bindu V, Riyaz N, et al. Syphilis among sexually transmitted infections clinic attendees in a tertiary care institution: a retrospective data analysis. Indian J Dermatol Venereol Leprol. 2014;80(2):161-2. Exclusion: Wrong publication type. [pmid: 24685860].
Sato NS, de Melo CS, Zerbini LC, et al. Assessment of the rapid test based on an immunochromatography technique for detecting anti-Treponema pallidum antibodies. Rev Inst Med Trop Sao Paulo. 2003;45(6):319-22. Exclusion: Wrong population. [pmid: 14762631].
Sato NS, Suzuki T, Ueda T, et al. Recombinant antigen-based immuno-slot blot method for serodiagnosis of syphilis. Braz J Med Biol Res. 2004;37(7):949-55. Exclusion: Wrong publication type. [pmid: 15264000].
Savage EJ, Hughes G, Ison C, et al. Syphilis and gonorrhoea in men who have sex with men: a European overview. Euro Surveill. 2009;14(47). Exclusion: Wrong study design for Key Question.
Schaffzin JK, Koumans EH, Kahn RH, et al. Evaluation of syphilis reactor grids: optimizing impact. Sex Transm Dis. 2003;30(9):700-6. Exclusion: Wrong population. [pmid: 12972793].
Scherbaum N, Baune BT, Mikolajczyk R, et al. Prevalence and risk factors of syphilis infection among drug addicts. BMC Infect Dis. 2005;5:33. Exclusion: Wrong outcomes. [pmid: 15904501].
Schmidt BL. Evaluation of a new particle gel immunoassay for determination of antibodies against Treponema pallidum. J Clin Microbiol. 2004;42(6):2833-5. Exclusion: Wrong intervention. [pmid: 15184485].
Schmitt K, Bulecza S, George D, et al. Florida's multifaceted response for increases in syphilis among MSM: the Miami-Ft. Lauderdale initiative. Sex Transm Dis. 2005;32(10 Suppl):S19-23. Exclusion: Wrong outcomes. [pmid: 16205287].
Schroeter AL, Turner RH, Lucas JB, et al. Therapy for incubating syphilis. Effectiveness of gonorrhea treatment. JAMA. 1971;218(5):711-3. Exclusion: Wrong publication type. [pmid: 5171497].
Schumacher CM, Bernstein KT, Zenilman JM, et al. Reassessing a large-scale syphilis epidemic using an estimated infection date. Sex Transm Dis. 2005;32(11):659-64. Exclusion: Wrong outcomes. [pmid: 16254539].
Scott LJ, Gunson RN, Carman WF, et al. A new multiplex real-time PCR test for HSV1/2 and syphilis: an evaluation of its impact in the laboratory and clinical setting. Sex Transm Infect. 2010;86(7):537-9. Exclusion: Wrong population. [pmid: 20643660].
Scythes JB, Jones CM. Syphilis in the AIDS era: diagnostic dilemma and therapeutic challenge. Acta Microbiol Immunol Hung. 2013;60(2):93-116. Exclusion: Wrong publication type. [pmid: 23827743].
Sena A, Wolff M, Behets F, et al. Seroreversion of nontreponemal antibody titers among HIV-negative patients with an appropriate serological response after treatment of early syphilis. Sex Transm Dis. 2014;41(9). Exclusion: Wrong publication type.
Shah BB, Lang AE. Acquired neurosyphilis presenting as movement disorders. Mov Disord. 2012;27(6):690-5. Exclusion: Review not meeting inclusion criteria. [pmid: 22410849].
Sharma M, Wanchu A, Biswal M, et al. Syphilis serology in human immunodeficiency virus patients: a need to redefine the VDRL test cut-off for biological false-positives. J Med Microbiol. 2010;59(Pt 1):130-1. Exclusion: Wrong publication type. [pmid: 19729459].
Sheng Q, Wang J, Zheng J, et al. Ultrasensitive electrical biosensing of syphilis DNA using target-guided formation of polyaniline based on enzyme-catalyzed polymerization. Biosens Bioelectron. 2010;25(9):2071-7. Exclusion: Wrong intervention. [pmid: 20207129].
Shields M, Guy RJ, Jeoffreys NJ, et al. A longitudinal evaluation of Treponema pallidum PCR testing in early syphilis. BMC Infect Dis. 2012;12:353. Exclusion: Wrong population. [pmid: 23241398].
Shimanskaya I, Zhurauskaya L, Pankratov O, et al. Evaluation of three serological tests manufactured in Belarus for the diagnosis of syphilis. Acta Derm Venereol. 2011;91(3):299-302. Exclusion: Wrong population. [pmid: 21369683].
Shimelis T, Tadesse E. The diagnostic performance evaluation of the SD BIOLINE HIV/syphilis duo rapid test in southern Ethiopia: a cross-sectional study. BMJ Open. 2015;5(4):e007371. Exclusion: Wrong population.
Shrestha B. Screening of syphilis in abroad job seeking healthy males. J Nepal Med Assoc. 2008;47(172):201-4. Exclusion: Wrong population.
Siedner M, Zapitz V, Ishida M, et al. Performance of rapid syphilis tests in venous and fingerstick whole blood specimens. Sex Transm Dis. 2004;31(9):557-60. Exclusion: Wrong intervention. [pmid: 15480118].
Silberstein GS, Coles FB, Greenberg A, et al. Effectiveness and cost-benefit of enhancements to a syphilis screening and treatment program at a county jail. Sex Transm Dis. 2000;27(9):508-17. Exclusion: Wrong outcomes. [pmid: 11034525].
Singh AE, Wong T, De P. Characteristics of primary and late latent syphilis cases which were initially non-reactive with the rapid plasma reagin as the screening test. Int J STD AIDS. 2008;19(7):464-8. Exclusion: Wrong outcomes. [pmid: 18574118].
Singh S, Bell G, Talbot M. The characterisation of a recent syphilis outbreak in Sheffield, UK, and an evaluation of contact tracing as a method of control. Sex Transm Infect. 2007;83(3):193-9. Exclusion: Wrong outcomes. [pmid: 17151024].
Skinner JM, Distefano J, Warrington J, et al. Trends in reported syphilis and gonorrhea among HIV-infected people in Arizona: implications for prevention and control. Public Health Rep. 2014;129(Suppl 1):85-94. Exclusion: Wrong outcomes. [pmid: 24385654].
Smit PW, Mabey D, Changalucha J, et al. The trade-off between accuracy and accessibility of syphilis screening assays. PLoS One. 2013;8(9):e75327. Exclusion: Wrong population. [pmid: 24066175].
Smit PW, Mabey D, van der Vlis T, et al. The implementation of an external quality assurance method for point-of-care tests for HIV and syphilis in Tanzania. BMC Infect Dis. 2013;13:530. Exclusion: Wrong outcomes. [pmid: 24206624].
Smit PW, van der Vlis T, Mabey D, et al. The development and validation of dried blood spots for external quality assurance of syphilis serology. BMC Infect Dis. 2013;13:102. Exclusion: Wrong population. [pmid: 23442198].
Smith BC, Simpson Y, Morshed MG, et al. New proteins for a new perspective on syphilis diagnosis. J Clin Microbiol. 2013;51(1):105-11. Exclusion: Wrong outcomes. [pmid: 23100335].
Snow AF, Vodstrcil LA, Fairley CK, et al. Introduction of a sexual health practice nurse is associated with increased STI testing of men who have sex with men in primary care. BMC Infect Dis. 2013;13:298. Exclusion: Wrong outcomes. [pmid: 23815371].
Solomon MM, Mayer KH, Glidden DV, et al. Syphilis predicts HIV incidence among men and transgender women who have sex with men in a preexposure prophylaxis trial. Clin Infect Dis. 2014;59(7):1020-6. Exclusion: Wrong intervention. [pmid: 24928295].
Soreng K, Mardis C. Syphilis: evolving screening algorithms and role of automated immunoassays. MLO Med Lab Obs. 2012;44(6):30. 2. Exclusion: Wrong publication type. [pmid: 22792643].
Sosman J, Macgowan R, Margolis A, et al. Sexually transmitted infections and hepatitis in men with a history of incarceration. Sex Transm Dis. 2011;38(7):634-9. Exclusion: Wrong outcomes. [pmid: 21844713].
Sosman JM, MacGowan RJ, Margolis AD, et al. Screening for sexually transmitted diseases and hepatitis in 18-29-year-old men recently released from prison: feasibility and acceptability. Int J STD AIDS. 2005;16(2):117-22. Exclusion: Wrong outcomes. [pmid: 15825246].
Spaulding AC, Miller J, Trigg BG, et al. Screening for sexually transmitted diseases in short-term correctional institutions: summary of evidence reviewed for the 2010 Centers for Disease Control and Prevention Sexually Transmitted Diseases Treatment Guidelines. Sex Transm Dis. 2013;40(9):679-84. Exclusion: Wrong publication type. [pmid: 23945422].
Stephens SC, Fann CK, Strona FV, et al. Identifying syphilis risk networks through venue attendance in San Francisco. Sex Transm Dis. 2014;41(5):333-7. Exclusion: Wrong population. [pmid: 24722390].
Strathdee SA, Abramovitz D, Lozada R, et al. Reductions in HIV/STI incidence and sharing of injection equipment among female sex workers who inject drugs: results from a randomized controlled trial. PLoS One. 2013;8(6). Exclusion: Wrong intervention.
Su JR, Beltrami JF, Zaidi AA, et al. Primary and secondary syphilis among black and Hispanic men who have sex with men: case report data from 27 states. Ann Intern Med. 2011;155(3):145-51. Exclusion: Wrong outcomes. [pmid: 21810707].
Sun AH, Mao YF, Hu Y, et al. Sensitive and specific ELISA coated by TpN15-TpN17-TpN47 fusion protein for detection of antibodies to Treponema pallidum. Clin Chem Lab Med. 2009;47(3):321-6. Exclusion: Wrong intervention. [pmid: 19676144].
Suntoke TR, Hardick A, Tobian AA, et al. Evaluation of multiplex real-time PCR for detection of Haemophilus ducreyi, Treponema pallidum, herpes simplex virus type 1 and 2 in the diagnosis of genital ulcer disease in the Rakai District, Uganda. Sex Transm Infect. 2009;85(2):97-101. Exclusion: Wrong population. [pmid: 19066198].
Tai E, Sanchez T, Lansky A, et al. Self-reported syphilis and gonorrhoea testing among men who have sex with men: national HIV behavioural surveillance system, 2003-5. Sex Transm Infect. 2008;84(6):478-82. Exclusion: Wrong outcomes. [pmid: 19028951].
Talha E, Juhasz E, Kanizsai S, et al. Molecular detection of T. pallidum by PCR in seronegative cases. Acta Microbiol Immunol Hung. 2009;56(2):181-9. Exclusion: Wrong population. [pmid: 19621769].
Tang J, Zhou L, Gao W, et al. Visual DNA microarrays for simultaneous detection of human immunodeficiency virus type-1 and Treponema pallidum coupled with multiplex asymmetric polymerase chain reaction. Diagn Microbiol Infect Dis. 2009;65(4):372-8. Exclusion: Wrong outcomes. [pmid: 19765935].
Tankhiwale SS, Naikwade SR. Seroprevalence of syphilis and biologically false positive cases in a tertiary care center. Indian J Dermatol Venereol Leprol. 2014;80(4):340-1. Exclusion: Wrong publication type. [pmid: 25035363].
Tao G, Irwin KL. Receipt of HIV and STD testing services during routine general medical or gynecological examinations: variations by patient sexual risk behaviors. Sex Transm Dis. 2008;35(2):167-71. Exclusion: Wrong outcomes. [pmid: 18090177].
Tayal S, Ahmed MS, Hanif U. Audit of early syphilis: Teesside experience 2005-2007. Int J STD AIDS. 2009;20(9):647-9. Exclusion: Wrong study design for Key Question. [pmid: 19710341].
Taylor MM, Hawkins K, Gonzalez A, et al. Use of the serologic testing algorithm for recent HIV seroconversion (STARHS) to identify recently acquired HIV infections in men with early syphilis in Los Angeles County. J Acquir Immune Defic Syndr. 2005;38(5):505-8. Exclusion: Wrong population. [pmid: 15793359].
Thurnheer MC, Weber R, Toutous-Trellu L, et al. Occurrence, risk factors, diagnosis and treatment of syphilis in the prospective observational Swiss HIV Cohort Study. AIDS. 2010;24(12):1907-16. Exclusion: Wrong outcomes. [pmid: 20616699].
Tong ML, Lin LR, Liu LL, et al. Analysis of 3 algorithms for syphilis serodiagnosis and implications for clinical management. Clin Infect Dis. 2014;58(8):1116-24. Exclusion: Wrong population. [pmid: 24550376].
Tucker JD, Bien CH, Peeling RW. Point-of-care testing for sexually transmitted infections: recent advances and implications for disease control. Curr Opin Infect Dis. 2013;26(1):73-9. Exclusion: Wrong publication type. [pmid: 23242343].
Tucker JD, Bu J, Brown LB, et al. Accelerating worldwide syphilis screening through rapid testing: a systematic review. Lancet Infect Dis. 2010;10(6):381-6. Exclusion: Review not meeting inclusion criteria. [pmid: 20510278].
Tucker JD, Hawkes SJ, Yin YP, et al. Scaling up syphilis testing in China: implementation beyond the clinic. Bull World Health Organ. 2010;88(6):452-7. Exclusion: Wrong publication type. [pmid: 20539859].
Tucker JD, Yang LG, Zhu ZJ, et al. Integrated syphilis/HIV screening in China: a qualitative analysis. BMC Health Serv Res. 2010;10:58. Exclusion: Population not applicable to U.S. population. [pmid: 20205942].
Tuite AR, Fisman DN, Mishra S. Screen more or screen more often? Using mathematical models to inform syphilis control strategies. BMC Public Health. 2013;13:606. Exclusion: Wrong study design for Key Question. [pmid: 23800206].
Valway S, Jenison S, Keller N, et al. Risk assessment and screening for sexually transmitted infections, HIV, and hepatitis virus among long-distance truck drivers in New Mexico, 2004-2006. Am J Public Health. 2009;99(11):2063-8. Exclusion: Wrong comparison. [pmid: 19762674].
Van den Bossche D, Florence E, Kenyon C, et al. Vitros 5600 Syphilis TPA assay: evaluation of an automated chemiluminescence assay for detection of Treponema pallidum antibodies in a high prevalence setting. Sex Transm Dis. 2014;41(11):680-3. Exclusion: Wrong population. [pmid: 25299416].
van Dommelen L, Smismans A, Goossens VJ, et al. Evaluation of a rapid one-step immunochromatographic test and two immunoenzymatic assays for the detection of anti-Treponema pallidum antibodies. Sex Transm Infect. 2008;84(4):292-6. Exclusion: Wrong population. [pmid: 18216156].
Van Wagoner NJ, Harbison HS, Drewry J, et al. Characteristics of women reporting multiple recent sex partners presenting to a sexually transmitted disease clinic for care. Sex Transm Dis. 2011;38(3):210-5. Exclusion: Included for contextual questions only. [pmid: 20966829].
Vandepitte J, Bukenya J, Weiss HA, et al. HIV and other sexually transmitted infections in a cohort of women involved in high-risk sexual behavior in Kampala, Uganda. Sex Transm Dis. 2011;38(4):316-23. Exclusion: Population not applicable to U.S. population. [pmid: 23330152].
Viriyataveekul R, Laodee N, Potprasat S, et al. Comparative evaluation of three different treponemal enzyme immunoassays for syphilis. J Med Assoc Thai. 2006;89(6):773-9. Exclusion: Wrong population. [pmid: 16850676].
Wagner KD, Pitpitan EV, Chavarin CV, et al. Drug-using male clients of female sex workers who report being paid for sex: HIV/sexually transmitted infection, demographic, and drug use correlates. Sex Transm Dis. 2013;40(8):619-23. Exclusion: Population not applicable to U.S. population. [pmid: 23863514].
Wang B, Wang QQ, Yin YP, et al. The effect of a structural intervention for syphilis control among 3597 female sex workers: a demonstration study in South China. J Infect Dis. 2012;206(6):907-14. Exclusion: Wrong outcomes. [pmid: 22807520].
Wang HC, Chen C, Wang LN, et al. The clinical significance comparison of a latex agglutination based syphilis screening test at low antibody titer. Clin Lab. 2013;59(11-12):1429-32. Exclusion: Wrong population. [pmid: 24409682].
Wang LJ, Lin SK, Chiang SC, et al. Risk factors for HIV, viral hepatitis, and syphilis among heroin users in northern Taiwan. Subst Use Misuse. 2013;48(1-2):89-98. Exclusion: Population not applicable to U.S. population. [pmid: 23077983].
Wang LN, Yang L, Zheng HY. Clinical evaluation of four recombinant Treponema pallidum antigen-based rapid tests in the diagnosis of syphilis. Chin Med Sci J. 2007;22(4):250-3. Exclusion: Wrong intervention. [pmid: 18246673].
Wang XF, Norris JL, Liu YJ, et al. Health-related attitudes and risk factors for sexually transmitted infections of Chinese women who have sex with women. Chin Med J. 2012;125(16):2819-25. Exclusion: Population not applicable to U.S. population. [pmid: 22932073].
Wang Y, Gao W, Wang H, et al. Preparation of a visual protein chip for detection of IgG against Treponema pallidum. Mol Biotechnol. 2005;31(2):121-8. Exclusion: Wrong intervention. [pmid: 16170212].
Wei C, Herrick A, Raymond FH, et al. Social marketing interventions to increase HIV/STI testing uptake among men who have sex with men and male-to-female transgender women. Cochrane Database Syst Rev. 2013;(4). Exclusion: Wrong outcomes.
Weiss HA, Thomas SL, Munabi SK, et al. Male circumcision and risk of syphilis, chancroid, and genital herpes: a systematic review and meta-analysis. Sex Transm Infect. 2006;82(2):101-9. discussion 10. Exclusion: Wrong outcomes. [pmid: 16581731].
Welch RJ, Litwin CM. Evaluation of two immunoblot assays and a Western blot assay for the detection of antisyphilis immunoglobulin G antibodies. Clin Vaccine Immunol. 2010;17(1):183-4. Exclusion: Wrong population. [pmid: 19940043].
Wellinghausen N, Dietenberger H. Evaluation of two automated chemiluminescence immunoassays, the LIAISON Treponema Screen and the ARCHITECT Syphilis TP, and the Treponema pallidum particle agglutination test for laboratory diagnosis of syphilis. Clin Chem Lab Med. 2011;49(8):1375-7. Exclusion: Wrong population. [pmid: 21619473].
Wenhai L, Jianzhong Z, Cao Y. Detection of Treponema pallidum in skin lesions of secondary syphilis and characterization of the inflammatory infiltrate. Dermatology. 2004;208(2):94-7. Exclusion: Wrong population. [pmid: 15056995].
West B, Walraven G, Morison L, et al. Performance of the rapid plasma reagin and the rapid syphilis screening tests in the diagnosis of syphilis in field conditions in rural Africa. Sex Transm Infect. 2002;78(4):282-5. Exclusion: Wrong intervention. [pmid: 12181468].
Wheeler HL, Agarwal S, Goh BT. Dark ground microscopy and treponemal serological tests in the diagnosis of early syphilis. Sex Transm Infect. 2004;80(5):411-4. Exclusion: Wrong population. [pmid: 15459413].
White DA, Alter HJ, Irvin NA, et al. Low rate of syphilis screening among high-risk emergency department patients tested for gonorrhea and chlamydia infections. Sex Transm Dis. 2012;39(4):286-90. Exclusion: Wrong outcomes. [pmid: 22421695].
Wimberly YH, Hogben M. Physicians' STD diagnosis and screening practices in the South. South Med J. 2004;97(7):624-30. Exclusion: Wrong outcomes. [pmid: 15301117].
Winscott M, Taylor M, Kenney K. Sexually transmitted diseases among American Indians in Arizona: an important public health disparity. Public Health Rep. 2010;125(Suppl 4):51-60. Exclusion: Wrong outcomes. [pmid: 20626193].
Winston A, Hawkins D, Mandalia S, et al. Is increased surveillance for asymptomatic syphilis in an HIV outpatient department worthwhile?. Sex Transm Infect. 2003;79(3):257-9. Exclusion: Wrong outcomes. [pmid: 12794218].
Wong W, Chaw JK, Kent CK, et al. Risk factors for early syphilis among gay and bisexual men seen in an STD clinic: San Francisco, 2002-2003. Sex Transm Dis. 2005;32(7):458-63. Exclusion: Wrong outcomes. [pmid: 15976605].
Wong W, Tambis JA, Hernandez MT, et al. Prevalence of sexually transmitted diseases among Latino immigrant day laborers in an urban setting--San Francisco. Sex Transm Dis. 2003;30(8):661-3. Exclusion: Wrong outcomes. [pmid: 12897691].
Wong WC, Yim YL, Leung TN, et al. Prevalence and risk factors of sexually transmitted infections in female sex workers in Hong Kong. Hong Kong Med J. 2012;18(Suppl 3):42-6. Exclusion: Population not applicable to U.S. population. [pmid: 22865224].
Wong WC, Yim YL, Lynn H. Sexually transmitted infections among female sex workers in Hong Kong: the role of migration status. J Travel Med. 2011;18(1):1-7. Exclusion: Population not applicable to U.S. population. [pmid: 21199136].
Woznicova V, Valisova Z. Performance of CAPTIA SelectSyph-G enzyme-linked immunosorbent assay in syphilis testing of a high-risk population: analysis of discordant results. J Clin Microbiol. 2007;45(6):1794-7. Exclusion: Wrong population. [pmid: 17442795].
Wu J, Huang J, Xu D, et al. Infection status and risk factors of HIV, HBV, HCV, and syphilis among drug users in Guangdong, China--a cross-sectional study. BMC Public Health. 2010;10:657. Exclusion: Population not applicable to U.S. population. [pmid: 21040549].
Wu Z, Xu J, Liu E, et al. HIV and syphilis prevalence among men who have sex with men: a cross-sectional survey of 61 cities in China. Clin Infect Dis. 2013;57(2):298-309. Exclusion: Wrong outcomes. [pmid: 23580732].
Xiao Y, Sun J, Li C, et al. Prevalence and correlates of HIV and syphilis infections among men who have sex with men in seven provinces in China with historically low HIV prevalence. J Acquir Immune Defic Syndr. 2010;53(Suppl 1):S66-73. Exclusion: Population not applicable to U.S. population. [pmid: 20104113].
Xu JJ, Reilly KH, Lu CM, et al. A cross-sectional study of HIV and syphilis infections among male students who have sex with men (MSM) in northeast China: implications for implementing HIV screening and intervention programs. BMC Public Health. 2011;11:287. Exclusion: Wrong outcomes. [pmid: 21554742].
Yang B, Hallmark CJ, Huang JS, et al. Characteristics and risk of syphilis diagnosis among HIV-infected male cohort: a population-based study in Houston, Texas. Sex Transm Dis. 2013;40(12):957-63. Exclusion: Included for contextual questions only. [pmid: 24220358].
Yang H, Li D, He R, et al. A novel quantum dots-based point of care test for syphilis. Nanoscale Res Lett. 2010;5(5):875-81. Exclusion: Wrong population. [pmid: 20672123].
Yang Z, Su J, Peng X, et al. A decline in HIV and syphilis epidemics in Chinese female sex workers (2000-2011): a systematic review and meta-analysis. PLoS One. 2013;8(12):e82451. Exclusion: Population not applicable to U.S. population. [pmid: 24349288].
Yen-Lieberman B, Daniel J, Means C, et al. Identification of false-positive syphilis antibody results using a semiquantitative algorithm. Clin Vaccine Immunol. 2011;18(6):1038-40. Exclusion: Wrong population. [pmid: 21508162].
Yin YP, Chen XS, Wei WH, et al. A dual point-of-care test shows good performance in simultaneously detecting nontreponemal and treponemal antibodies in patients with syphilis: a multisite evaluation study in China. Clin Infect Dis. 2013;56(5):659-65. Exclusion: Wrong intervention. [pmid: 23132172].
Yin YP, Wei WH, Wang HC, et al. Performance of serological tests for syphilis in sexually transmitted diseases clinics in Guangxi Autonomous Region, China: implications for syphilis surveillance and control. Sex Health. 2009;6(1):5-9. Exclusion: Population not applicable to U.S. population. [pmid: 19254485].
Yin YP, Wong SP, Liu MS, et al. Improving strategies for syphilis control in China: selective testing of sexually transmitted disease patients--too little, too late?. Int J STD AIDS. 2008;19(12):838-42. Exclusion: Population not applicable to U.S. population. [pmid: 19050215].
Yoshida M, Chiba A, Kawano S, et al. Comparison of free and anonymous testing for HIV and sexually transmitted infections between the university hospital and health center. J Infect Chemother. 2012;18(5):704-8. Exclusion: Wrong outcomes. [pmid: 22437886].
Young F. Syphilis: still with us, so watch out!. J Fam Health Care. 2006;16(3):77-81. Exclusion: Wrong publication type. [pmid: 16886730].
Young H, Pryde J, Duncan L, et al. The Architect syphilis assay for antibodies to Treponema pallidum: an automated screening assay with high sensitivity in primary syphilis. Sex Transm Infect. 2009;85(1):19-23. Exclusion: Wrong comparison. [pmid: 18790859].
Zarakolu P, Buchanan I, Tam M, et al. Preliminary evaluation of an immunochromatographic strip test for specific Treponema pallidum antibodies. J Clin Microbiol. 2002;40(8):3064-5. Exclusion: Wrong population. [pmid: 12149381].
Zeng Y, Zhang L, Li T, et al. Risk factors for HIV/syphilis infection and male circumcision practices and preferences among men who have sex with men in China. Biomed Res Int. 2014;2014:498987. Exclusion: Population not applicable to U.S. population. [pmid: 24795883].
Zhang L, Ding X, Lu R, et al. Predictors of HIV and syphilis among men who have sex with men in a Chinese metropolitan city: comparison of risks among students and non-students. PLoS One. 2012;7(5):e37211. Exclusion: Population not applicable to U.S. population. [pmid: 22623994].
Zhang L, Liang S, Lu W, et al. HIV, syphilis, and behavioral risk factors among female sex workers before and after implementation of harm reduction programs in a high drug-using area of China. PLoS One. 2014;9(1):e84950. Exclusion: Population not applicable to U.S. population. [pmid: 24416319].
Zhang L, Qian H, Blevins ML, et al. Internet-based behavioral interventions for preventing HIV infection in men who have sex with men (MSM). Cochrane Database Syst Rev. 2012;(1). Exclusion: Wrong publication type.
Zhang X, Wang C, Hengwei W, et al. Risk factors of HIV infection and prevalence of co-infections among men who have sex with men in Beijing, China. AIDS. 2007;21(Suppl 8):S53-7. Exclusion: Population not applicable to U.S. population. [pmid: 18172392].
Zhao YS, Su SI, Lv CX, et al. Seroprevalence of hepatitis C, hepatitis B virus and syphilis in HIV-1 infected patients in Shandong, China. Int J STD AIDS. 2012;23(9):639-43. Exclusion: Wrong outcomes. [pmid: 23033517].
Zheng J, Wu Z, Poundstone KE, et al. HIV, syphilis infection, and risky sexual behaviors among male university students who have sex with men in Beijing, China: a cross-sectional study. AIDS Educ Prev. 2012;24(1):78-88. Exclusion: Wrong outcomes. [pmid: 22339147].
Zhu L, Gu X, Peng RR, et al. Comparison of the cerebrospinal fluid (CSF) toluidine red unheated serum test and the CSF rapid plasma reagin test with the CSF Venereal Disease Research Laboratory test for diagnosis of neurosyphilis among HIV-negative syphilis patients in China. J Clin Microbiol. 2014;52(3):736-40. Exclusion: Wrong population. [pmid: 24335955].
Zhuang YH, Tian Y, Chen Y, et al. Evaluation of the Determine Syphilis TP assay for the detection of antibodies against Treponema pallidum for the serodiagnosis of syphilis. Eur J Clin Microbiol Infect Dis. 2012;31(6):929-35. Exclusion: Wrong intervention. [pmid: 21866323].
Zou H, Fairley CK, Guy R, et al. The efficacy of clinic-based interventions aimed at increasing screening for bacterial sexually transmitted infections among men who have sex with men: a systematic review. Sex Transm Dis. 2012;39(5):382-7. Exclusion: Included orriginal studies (no new data). [pmid: 22504605].
Zou H, Wu Z, Yu J, et al. Sexual risk behaviors and HIV infection among men who have sex with men who use the internet in Beijing and Urumqi, China. J Acquir Immune Defic Syndr. 2010;53(Suppl 1):S81-7. Exclusion: Population not applicable to U.S. population. [pmid: 20104115].
Zou S, Notari EP, Fang CT, et al. Current value of serologic test for syphilis as a surrogate marker for blood-borne viral infections among blood donors in the United States. Transfusion. 2009;49(4):655-61. Exclusion: Wrong population. [pmid: 19170999].

## Appendix B5 Quality Rating Criteria

### Cohort Studies1,2

#### Criteria

- Initial assembly of comparable groups: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies.

#### Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup at least 80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

### Diagnostic Accuracy Studies1,2

#### Criteria

- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate results in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test

#### Definition of ratings based on above criteria

Good: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease.
Fair: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor: | Has fatal flaw such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

## Appendix B6 List of Peer Reviewers

### Expert reviewers

Matthew J. Binnicker, PhD, D(ABMM) Director of Clinical Virology, Division of Clinical Microbiology, Department of Laboratory Medicine and Pathology, Mayo Clinic, Rochester, MN

Khalil Ghanem, MD, PhD Associate Professor of Medicine, Johns Hopkins University, School of Medicine, Baltimore, MD

Heidi M. Bauer, MD, MPH, MS Chief, STD Control Branch, California Department of Public Health, Richmond, CA

Jeffrey D. Klausner, MD, MPH Professor of Medicine and Public Health, UCLA, Los Angeles, CA

### Federal reviewers

Tom Peterman, MD, MSc Chief, Epidemiology 2 Unit, Division of STD Prevention, CDC, Atlanta, Georgia

Catherine T. Witkop, MD, MPH Chief, Preventive Medicine, Air Force