# Terminology

Enzyme Immunoassay (EIA): An assay designed to detect antigens of antibodies by producing an enzyme triggered color change.
Indeterminate test result: Test result was not clear.
Likelihood Ratio: Positive Likelihood Ratio – ratio between the probability of a positive test result given the presence of the disease and the probability of a positive test result given the absence of the disease; Negative Likelihood Ratio – ratio between the probability of a negative test result given the presence of the disease and the probability of a negative test result given the absence of the disease.
Men who have sex with men (MSM): Men who engage in sexual activities with other men, even if they engage in sexual activities with women as well.
Men who have sex with women (MSW): Men who engage in sexual activities with women only.
Predictive Value (PPV): Positive Predictive Value – the proportion of people with a positive test who have the disease; Negative Predictive Value – proportion of people with a negative test who are free of disease.
Prozone phenomenon: False negative due to lack of agglutination with high antibody levels.
Rapid Plasma Reagin (RPR): A type of rapid diagnostic test that looks for non-specific antibodies in the blood of a patient.
Relative Risk (RR): Ratio of the risk of an event among an exposed population to the risk among the unexposed.
Sensitivity: The proportion of truly diseased/infected persons in the screened population who are identified as diseased by the screening test—that is, the true-positive rate.
Serofast: Persistent, low-level positive titer after adequate treatment.
Specificity: The proportion of truly nondiseased/noninfected persons who are identified as such by the screening test—that is, the true-negative rate.
Venereal Disease Research Laboratory (VDRL): A blood test for syphilis developed by the former Venereal Disease Research Laboratory, now the Treponemal Pathogenesis and Immunology Branch of the United States Public Health Service. The test is used to screen for syphilis.