# References

1 American Cancer Society. Cancer Facts and Figures 2013. Atlanta. American Cancer Society. 2013.
2 U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999–2011 Incidence and Mortality Web-based Report. Atlanta. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention and National Cancer Institute. 2014.
3 National Cancer Institute. SEER Cancer Statistics Factsheets: Colon and Rectum Cancer. Bethesda, MD. 2014.
4 Cress RD, Morris CR, Wolfe BM. Cancer of the colon and rectum in California: trends in incidence by race/ethnicity, stage, and subsite. Prev Med. Oct. 2000;31(4):447-53. [pmid: 11006071].
5 Ward E, Jemal A, Cokkinides V, et al. Cancer disparities by race/ethnicity and socioeconomic status. CA Cancer J Clin. Mar. 2004;54(2):78-93. [pmid: 15061598].
6 Irby K, Anderson WF, Henson DE, et al. Emerging and widening colorectal carcinoma disparities between Blacks and Whites in the United States (1975–2002). Cancer Epidemiol Biomarkers Prev. Apr. 2006;15(4):792-7. [pmid: 16614125].
7 Whitlock EP, Lin JS, Liles E, et al. Screening for colorectal cancer: a targeted, updated systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. Nov. 4. 2008;149(9):638-58. [pmid: 18838718].
8 Soetikno RM, Kaltenbach T, Rouse RV, et al. Prevalence of nonpolypoid (flat and depressed) colorectal neoplasms in asymptomatic and symptomatic adults. JAMA. Mar. 5. 2008;299(9):1027-35. [pmid: 18319413].
9 Walsh JM, Terdiman JP. Colorectal cancer screening: scientific review. JAMA. 2003;289(10):1288-96. Mar. 12. [pmid: 12633191].
10 Chen CD, Yen MF, Wang WM, et al. A case-cohort study for the disease natural history of adenoma-carcinoma and de novo carcinoma and surveillance of colon and rectum after polypectomy: implication for efficacy of colonoscopy. Br J Cancer. Jun. 16. 2003;88(12):1866-73. [pmid: 12799628].
11 Galiatsatos P, Foulkes WD. Familial adenomatous polyposis. Am J Gastroenterol. Feb. 2006;101(2):385-98. [pmid: 16454848].
12 Lynch HT, Smyrk T. Hereditary nonpolyposis colorectal cancer (Lynch syndrome). An updated review. Cancer. Sep. 15. 1996;78(6):1149-67. [pmid: 8826936].
13 Morson B. President’s address. The polyp-cancer sequence in the large bowel. Proc R Soc Med. Jun. 1974;67(6 Pt 1):451-7. [pmid: 4853754].
14 Jarvinen HJ, Mecklin JP, Sistonen P. Screening reduces colorectal cancer rate in families with hereditary nonpolyposis colorectal cancer. Gastroenterology. May. 1995;108(5):1405-11. [pmid: 7729632].
15 Citarda F, Tomaselli G, Capocaccia R, et al. Efficacy in standard clinical practice of colonoscopic polypectomy in reducing colorectal cancer incidence. Gut. Jun. 2001;48(6):812-5. [pmid: 11358901].
16 Winawer SJ, Zauber AG, Ho MN, et al. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. Dec. 30. 1993;329(27):1977-81. [pmid: 8247072].
17 Thiis-Evensen E, Hoff GS, Sauar J, et al. Population-based surveillance by colonoscopy: effect on the incidence of colorectal cancer. Telemark Polyp Study I. Scand J Gastroenterol. Apr. 1999;34(4):414-20. [pmid: 10365903].
18 Selby JV, Friedman GD, Quesenberry CP Jr, et al. A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. Mar. 5. 1992;326(10):653-7. [pmid: 1736103].
19 Newcomb PA, Norfleet RG, Storer BE, et al. Screening sigmoidoscopy and colorectal cancer mortality. J Natl Cancer Inst. Oct. 21. 1992;84(20):1572-5. [pmid: 1404450].
20 Muller AD, Sonnenberg A. Prevention of colorectal cancer by flexible endoscopy and polypectomy. A case-control study of 32,702 veterans. Ann Intern Med. Dec. 15. 1995;123(12):904-10. [pmid: 7486484].
21 Zauber AG, Winawer SJ, O’Brien MJ, et al. Colonoscopic polypectomy and long-term prevention of colorectal-cancer deaths. N Engl J Med. Feb. 23. 2012;366(8):687-96. [pmid: 22356322].
22 Heitman SJ, Ronksley PE, Hilsden RJ, et al. Prevalence of adenomas and colorectal cancer in average risk individuals: a systematic review and meta-analysis. Clinical Gastroenterology & Hepatology. Dec. 2009;7(12):1272-8. [pmid: 19523536].
23 Hofstad B, Vatn MH, Andersen SN, et al. Growth of colorectal polyps: redetection and evaluation of unresected polyps for a period of three years. Gut. Sep. 1996;39(3):449-56. [pmid: 8949653].
24 Bersentes K, Fennerty MB, Sampliner RE, et al. Lack of spontaneous regression of tubular adenomas in two years of follow-up. Am J Gastroenterol. Jul. 1997;92(7):1117-20. [pmid: 9219781].
25 Young GP, Bosch LJ. Fecal Tests: From Blood to Molecular Markers. Curr Colorectal Cancer Rep. Mar. 2011;7(1):62-70. [pmid: 21423316].
26 Crockett SD, Snover DC, Ahnen DJ, et al. Sessile serrated adenomas: an evidence-based guide to management. Clin Gastroenterol Hepatol. Jan. 2015;13(1):11-26. [pmid: 24216467].
27 Schoenfeld P. Small and diminutive polyps: implications for colorectal cancer screening with computed tomography colonography. Clinical Gastroenterology & Hepatology. 2006;4(3):293-5. Mar. [pmid: 16527690].
28 Schoen RE, Weissfeld JL, Pinsky PF, et al. Yield of advanced adenoma and cancer based on polyp size detected at screening flexible sigmoidoscopy. Gastroenterology. 2006;131(6):1683-9. Dec. [pmid: 17188959].
29 Coe SG, Wallace MB. Management of small and diminutive colorectal polyps: a review of the literature. Minerva Gastroenterologica e Dietologica. Jun. 2011;57(2):167-76. [pmid: 21587146].
30 Hassan C, Repici A, Zullo A, et al. Colonic polyps: are we ready to resect and discard?. Gastrointestinal Endoscopy Clinics of North America. Jul. 2013;23(3):663-78. [pmid: 23735109].
31 Hassan C, Pickhardt PJ, Kim DH, et al. Alimentary Pharmacology & Therapeutics. Jan. 15. 2010;31(2). [pmid: 19814745].
32 Lieberman D, Moravec M, Holub J, et al. Polyp size and advanced histology in patients undergoing colonoscopy screening: implications for CT colonography. Gastroenterology. Oct. 2008;135(4):1100-5. [pmid: 18691580].
33 Hoff G, Sauar J, Vatn MH, et al. Polypectomy of adenomas in the prevention of colorectal cancer: 10 years’ follow-up of the Telemark Polyp Study I. A prospective, controlled population study. Scand J Gastroenterol. Oct. 1996;31(10):1006-10. [pmid: 8898422].
34 Pickhardt PJ, Kim DH, Pooler BD, et al. Assessment of volumetric growth rates of small colorectal polyps with CT colonography: A longitudinal study of natural history. The lancet oncology. 2013;14:711-20. [pmid: 23746988].
35 Phipps AI, Scoggins J, Rossing MA, et al. Temporal trends in incidence and mortality rates for colorectal cancer by tumor location: 1975–2007. American Journal of Public Health. Sep. 2012;102(9):1791-7. [pmid: 22873481].
36 Siegel RL, Ward EM, Jemal A. Trends in colorectal cancer incidence rates in the United States by tumor location and stage, 1992–2008. Cancer Epidemiology, Biomarkers & Prevention. Mar. 2012;21(3):411-6. [pmid: 22219318].
37 Rabeneck L, Davila JA, El-Serag HB. Is there a true “shift” to the right colon in the incidence of colorectal cancer?. Am J Gastroenterol. Jun. 2003;98(6):1400-9. [pmid: 12818288].
38 Brenner H, Hoffmeister M, Arndt V, et al. Protection from right- and left-sided colorectal neoplasms after colonoscopy: population-based study. J Natl Cancer Inst. Jan. 20. 2010;102(2):89-95. [pmid: 20042716].
39 Baxter NN, Warren JL, Barrett MJ, et al. Association between colonoscopy and colorectal cancer mortality in a US cohort according to site of cancer and colonoscopist specialty. Journal of Clinical Oncology. Jul. 20. 2012;30(21):2664-9. [pmid: 22689809].
40 Brenner H, Chang-Claude J, Seiler CM, et al. Protection From Colorectal Cancer After Colonoscopy A Population-Based, Case-Control Study. Ann Intern Med. Jan. 4. 2011;154(1):22-30. [pmid: 21200035].
41 Nishihara R, Wu K, Lochhead P, et al. Long-Term Colorectal-Cancer Incidence and Mortality after Lower Endoscopy. N Engl J Med. Sep. 18. 2013;369(12):1095-105. [pmid: 24047059].
42 Doubeni CA, Weinmann S, Adams K, et al. Screening colonoscopy and risk for incident late-stage colorectal cancer diagnosis in average-risk adults: a nested case-control study. Ann Intern Med. Mar. 5. 2013;158(5 Pt 1):312-20. [pmid: 23460054].
43 Yamauchi M, Lochhead P, Morikawa T, et al. Colorectal cancer: a tale of two sides or a continuum?. Gut. Jun. 1. 2012;61(6):794-7. [pmid: 22490520].
44 Azzoni C, Bottarelli L, Campanini N, et al. Distinct molecular patterns based on proximal and distal sporadic colorectal cancer: arguments for different mechanisms in the tumorigenesis. Int J Colorectal Dis. 2007;22(2):115-26. [pmid: 17021745].
45 O’Brien MJ, Winawer SJ, Zauber AG, et al. Flat adenomas in the National Polyp Study: is there increased risk for high-grade dysplasia initially or during surveillance?. Clinical Gastroenterology & Hepatology. 2004;2(10):905-11. Oct. [pmid: 15476154].
46 Siegel R, DeSantis C, Jemal A. Colorectal cancer statistics, 2014. CA Cancer J Clin. Mar. 1. 2014;64(2):104-17. [pmid: 24639052].
47 Henry KA, Sherman RL, McDonald K, et al. Associations of census-tract poverty with subsite-specific colorectal cancer incidence rates and stage of disease at diagnosis in the United States. J Cancer Epidemiol. 2014;2014:823484. [pmid: 25165475].
48 Ferlitsch M, Reinhart K, Pramhas S, et al. Sex-specific prevalence of adenomas, advanced adenomas, and colorectal cancer in individuals undergoing screening colonoscopy. JAMA. Sep. 28. 2011;306(12):1352-8. [pmid: 21954479].
49 Graser A, Stieber P, Nagel D, et al. Comparison of CT colonography, colonoscopy, sigmoidoscopy and faecal occult blood tests for the detection of advanced adenoma in an average risk population. Gut. Feb. 2009;58(2):241-8. [pmid: 18852257].
50 Johnson CD, Chen MH, Toledano AY, et al. Accuracy of CT colonography for detection of large adenomas and cancers. N Engl J Med. Sep. 18. 2008;359(12):1207-17. [pmid: 18799557].
51 Lefere P, Silva C, Gryspeerdt S, et al. Teleradiology based CT colonography to screen a population group of a remote island; at average risk for colorectal cancer. European Journal of Radiology. Jun. 2013;82(6):e262-e267. [pmid: 23473734].
52 Pickhardt PJ, Choi JR, Hwang I, et al. Computed tomographic virtual colonoscopy to screen for colorectal neoplasia in asymptomatic adults. N Engl J Med. Dec. 4. 2003;349(23):2191-200. [pmid: 14657426].
53 Nusko G, Mansmann U, tendorf-Hofmann A, et al. Risk of invasive carcinoma in colorectal adenomas assessed by size and site. Int J Colorectal Dis. 1997;12(5):267-71. [pmid: 9401839].
54 Gupta S, Balasubramanian BA, Fu T, et al. Polyps with advanced neoplasia are smaller in the right than in the left colon: implications for colorectal cancer screening. Clinical Gastroenterology & Hepatology. Dec. 2012;10(12):1395-401. [pmid: 22835574].
55 Wong RJ. Marked variations in proximal colon cancer survival by race/ethnicity within the United States. Journal of Clinical Gastroenterology. Oct. 2010;44(9):625-30. [pmid: 19996985].
56 Lieberman DA, Holub JL, Moravec MD, et al. Prevalence of colon polyps detected by colonoscopy screening in asymptomatic black and white patients. JAMA. Sep. 24. 2008;300(12):1417-22. [pmid: 18812532].
57 Thornton JG, Morris AM, Thornton JD, et al. Racial variation in colorectal polyp and tumor location. Journal of the National Medical Association. Jul. 2007;99(7):723-8. [pmid: 17668638].
58 Schroy PC III, Coe A, Chen CA, et al. Prevalence of advanced colorectal neoplasia in white and black patients undergoing screening colonoscopy in a safety-net hospital. Ann Intern Med. Jul. 2. 2013;159(1):13-20. [pmid: 23817700].
59 Lieberman DA, Williams JL, Holub JL, et al. Race, ethnicity, and sex affect risk for polyps >9 mm in average-risk individuals. Gastroenterology. 2014;147(2):351-8. [pmid: 24786894].
60 Lee B, Holub J, Peters D, et al. Prevalence of colon polyps detected by colonoscopy screening of asymptomatic Hispanic patients. Digestive Diseases & Sciences. Feb. 2012;57(2):481-8. [pmid: 21918852].
61 Eaden JA, Mayberry JF. Colorectal cancer complicating ulcerative colitis: a review. Am J Gastroenterol. Oct. 2000;95(10):2710-9. [pmid: 11051339].
62 Schoen RE. Families at risk for colorectal cancer: risk assessment and genetic testing. J Clin Gastroenterol. Sep. 2000;31(2):114-20. [pmid: 10993425].
63 Weitz J, Koch M, Debus J, et al. Colorectal cancer. Lancet. Jan. 8. 2005;365(9454):153-65. [pmid: 15639298].
64 Winawer SJ. Screening of colorectal cancer: progress and problems. Recent Results Cancer Res. 2005;166:231-44. [pmid: 15648193].
65 Taylor DP, Burt RW, Williams MS, et al. Population-based family history-specific risks for colorectal cancer: a constellation approach. Gastroenterology. Mar. 2010;138(3):877-85. [pmid: 19932107].
66 Johns LE, Houlston RS. A systematic review and meta-analysis of familial colorectal cancer risk. Am J Gastroenterol. Oct. 2001;96(10):2992-3003. [pmid: 11693338].
67 Baglietto L, Jenkins MA, Severi G, et al. Measures of familial aggregation depend on definition of family history: meta-analysis for colorectal cancer. Journal of Clinical Epidemiology. Feb. 2006;59(2):114-24. [pmid: 16426946].
68 Hopper JL. Disease-specific prospective family study cohorts enriched for familial risk. Epidemiol Perspect Innov. 2011;8(1):2. [pmid: 21352566].
69 Win AK, Macinnis RJ, Hopper JL, et al. Risk prediction models for colorectal cancer: a review. Cancer Epidemiol Biomarkers Prev. Mar. 2012;21(3):398-410. [pmid: 22169185].
70 Vital signs: colorectal cancer screening test use - United States, 2012. MMWR Morb Mortal Wkly Rep. Nov. 8. 2013;62(44):881-8. [pmid: 24196665].
71 Prevlance of colorectal cancer screening among adults--Behavioral Risk Factor Surveillance System, United States, 2010. MMWR: Morbidity & Mortality Weekly Report. 2012;61(suppl):51-6. [pmid: 22695464].
72 Holden DJ, Jonas DE, Porterfield DS, et al. Systematic review: enhancing the use and quality of colorectal cancer screening. Ann Intern Med. May. 18. 2010;152(10):668-76. [pmid: 20388703].
73 Whitlock EP, Lin J, Liles E, et al. Screening for Colorectal Cancer: An Updated Systematic Review. 2008. [bookaccession].
74 U.S. Food and Drug Administration. Clinical Laboratory Improvement Amendments. Fecal Occult Blood. 2015.
75 Ashraf I, Paracha SR, Arif M, et al. Digital rectal examination versus spontaneous passage of stool for fecal occult blood testing. Southern Medical Journal. Jul. 2012;105(7):357-61. [pmid: 22766663].
76 Nakama H, Zhang B, Abdul Fattah AS, et al. Does stool collection method affect outcomes in immunochemical fecal occult blood testing?. Dis Colon Rectum. Jun. 2001;44(6):871-5. [pmid: 11391151].
77 Klabunde C, Breen N, Meissner H, et al. Use of colonoscopy for colorectal cancer screening. Cancer Epidemiol Biomarkers Prev. Sep. 2005;14(9):2279-80. [pmid: 16172249].
78 Zapka J, Klabunde CN, Taplin S, et al. Screening colonoscopy in the US: attitudes and practices of primary care physicians. J GEN INTERN MED. Sep. 2012;27(9):1150-8. [pmid: 22539065].
79 Baxter NN, Goldwasser MA, Paszat LF, et al. Association of colonoscopy and death from colorectal cancer. Ann Intern Med. Jan. 6. 2009;150(1):1-8. [pmid: 19075198].
80 Singh H, Nugent Z, Demers AA, et al. The Reduction in Colorectal Cancer Mortality After Colonoscopy Varies by Site of the Cancer. Gastroenterology. Oct. 2010;139(4):1128-37. [pmid: 20600026].
81 Lakoff J, Paszat LF, Saskin R, et al. Risk of Developing Proximal Versus Distal Colorectal Cancer After a Negative Colonoscopy: A Population-Based Study. Clinical Gastroenterology and Hepatology. Oct. 2008;6(10):1117-21. [pmid: 18691942].
82 Rim SH, Joseph DA, Steele CB, et al. Colorectal cancer screening - United States, 2002, 2004, 2006, and 2008. MMWR Surveill Summ. Jan. 14. 2011;60(Suppl):42-6. [pmid: 21430619].
83 Meissner HI, Breen N, Klabunde CN, et al. Patterns of colorectal cancer screening uptake among men and women in the United States. Cancer Epidemiology, Biomarkers & Prevention. 2006;15(2):389-94. Feb. [pmid: 16492934].
84 McNamara D. FDA Panel: Most favor CTC colorectal cancer screen. Medscape. 2013. http://www.medscape.com/viewarticle/810740. Accessed December 18, 2014.
85 Zijta FM, Bipat S, Stoker J. Magnetic resonance (MR) colonography in the detection of colorectal lesions: a systematic review of prospective studies. European Radiology. May. 2010;20(5):1031-46. [pmid: 19936754].
86 Spada C, Hassan C, Marmo R, et al. Meta-analysis shows colon capsule endoscopy is effective in detecting colorectal polyps. Clinical Gastroenterology & Hepatology. Jun. 2010;8(6):516-22. [pmid: 20215066].
87 U.S. Preventive Services Task Force. Screening for colorectal cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. Nov. 4. 2008;149(9):627-37. [pmid: 18838716].
88 Levin B, Lieberman DA, McFarland B, et al. Screening and surveillance for the early detection of colorectal cancer and adenomatous polyps, 2008: a joint guideline from the American Cancer Society, the US Multi-Society Task Force on Colorectal Cancer, and the American College of Radiology. CA Cancer J Clin. May. 2008;58(3):130-60. [pmid: 18322143].
89 Zauber A, Knudsen A, Rutter CM, Lansdorp-Vogelaar I, Kuntz KM. Evaluating the Benefits and Harms of Colorectal Cancer Screening Strategies: A Collaborative Modeling Approach. AHRQ Publication No. 14-05203-EF-2. Rockville, MD. Agency for Healthcare Research and Quality. 2015.
90 Whitlock EP, Lin J, Liles E, et al. Screening for Colorectal Cancer: An Updated Systematic Review. 2008. [pmid: 20722162].
91 Wallace BC, Small K, Brodley CE, et al. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the ACM International Health Informatics Symposium. 2012:819-24. PMID: None.
92 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. Sep. 15. 1999;282(11):1061-6. [pmid: 10493205].
93 Whiting P, Rutjes AW, Reitsma JB, et al. Sources of variation and bias in studies of diagnostic accuracy: a systematic review. Ann Intern Med. Feb. 3. 2004;140(3):189-202. [pmid: 14757617].
94 Leeflang MM, Bossuyt PM, Irwig L. Diagnostic test accuracy may vary with prevalence: implications for evidence-based diagnosis. J Clin Epidemiol. Jan. 2009;62(1):5-12. [pmid: 18778913].
95 Ransohoff DF, Feinstein AR. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. Oct. 26. 1978;299(17):926-30. [pmid: 692598].
96 Rutjes AW, Reitsma JB, Di NM, et al. Evidence of bias and variation in diagnostic accuracy studies. CMAJ. Feb. 14. 2006;174(4):469-76. [pmid: 16477057].
97 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
98 National Institute for Health and Clinical Excellence. The guidelines manual. London. National Institute for Health and Clinical Excellence. 2006.
99 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
100 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. Ottawa. Ottawa Hospital Research Institute. 2014. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed January 21, 2014. PMID: None.
101 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
102 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
103 de Groot JA, Bossuyt PM, Reitsma JB, et al. Verification problems in diagnostic accuracy studies: consequences and solutions. BMJ. 2011;343:d4770. [pmid: 21810869].
104 Thompson SG, Sharp SJ. Explaining heterogeneity in meta-analysis: A comparison of methods. Statistics in Medicine. 1999;18:2693-708. [pmid: 10521860].
105 Guolo A, Varin C. Package ‘metaLik’. 2014.
106 Rutter CM, Gatsonis CA. A hierarchical regression approach to meta-analysis of diagnostic test accuracy evaluations. Stat Med. Oct. 15. 2001;20(19):2865-84. [pmid: 11568945].
107 Viechtbauer W. Conducting meta-analyses in R with the metafor package. Journal of Statistical Software. 2010;36(3).
108 Fraser CG, Allison JE, Halloran SP, et al. A proposal to standardize reporting units for fecal immunochemical tests for hemoglobin. J Natl Cancer Inst. Jun. 6. 2012;104(11):810-4. [pmid: 22472305].
109 Atkin WS, Edwards R, Kralj-Hans I, et al. Once-only flexible sigmoidoscopy screening in prevention of colorectal cancer: a multicentre randomised controlled trial. Lancet. May. 8. 2010;375(9726):1624-33. [pmid: 20430429].
110 Berry DP, Clarke P, Hardcastle JD, et al. Randomized trial of the addition of flexible sigmoidoscopy to faecal occult blood testing for colorectal neoplasia population screening. Br J Surg. Sep. 1997;84(9):1274-6. [pmid: 9313712].
111 Brevinge H, Lindholm E, Buntzen S, et al. Screening for colorectal neoplasia with faecal occult blood testing compared with flexible sigmoidoscopy directly in a 55–56 years’ old population. Int J Colorectal Dis. 1997;12(5):291-5. [pmid: 9401844].
112 Faivre J, Dancourt V, Denis B, et al. Comparison between a guaiac and three immunochemical faecal occult blood tests in screening for colorectal cancer. European Journal of Cancer. Nov. 2012;48(16):2969-76. [pmid: 22572481].
113 Faivre J, Dancourt V, Lejeune C, et al. Reduction in colorectal cancer mortality by fecal occult blood screening in a French controlled study. Gastroenterology. Jun. 2004;126(7):1674-80. [pmid: 15188160].
114 Guittet L, Bouvier V, Mariotte N, et al. Comparison of a guaiac and an immunochemical faecal occult blood test for the detection of colonic lesions according to lesion type and location. British Journal of Cancer. Apr. 21. 2009;100(8):1230-5. [pmid: 19337253].
115 Hamza S, Dancourt V, Lejeune C, et al. Diagnostic yield of a one sample immunochemical test at different cut-off values in an organised screening programme for colorectal cancer. European Journal of Cancer. Aug. 2013;49(12):2727-33. [pmid: 23601670].
116 Hol L, van Leerdam ME, van BM, et al. Screening for colorectal cancer: randomised trial comparing guaiac-based and immunochemical faecal occult blood testing and flexible sigmoidoscopy. Gut. Jan. 2010;59(1):62-8. [pmid: 19671542].
117 Kronborg O, Jorgensen OD, Fenger C, et al. Randomized study of biennial screening with a faecal occult blood test: results after nine screening rounds. Scand J Gastroenterol. Sep. 2004;39(9):846-51. [pmid: 15513382].
118 Lindholm E, Brevinge H, Haglind E. Survival benefit in a randomized clinical trial of faecal occult blood screening for colorectal cancer. British Journal of Surgery. Aug. 2008;95(8):1029-36. [pmid: 18563785].
119 Malila N, Palva T, Malminiemi O, et al. Coverage and performance of colorectal cancer screening with the faecal occult blood test in Finland. Journal of Medical Screening. 2011;18(1):18-23. [pmid: 21536812].
120 Quintero E, Castells A, Bujanda L, et al. Colonoscopy versus fecal immunochemical testing in colorectal-cancer screening. N Engl J Med. Feb. 23. 2012;366(8):697-706. [pmid: 22356323].
121 Rasmussen M, Kronborg O, Fenger C, et al. Possible advantages and drawbacks of adding flexible sigmoidoscopy to hemoccult-II in screening for colorectal cancer. A randomized study. Scand J Gastroenterol. Jan. 1999;34(1):73-8. [pmid: 10048736].
122 Schoen RE, Pinsky PF, Weissfeld JL, et al. Colorectal-cancer incidence and mortality with screening flexible sigmoidoscopy. N Engl J Med. Jun. 21. 2012;366(25):2345-57. [pmid: 22612596].
123 Scholefield JH, Moss SM, Mangham CM, et al. Nottingham trial of faecal occult blood testing for colorectal cancer: a 20-year follow-up. Gut. Jul. 2012;61(7):1036-40. [pmid: 22052062].
124 Segnan N, Armaroli P, Bonelli L, et al. Once-only sigmoidoscopy in colorectal cancer screening: follow-up findings of the Italian Randomized Controlled Trial--SCORE. J Natl Cancer Inst. Sep. 7. 2011;103(17):1310-22. [pmid: 21852264].
125 Segnan N, Senore C, Andreoni B, et al. Comparing attendance and detection rate of colonoscopy with sigmoidoscopy and FIT for colorectal cancer screening. Gastroenterology. Jun. 2007;132(7):2304-12. [pmid: 17570205].
126 Segnan N, Senore C, Andreoni B, et al. Randomized trial of different screening strategies for colorectal cancer: patient response and detection rates. J Natl Cancer Inst. Mar. 2. 2005;97(5):347-57. [pmid: 15741571].
127 Shaukat A, Mongin SJ, Geisser MS, et al. Long-Term Mortality after Screening for Colorectal Cancer. N Engl J Med. Sep. 18. 2013;369(12):1106-14. [pmid: 24047060].
128 Stoop EM, de Haan MC, de Wijkerslooth TR, et al. Participation and yield of colonoscopy versus non-cathartic CT colonography in population-based screening for colorectal cancer: a randomised controlled trial. Lancet Oncology. Jan. 2012;13(1):55-64. [pmid: 22088831].
129 van Roon AH, Goede SL, van BM, et al. Random comparison of repeated faecal immunochemical testing at different intervals for population-based colorectal cancer screening. Gut. Mar. 2013;62(3):409-15. [pmid: 22387523].
130 van Rossum LG, van Rijn AF, Laheij RJ, et al. Random comparison of guaiac and immunochemical fecal occult blood tests for colorectal cancer in a screening population. Gastroenterology. Jul. 2008;135(1):82-90. [pmid: 18482589].
131 Verne JECW, Roger A, Sharon BL, et al. Population based randomised study of uptake and yield of screening by flexible sigmoidoscopy compared with screening by faecal occult blood testing. BMJ. Jul. 1998;18:317. [pmid: 9665902].
132 Zubero MB, Arana-Arri E, Pijoan JI, et al. Population-based colorectal cancer screening: comparison of two fecal occult blood test. Front Pharmacol. Jan. 10. 2014;4:175. [pmid: 24454288].
133 Atkin WS. Single flexible sigmoidoscopy screening to prevent colorectal cancer: baseline findings of a UK multicentre randomised trial. The Lancet. Apr. 13. 2002;359(9314):1291-300. [pmid: 11965274].
134 Atkin WS, Cuzick J, Northover JM, et al. Prevention of colorectal cancer by once-only sigmoidoscopy. Lancet. Mar. 20. 1993;341(8847):736-40. [pmid: 8095636].
135 Bretthauer M, Gondal G, Larsen K, et al. Design, organization and management of a controlled population screening study for detection of colorectal neoplasia: attendance rates in the NORCCAP study (Norwegian Colorectal Cancer Prevention). Scand J Gastroenterol. May. 2002;37(5):568-73. [pmid: 12059059].
136 de Wijkerslooth TR, de Haan MC, Stoop EM, et al. Study protocol: population screening for colorectal cancer by colonoscopy or CT colonography: a randomized controlled trial. BMC Gastroenterology. 2010;10:47. [pmid: 20482825].
137 Denters MJ, Deutekom M, Bossuyt PM, et al. Lower risk of advanced neoplasia among patients with a previous negative result from a fecal test for colorectal cancer. Gastroenterology. Mar. 2012;142(3):497-504. [pmid: 22108194].
138 Denters MJ, Deutekom M, Fockens P, et al. Implementation of population screening for colorectal cancer by repeated fecal occult blood test in the Netherlands. BMC Gastroenterology. 2009;9:28. [pmid: 19393087].
139 Faivre J, Dancourt V, Manfredi S, et al. Positivity rates and performances of immunochemical faecal occult blood tests at different cut-off levels within a colorectal cancer screening programme. Digestive & Liver Disease. Aug. 2012;44(8):700-4. [pmid: 22542582].
140 Guittet L, Bouvier V, Guillaume E, et al. Colorectal cancer screening: why immunochemical faecal occult blood test performs as well with either one or two samples. Digestive & Liver Disease. Aug. 2012;44(8):694-9. [pmid: 22525156].
141 Guittet L, Bouvier V, Mariotte N, et al. Performance of immunochemical faecal occult blood test in colorectal cancer screening in average-risk population according to positivity threshold and number of samples. International Journal of Cancer. Sep. 1. 2009;125(5):1127-33. [pmid: 19431212].
142 Hardcastle JD, Chamberlain JO, Robinson MH, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. Nov. 30. 1996;348(9040):1472-7. [pmid: 8942775].
143 Holme O, Loberg M, Kalager M, et al. Effect of flexible sigmoidoscopy screening on colorectal cancer incidence and mortality: A randomized clinical trial. JAMA. Aug. 13. 2014;312(6):606-15. [pmid: 25117129].
144 Kewenter J, Brevinge H, Engaras B, et al. Results of screening, rescreening, and follow-up in a prospective randomized study for detection of colorectal cancer by fecal occult blood testing. Results for 68,308 subjects. Scand J Gastroenterol. May. 1994;29(5):468-73. [pmid: 8036464].
145 Malila N, Oivanen T, Malminiemi O, et al. Test, episode, and programme sensitivities of screening for colorectal cancer as a public health policy in Finland: experimental design. BMJ. 2008;337:a2261. [pmid: 19022840].
146 Mandel JS, Church TR, Bond JH, et al. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. Nov. 30. 2000;343(22):1603-7. [pmid: 11096167].
147 Mandel JS, Bond JH, Church TR, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. May. 13. 1993;328(19):1365-71. [pmid: 8474513].
148 Parra-Blanco A, Nicolas-Perez D, Gimeno-Garcia A, et al. The timing of bowel preparation before colonoscopy determines the quality of cleansing, and is a significant factor contributing to the detection of flat lesions: a randomized study. World J Gastroenterol. Oct. 14. 2006;12(38):6161-6. [pmid: 17036388].
149 Segnan N, Senore C, Andreoni B, et al. Baseline findings of the Italian multicenter randomized controlled trial of “once-only sigmoidoscopy”--SCORE. J Natl Cancer Inst. Dec. 4. 2002;94(23):1763-72. [pmid: 12464648].
150 Thomas W, White CM, Mah J, et al. Longitudinal compliance with annual screening for fecal occult blood. Minnesota Colon Cancer Control Study. Am J Epidemiol. Jul. 15. 1995;142(2):176-82. [pmid: 7598117].
151 UK Flexible Sigmoidoscopy Screening Trial Investigators. Single flexible sigmoidoscopy screening to prevent colorectal cancer: baseline findings of a UK multicentre randomised trial. Lancet. 2002;359(9314):1291-300. Apr. 13. [pmid: 11965274].
152 van Roon AH, Wilschut JA, Hol L, et al. Diagnostic yield improves with collection of 2 samples in fecal immunochemical test screening without affecting attendance. Clinical Gastroenterology & Hepatology. Apr. 2011;9(4):333-9. [pmid: 21185397].
153 van DL, de Wijkerslooth TR, de Haan MC, et al. Time requirements and health effects of participation in colorectal cancer screening with colonoscopy or computed tomography colonography in a randomized controlled trial. Eur J Radiol. 2013;45(3):182-8. [pmid: 23446667].
154 Weissfeld JL, Schoen RE, Pinsky PF, et al. Flexible sigmoidoscopy in the PLCO cancer screening trial: results from the baseline screening examination of a randomized trial. J Natl Cancer Inst. Jul. 6. 2005;97(13):989-97. [pmid: 15998952].
155 Allison JE, Sakoda LC, Levin TR, et al. Screening for colorectal neoplasms with new fecal occult blood tests: update on performance characteristics. J Natl Cancer Inst. Oct. 3. 2007;99(19):1462-70. [pmid: 17895475].
156 Allison JE, Tekawa IS, Ransom LJ, et al. A comparison of fecal occult-blood tests for colorectal-cancer screening. N Engl J Med. Jan. 18. 1996;334(3):155-9. [pmid: 8531970].
157 Brenner H, Tao S. Superior diagnostic performance of faecal immunochemical tests for haemoglobin in a head-to-head comparison with guaiac based faecal occult blood test among 2235 participants of screening colonoscopy. European Journal of Cancer. Sep. 2013;49(14):3049-54. [pmid: 23706981].
158 Castiglione G, Visioli CB, Ciatto S, et al. Sensitivity of latex agglutination faecal occult blood test in the Florence District population-based colorectal cancer screening programme. Br J Cancer. Jun. 4. 2007;96(11):1750-4. [pmid: 17453007].
159 Chen LS, Yen AM, Chiu SY, et al. Baseline faecal occult blood concentration as a predictor of incident colorectal neoplasia: longitudinal follow-up of a Taiwanese population-based colorectal cancer screening cohort. Lancet Oncology. Jun. 2011;12(6):551-8. [pmid: 21592859].
160 Cheng TI, Wong JM, Hong CF, et al. Colorectal cancer screening in asymptomaic adults: comparison of colonoscopy, sigmoidoscopy and fecal occult blood tests. J Formos Med Assoc. Oct. 2002;101(10):685-90. [pmid: 12517041].
161 Chiang TH, Chuang SL, Chen SL, et al. Difference in performance of fecal immunochemical tests with the same hemoglobin cutoff concentration in a nationwide colorectal cancer screening program. Gastroenterology. Dec. 2014;147(6):1317-26. [pmid: 25200099].
162 Chiu HM, Lee YC, Tu CH, et al. Association between early stage colon neoplasms and false-negative results from the fecal immunochemical test. Clinical Gastroenterology & Hepatology. Jul. 2013;11(7):832-8. [pmid: 23376002].
163 Church TR, Wandell M, Lofton-Day C, et al. Prospective evaluation of methylated SEPT9 in plasma for detection of asymptomatic colorectal cancer. Gut. Feb. 2014;63(2):317-25. [pmid: 23408352].
164 de Wijkerslooth TR, Stoop EM, Bossuyt PM, et al. Immunochemical fecal occult blood testing is equally sensitive for proximal and distal advanced neoplasia. Am J Gastroenterol. Oct. 2012;107(10):1570-8. [pmid: 22850431].
165 Fletcher JG, Silva AC, Fidler JL, et al. Noncathartic CT colonography: Image quality assessment and performance and in a screening cohort. Am J Roentgenol. 2013;201(4):787-94. [pmid: 24059367].
166 Hernandez V, Cubiella J, Gonzalez-Mao MC, et al. Fecal immunochemical test accuracy in average-risk colorectal cancer screening. World Journal of Gastroenterology. Jan. 28. 2014;20(4):1038-47. [pmid: 24574776].
167 Imperiale TF, Ransohoff DF, Itzkowitz SH, et al. Multitarget Stool DNA Testing for Colorectal-Cancer Screening. N Engl J Med. Mar. 19. 2014;370(14):1287-97. [pmid: 24645800].
168 Itoh M, Takahashi K, Nishida H, et al. Estimation of the optimal cut off point in a new immunological faecal occult blood test in a corporate colorectal cancer screening programme. J Med Screen. 1996;3(2):66-71. [pmid: 8849762].
169 Johnson CD, Fletcher JG, MacCarty RL, et al. Effect of slice thickness and primary 2D versus 3D virtual dissection on colorectal lesion detection at CT colonography in 452 asymptomatic adults. AJR American journal of roentgenology. Sep. 2007;189(3):672-80. [pmid: 17715116].
170 Kim YS, Kim N, Kim SH, et al. The efficacy of intravenous contrast-enhanced 16-raw multidetector CT colonography for detecting patients with colorectal polyps in an asymptomatic population in Korea. Journal of Clinical Gastroenterology. Aug. 2008;42(7):791-8. [pmid: 18580500].
171 Launoy GD, Bertrand HJ, Berchi C, et al. Evaluation of an immunochemical fecal occult blood test with automated reading in screening for colorectal cancer in a general average-risk population. International Journal of Cancer. Jun. 20. 2005;115(3):493-6. [pmid: 15700317].
172 Lee YH, Hur M, Kim H, et al. Optimal cut-off concentration for a faecal immunochemical test for haemoglobin by Hemo Techt NS-Plus C15 system for the colorectal cancer screening. Clin Chem Lab Med. 2014. Aug. 15. [pmid: 25153599].
173 Levi Z, Birkenfeld S, Vilkin A, et al. A higher detection rate for colorectal cancer and advanced adenomatous polyp for screening with immunochemical fecal occult blood test than guaiac fecal occult blood test, despite lower compliance rate. A prospective, controlled, feasibility study. International Journal of Cancer. May. 15. 2011;128(10):2415-24. [pmid: 20658527].
174 Levy BT, Bay C, Xu Y, et al. Test Characteristics of Faecal Immunochemical Tests (FIT) Compared with Optical Colonoscopy. J Med Screen. Jun. 23. 2014;21(3):133-43. [pmid: 24958730].
175 Lin JS, Webber EM, Beil TL, et al. Fecal DNA Testing in Screening for Colorectal Cancer in Average-Risk Adults. 12-EHC022-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2012. [pmid: 22457883].
176 Macari M, Bini EJ, Jacobs SL, et al. Colorectal polyps and cancers in asymptomatic average-risk patients: evaluation with CT colonography. Radiology. Mar. 2004;230(3):629-36. [pmid: 14739311].
177 Morikawa T, Kato J, Yamaji Y, et al. A comparison of the immunochemical fecal occult blood test and total colonoscopy in the asymptomatic population. Gastroenterology. Aug. 2005;129(2):422-8. [pmid: 16083699].
178 Nakama H, Yamamoto M, Kamijo N, et al. Colonoscopic evaluation of immunochemical fecal occult blood test for detection of colorectal neoplasia. Hepatogastroenterology. Jan. 1999;46(25):228-31. [pmid: 10228797].
179 Nakama H, Kamijo N, Abdul Fattah AS, et al. Sensitivity of immunochemical fecal occult blood test to small colorectal adenomas. Journal of Medical Screening. 1996;3(2):63-5. [pmid: 8849761].
180 Ng SC, Ching JY, Chan V, et al. Diagnostic accuracy of faecal immunochemical test for screening individuals with a family history of colorectal cancer. Alimentary Pharmacology & Therapeutics. Oct. 2013;38(7):835-41. [pmid: 23957462].
181 Park DI, Ryu S, Kim YH, et al. Comparison of guaiac-based and quantitative immunochemical fecal occult blood testing in a population at average risk undergoing colorectal cancer screening. Am J Gastroenterol. Sep. 2010;105(9):2017-25. [pmid: 20502450].
182 Sohn DK, Jeong SY, Choi HS, et al. Single immunochemical fecal occult blood test for detection of colorectal neoplasia. Cancer Res Treat. Feb. 2005;37(1):20-3. [pmid: 19956505].
183 Zalis ME, Blake MA, Cai W, et al. Diagnostic accuracy of laxative-free computed tomographic colonography for detection of adenomatous polyps in asymptomatic adults: a prospective evaluation. Ann Intern Med. May. 15. 2012;156(10):692-702. [pmid: 22586008].
184 Cologaurd summary of safety and effectiveness data (SSED). 2014.
185 Ahlquist DA, Sargent DJ, Loprinzi CL, et al. Stool DNA and occult blood testing for screen detection of colorectal neoplasia. Ann Intern Med. 2008;149(7):441-50. [pmid: 18838724].
186 Brenner H, Haug U, Hundt S. Inter-test agreement and quantitative cross-validation of immunochromatographical fecal occult blood tests. International Journal of Cancer. Oct. 1. 2010;127(7):1643-9. [pmid: 20049840].
187 Brenner H, Haug U, Hundt S. Sex differences in performance of fecal occult blood testing. Am J Gastroenterol. Nov. 2010;105(11):2457-64. [pmid: 20700114].
188 Grazzini G, Castiglione G, Ciabattoni C, et al. Colorectal cancer screening programme by faecal occult blood test in Tuscany: first round results. Eur J Cancer Prev. Feb. 2004;13(1):19-26. [pmid: 15075784].
189 Haug U, Kuntz KM, Knudsen AB, et al. Sensitivity of immunochemical faecal occult blood testing for detecting left- vs right-sided colorectal neoplasia. British Journal of Cancer. May. 24. 2011;104(11):1779-85. [pmid: 21559011].
190 Haug U, Hillebrand T, Bendzko P, et al. Mutant-enriched PCR and allele-specific hybridization reaction to detect K-ras mutations in stool DNA: high prevalence in a large sample of older adults. Clin Chem. Apr. 2007;53(4):787-90. [pmid: 17317884].
191 Hundt S, Haug U, Brenner H. Comparative evaluation of immunochemical fecal occult blood tests for colorectal adenoma detection. Ann Intern Med. Feb. 3. 2009;150(3):162-9. [pmid: 19189905].
192 Imperiale TF, Ransohoff DF, Itzkowitz SH, et al. Fecal DNA versus fecal occult blood for colorectal-cancer screening in an average-risk population. N Engl J Med. Dec. 23. 2004;351(26):2704-14. [pmid: 15616205].
193 Johnson CD, Herman BA, Chen MH, et al. The National CT Colonography Trial: assessment of accuracy in participants 65 years of age and older. Radiology. May. 2012;263(2):401-8. [pmid: 22361006].
194 Morikawa T, Kato J, Yamaji Y, et al. Sensitivity of immunochemical fecal occult blood test to small colorectal adenomas. Am J Gastroenterol. Oct. 2007;102(10):2259-64. [pmid: 17617203].
195 Anderson JC, Alpern Z, Messina CR, et al. Predictors of proximal neoplasia in patients without distal adenomatous pathology. Am J Gastroenterol. Mar. 2004;99(3):472-7. [pmid: 15056088].
196 Lieberman DA, Weiss DG, Bond JH, et al. Use of colonoscopy to screen asymptomatic adults for colorectal cancer. Veterans Affairs Cooperative Study Group 380. N Engl J Med. Jul. 20. 2000;343(3):162-8. [pmid: 10900274].
197 Schoenfeld P, Cash B, Flood A, et al. Colonoscopic screening of average-risk women for colorectal neoplasia. N Engl J Med. May. 2005;352(20):2061-8. [pmid: 15901859].
198 Schoenfeld P, Lipscomb S, Crook J, et al. Accuracy of polyp detection by gastroenterologists and nurse endoscopists during flexible sigmoidoscopy: a randomized trial. Gastroenterology. Aug. 1999;117(2):312-8. [pmid: 10419911].
199 Schoen RE, Pinsky PF, Weissfeld JL, et al. Results of repeat sigmoidoscopy 3 years after a negative examination. JAMA. Jul. 2. 2003;290(1):41-8. [pmid: 12837710].
200 Burke CA, Elder K, Lopez R. Screening for colorectal cancer with flexible sigmoidoscopy: is a 5-yr interval appropriate? A comparison of the detection of neoplasia 3 yr versus 5 yr after a normal examination. Am J Gastroenterol. Jun. 2006;101(6):1329-32. [pmid: 16771957].
201 Betes-Ibanez M, Munoz-Navas MA, Duque JM, et al. Diagnostic value of distal colonic polyps for prediction of advanced proximal neoplasia in an average-risk population undergoing screening colonoscopy. Gastrointest Endosc. May. 2004;59(6):634-41. [pmid: 15114305].
202 Ikeda Y, Mori M, Miyazaki M, et al. Significance of small distal adenoma for detection of proximal neoplasms in the colorectum. Gastrointest Endosc. Sep. 2000;52(3):358-61. [pmid: 10968850].
203 Imperiale TF, Wagner DR, Lin CY, et al. Using risk for advanced proximal colonic neoplasia to tailor endoscopic screening for colorectal cancer. Ann Intern Med. Dec. 16. 2003;139(12):959-65. [pmid: 14678915].
204 Macari M, Milano A, Lavelle M, et al. Comparison of time-efficient CT colonography with two- and three-dimensional colonic evaluation for detecting colorectal polyps. AJR Am J Roentgenol. Jun. 2000;174(6):1543-9. [pmid: 10845478].
205 Rex DK, Vining D, Kopecky KK. An initial experience with screening for colon polyps using spiral CT with and without CT colography (virtual colonoscopy). Gastrointest Endosc. Sep. 1999;50(3):309-13. [pmid: 10462648].
206 Levi Z, Rozen P, Hazazi R, et al. A quantitative immunochemical fecal occult blood test for colorectal neoplasia. Ann Intern Med. Feb. 20. 2007;146(4):244-55. [pmid: 17310048].
207 Johnson DA. Can Cologuard Improve Colon Cancer Screening Rates. Medscape. 2014.
208 Imperiale TF, Ransohoff DF, Itzkowitz SH. Multitarget stool DNA testing for colorectal-cancer screening. N Engl J Med. Jul. 10. 2014;371(2):187-8. PMID:. [doi: 10.1056/NEJMc1405215]. [pmid: 25006736].
209 Adeyemo A, Bannazadeh M, Riggs T, et al. Does sedation type affect colonoscopy perforation rates?. Diseases of the Colon & Rectum. Jan. 2014;57(1):110-4. [pmid: 24316954].
210 Adler A, Wegscheider K, Lieberman D, et al. Factors determining the quality of screening colonoscopy: a prospective study on adenoma detection rates, from 12,134 examinations (Berlin colonoscopy project 3, BECOP-3). Gut. Feb. 2013;62(2):236-41. [pmid: 22442161].
211 An S, Lee KH, Kim YH, et al. Screening CT colonography in an asymptomatic average-risk Asian population: a 2-year experience in a single institution. AJR. Sep. American. 2008;(3):W100-W106. [pmid: 18716076].
212 Arora G, Mannalithara A, Singh G, et al. Risk of perforation from a colonoscopy in adults: a large population-based study. Gastrointest Endosc. Mar. 2009;69(3:Pt 2):t-64. [pmid: 19251006].
213 Bair D, Pham J, Seaton MB, et al. The quality of screening colonoscopies in an office-based endoscopy clinic. Canadian Journal of Gastroenterology. Jan. 2009;23(1):41-7. [pmid: 19172208].
214 Berhane C, Denning D. Incidental finding of colorectal cancer in screening colonoscopy and its cost effectiveness. American Surgeon. 2009;75(8):699-703. [pmid: 19725293].
215 Bielawska B, Day AG, Lieberman DA, et al. Risk factors for early colonoscopic perforation include non-gastroenterologist endoscopists: a multivariable analysis. Clinical Gastroenterology & Hepatology. Jan. 2014;12(1):85-92. [pmid: 23891916].
216 Blotiere PO, Weill A, Ricordeau P, et al. Perforations and haemorrhages after colonoscopy in 2010: A study based on comprehensive French health insurance data (SNIIRAM). Clin Res Hepatol Gastroenterol. 2014;38(1):112-7. [pmid: 24268997].
217 Bokemeyer B, Bock H, Huppe D, et al. Screening colonoscopy for colorectal cancer prevention: results from a German online registry on 269000 cases. European Journal of Gastroenterology & Hepatology. Jun. 2009;21(6):650-5. [pmid: 19445041].
218 Cash BD, Riddle MS, Bhattacharya I, et al. CT colonography of a Medicare-aged population: outcomes observed in an analysis of more than 1400 patients. AJR. Jul. American. 2012;(1):W27-W34. [pmid: 22733929].
219 Castro G, Azrak MF, Seeff LC, et al. Outpatient colonoscopy complications in the CDC’s Colorectal Cancer Screening Demonstration Program: a prospective analysis. Cancer. Aug. 1. 2013;119:Suppl-54. [pmid: 23868479].
220 Chin M, Mendelson R, Edwards J, et al. Computed tomographic colonography: prevalence, nature, and clinical significance of extracolonic findings in a community screening program. Am J Gastroenterol. Dec. 2005;100(12):2771-6. [pmid: 16393234].
221 Chukmaitov A, Bradley CJ, Dahman B, et al. Association of polypectomy techniques, endoscopist volume, and facility type with colonoscopy complications. Gastrointest Endosc. Mar. 2013;77(3):436-46. [pmid: 23290773].
222 Cooper GS, Kou TD, Rex DK. Complications following colonoscopy with anesthesia assistance: a population-based analysis. JAMA Internal Medicine. Apr. 8. 2013;173(7):551-6. [pmid: 23478904].
223 Cotterill M, Gasparelli R, Kirby E. Colorectal cancer detection in a rural community. Development of a colonoscopy screening program. Can Fam Physician. Sep. 2005;51:1224-8. [pmid: 16190175].
224 Crispin A, Birkner B, Munte A, et al. Process quality and incidence of acute complications in a series of more than 230,000 outpatient colonoscopies. Eur J Radiol. Dec. 2009;41(12):1018-25. [pmid: 19856246].
225 Dancourt V, Lejeune C, Lepage C, et al. Immunochemical faecal occult blood tests are superior to guaiac-based tests for the detection of colorectal neoplasms. European Journal of Cancer. Oct. 2008;44(15):2254-8. [pmid: 18760592].
226 Dominitz JA, Baldwin LM, Green P, et al. Regional variation in anesthesia assistance during outpatient colonoscopy is not associated with differences in polyp detection or complication rates. Gastroenterology. Feb. 2013;144(2):298-306. [pmid: 23103615].
227 Durbin JM, Stroup SP, Altamar HO, et al. Genitourinary abnormalities in an asymptomatic screening population: findings on virtual colonoscopy. Clinical Nephrology. Mar. 2012;77(3):204-10. [pmid: 22377251].
228 Edwards JT, Mendelson RM, Fritschi L, et al. Colorectal neoplasia screening with CT colonography in average-risk asymptomatic subjects: community-based study. Radiology. 2004;230(2):459-64. Feb. [pmid: 14688402].
229 Flicker MS, Tsoukas AT, Hazra A, et al. Economic impact of extracolonic findings at computed tomographic colonography. Journal of Computer Assisted Tomography. Jul. 2008;32(4):497-503. [pmid: 18664832].
230 Ginnerup PB, Rosenkilde M, Christiansen TE, et al. Extracolonic findings at computed tomography colonography are a challenge. Gut. Dec. 2003;52(12):1744-7. [pmid: 14633954].
231 Gluecker TM, Johnson CD, Wilson LA, et al. Extracolonic findings at CT colonography: evaluation of prevalence and cost in a screening population. Gastroenterology. Apr. 2003;124(4):911-6. [pmid: 12671887].
232 Hamdani U, Naeem R, Haider F, et al. Risk factors for colonoscopic perforation: a population-based study of 80118 cases. World Journal of Gastroenterology. Jun. 21. 2013;19(23):3596-601. [pmid: 23801860].
233 Hara AK, Johnson CD, MacCarty RL, et al. Incidental Extracolonic Findings at CT Colonography. Radiology. May. 1. 2000;215(2):353-7. [pmid: 10796907].
234 Ho JM, Gruneir A, Fischer HD, et al. Serious events in older Ontario residents receiving bowel preparations for outpatient colonoscopy with various comorbidity profiles: a descriptive, population-based study. Can J Gastroenterol. Jul. 2012;26(7):436-40. [pmid: 22803018].
235 Hoff G, Thiis-Evensen E, Grotmol T, et al. Do undesirable effects of screening affect all-cause mortality in flexible sigmoidoscopy programmes? Experience from the Telemark Polyp Study 1983–1996. Eur J Cancer Prev. Apr. 2001;10(2):131-7. [pmid: 11330453].
236 Hsieh TK, Hung L, Kang FC, et al. Anesthesia does not increase the rate of bowel perforation during colonoscopy: a retrospective study. Acta Anaesthesiologica Taiwanica: Official Journal of the Taiwan Society of Anesthesiologists. Dec. 2009;47(4):162-6. [pmid: 20015815].
237 Iafrate F, Iussich G, Correale L, et al. Adverse events of computed tomography colonography: an Italian National Survey. Digestive & Liver Disease. Aug. 2013;45(8):645-50. [pmid: 23643567].
238 Jain A, Falzarano J, Jain A, et al. Outcome of 5,000 flexible sigmoidoscopies done by nurse endoscopists for colorectal screening in asymptomatic patients. Hawaii Med J. Jun. 2002;61(6):118-20. [pmid: 12148407].
239 Kamath AS, Iqbal CW, Sarr MG, et al. Colonoscopic splenic injuries: incidence and management. Journal of Gastrointestinal Surgery. Dec. 2009;13(12):2136-40. [pmid: 19830501].
240 Kang HY, Kang HW, Kim SG, et al. Incidence and management of colonoscopic perforations in Korea. Digestion. 2008;78(4):218-23. [pmid: 19142003].
241 Kao KT, Jain A, Sheinbaum A. Ischemic colitis following routine screening colonoscopy: a case report. Eur J Radiol. 2009;41:Suppl. [pmid: 19418419].
242 Kim DH, Pickhardt PJ, Taylor AJ, et al. CT colonography versus colonoscopy for the detection of advanced neoplasia. N Engl J Med. Oct. 4. 2007;357(14):1403-12. [pmid: 17914041].
243 Kim JS, Kim BW, Kim JI, et al. Endoscopic clip closure versus surgery for the treatment of iatrogenic colon perforations developed during diagnostic colonoscopy: a review of 115,285 patients. Surgical Endoscopy. Feb. 2013;27(2):501-4. [pmid: 22773239].
244 Kim YS, Kim N, Kim SY, et al. Extracolonic findings in an asymptomatic screening population undergoing intravenous contrast-enhanced computed tomography colonography. Journal of Gastroenterology & Hepatology. Jul. 2008;23(7:Pt 2):t-57. [pmid: 17645481].
245 Ko CW, Riffle S, Michaels L, et al. Serious complications within 30 days of screening and surveillance colonoscopy are uncommon. Clinical Gastroenterology & Hepatology. Feb. 2010;8(2):166-73. [pmid: 19850154].
246 Ko CW, Riffle S, Shapiro JA, et al. Incidence of minor complications and time lost from normal activities after screening or surveillance colonoscopy. Gastrointest Endosc. 2007;65(4):648-56. [pmid: 17173914].
247 Korman LY, Overholt BF, Box T, et al. Perforation during colonoscopy in endoscopic ambulatory surgical centers. Gastrointestinal Endoscopy. 2003;58(4):554-7. Oct. [pmid: 14520289].
248 Layton JB, Klemmer PJ, Christiansen CF, et al. Sodium Phosphate Does Not Increase Risk For Acute Kidney Injury After Routine Colonoscopy, Compared With Polyethylene Glycol. Clin Gastroenterol Hepatol. Jan. 29. 2014;12(9):1514-21. [pmid: 24486407].
249 Levin TR, Zhao W, Conell C, et al. Complications of colonoscopy in an integrated health care delivery system. Annals of Internal Medicine. 2006;145(12):880-6. Dec. [pmid: 17179057].
250 Levin TR, Conell C, Shapiro JA, et al. Complications of screening flexible sigmoidoscopy. Gastroenterology. 2002;123(6):1786-92. Dec. [pmid: 12454834].
251 Loffeld RJ, Engel A, Dekkers PE. Incidence and causes of colonoscopic perforations: a single-center case series. Eur J Radiol. Mar. 2011;43(3):240-2. [pmid: 21165826].
252 Lorenzo-Zuniga V, Moreno dVV, Domenech E, et al. Endoscopist experience as a risk factor for colonoscopic complications. Colorectal Disease. Oct. 2010;12(10:Online):Online-7. [pmid: 19930145].
253 Macari M, Nevsky G, Bonavita J, et al. CT colonography in senior versus nonsenior patients: extracolonic findings, recommendations for additional imaging, and polyp prevalence. Radiology. Jun. 2011;259(3):767-74. [pmid: 21467252].
254 Mansmann U, Crispin A, Henschel V, et al. Epidemiology and quality control of 245 000 outpatient colonoscopies. Deutsches Arzteblatt International. Jun. 2008;105(24):434-40. [pmid: 19626186].
255 Multicentre Austrailian Colorectal-neoplasia Screening (MACS) Group. A comparison of colorectal neoplasia screening tests: a multicentre community-based study of the impact of consumer choice. Med J Aust. Jun. 5. 2006;184(11):546-50. [pmid: 16768659].
256 Nelson DB, McQuaid KR, Bond JH, et al. Procedural success and complications of large-scale screening colonoscopy. Gastrointestinal Endoscopy. 2002;55(3):307-14. Mar. [pmid: 11868001].
257 O’Connor SD, Pickhardt PJ, Kim DH, et al. Incidental finding of renal masses at unenhanced CT: prevalence and analysis of features for guiding management. AJR. Jul. American. 2011;(1):139-45. [pmid: 21701022].
258 Parente F, Boemo C, Ardizzoia A, et al. Outcomes and cost evaluation of the first two rounds of a colorectal cancer screening program based on immunochemical fecal occult blood test in northern Italy. Eur J Radiol. 2013;45(1):27-34. [pmid: 23254404].
259 Pickhardt PJ, Boyce CJ, Kim DH, et al. Should small sliding hiatal hernias be reported at CT colonography?. AJR. Apr. American. 2011;(4):W400-W404. [pmid: 21427303].
260 Pickhardt PJ, Kim DH, Meiners RJ, et al. Colorectal and extracolonic cancers detected at screening CT colonography in 10,286 asymptomatic adults. Radiology. Apr. 2010;255(1):83-8. [pmid: 20308446].
261 Pickhardt PJ, Kim DH, Taylor AJ, et al. Extracolonic tumors of the gastrointestinal tract detected incidentally at screening CT colonography. Dis Colon Rectum. Jan. 2007;50(1):56-63. [pmid: 17115333].
262 Pickhardt PJ. Incidence of colonic perforation at CT colonography: review of existing data and implications for screening of asymptomatic adults. Radiology. 2006;239(2):313-6. May. [pmid: 16641348].
263 Pox CP, Altenhofen L, Brenner H, et al. Efficacy of a nationwide screening colonoscopy program for colorectal cancer. Gastroenterology. Jun. 2012;142(7):1460-7. [pmid: 22446606].
264 Quallick MR, Brown WR. Rectal perforation during colonoscopic retroflexion: a large, prospective experience in an academic center. Gastrointest Endosc. Apr. 2009;69(4):960-3. [pmid: 19327487].
265 Rabeneck L, Paszat LF, Hilsden RJ, et al. Bleeding and perforation after outpatient colonoscopy and their risk factors in usual clinical practice. Gastroenterology. 2008;135(6):1899-906. [pmid: 18938166].
266 Rathgaber SW, Wick TM. Colonoscopy completion and complication rates in a community gastroenterology practice. Gastrointestinal Endoscopy. 2006;64(4):556-62. Oct. [pmid: 16996349].
267 Rutter CM, Johnson E, Miglioretti DL, et al. Adverse events after screening and follow-up colonoscopy. Cancer Causes & Control. Feb. 2012;23(2):289-96. [pmid: 22105578].
268 Sagawa T, Kakizaki S, Iizuka H, et al. Analysis of colonoscopic perforations at a local clinic and a tertiary hospital. World Journal of Gastroenterology. Sep. 21. 2012;18(35):4898-904. [pmid: 23002362].
269 Senore C, Ederle A, Fantin A, et al. Acceptability and side-effects of colonoscopy and sigmoidoscopy in a screening setting. Journal of Medical Screening. 2011;18(3):128-34. [pmid: 22045821].
270 Sieg A, Hachmoeller-Eisenbach U, Eisenbach T. Prospective evaluation of complications in outpatient GI endoscopy: a survey among German gastroenterologists. Gastrointest Endosc. May. 2001;53(6):620-7. [pmid: 11323588].
271 Singh H, Penfold RB, DeCoster C, et al. Colonoscopy and its complications across a Canadian regional health authority. Gastrointest Endosc. Mar. 2009;69(3:Pt 2):t-71. [pmid: 19251007].
272 Sosna J, Blachar A, Amitai M, et al. Colonic perforation at CT colonography: assessment of risk in a multicenter large cohort. Radiology. May. 2006;239(2):457-63. [pmid: 16543590].
273 Stock C, Ihle P, Sieg A, et al. Adverse events requiring hospitalization within 30 days after outpatient screening and nonscreening colonoscopies. Gastrointest Endosc. Mar. 2013;77(3):419-29. [pmid: 23410698].
274 Strul H, Kariv R, Leshno M, et al. The prevalence rate and anatomic location of colorectal adenoma and cancer detected by colonoscopy in average-risk individuals aged 40–80 years. Am J Gastroenterol. Feb. 2006;101(2):255-62. [pmid: 16454827].
275 Suissa A, Bentur OS, Lachter J, et al. Outcome and complications of colonoscopy: a prospective multicenter study in northern Israel. Diagnostic & Therapeutic Endoscopy. 2012;2012:612542. [pmid: 22778539].
276 Tam MS, Abbas MA. Perforation following colorectal endoscopy: what happens beyond the endoscopy suite?. Perm J. 2013;17(2):17-21. [pmid: 23704838].
277 Veerappan GR, Ally MR, Choi JH, et al. Extracolonic findings on CT colonography increases yield of colorectal cancer screening. AJR. Sep. American. 2010;(3):677-86. [pmid: 20729446].
278 Viiala CH, Olynyk JK. Outcomes after 10 years of a community-based flexible sigmoidoscopy screening program for colorectal carcinoma. Med J Aust. Sep. 3. 2007;187(5):274-7. [pmid: 17767431].
279 Wallace MB, Kemp JA, Meyer F, et al. Screening for colorectal cancer with flexible sigmoidoscopy by nonphysician endoscopists. Am J Med. Sep. 1999;107(3):214-8. [pmid: 10492313].
280 Warren JL, Klabunde CN, Mariotto AB, et al. Adverse events after outpatient colonoscopy in the Medicare population. Ann Intern Med. 2009;150(12):849-57. [pmid: 19528563].
281 Xirasagar S, Hurley TG, Sros L, et al. Screening colonoscopy vs flexible sigmoidoscopy. Medical Care. Aug. 2010;48(8):703-9. [pmid: 20613663].
282 Zafar HM, Harhay MO, Yang J, et al. Adverse events Following Computed Tomographic Colonography compared to Optical Colonoscopy in the Elderly. Prev Med Rep. 2014;1:3-8. [pmid: 25530940].
283 Gondal G, Grotmol T, Hofstad B, et al. The Norwegian Colorectal Cancer Prevention (NORCCAP) screening study: baseline findings and implementations for clinical work-up in age groups 50–64 years. Scandinavian Journal of Gastroenterology. 2003;38(6):635-42. Jun. [pmid: 12825872].
284 Hoff G, Grotmol T, Skovlund E, et al. Risk of colorectal cancer seven years after flexible sigmoidoscopy screening: randomised controlled trial. BMJ. 2009;338:b1846. [pmid: 19483252].
285 Kim DH, Pickhardt PJ, Hanson ME, et al. CT colonography: performance and program outcome measures in an older screening population. Radiology. Feb. 2010;254(2):493-500. [pmid: 20093521].
286 Miles A, Wardle J, McCaffery K, et al. The effects of colorectal cancer screening on health attitudes and practices. Cancer Epidemiol Biomarkers Prev. Jul. 2003;12(7):651-5. [pmid: 12869406].
287 Pickhardt PJ, Kim DH, Robbins JB. Flat (nonpolypoid) colorectal lesions identified at CT colonography in a U.S. screening population. Academic Radiology. Jun. 2010;17(6):784-90. [pmid: 20227304].
288 Pickhardt PJ, Hanson ME, Vanness DJ, et al. Unsuspected extracolonic findings at screening CT colonography: clinical and economic impact. Radiology. Oct. 2008;249(1):151-9. [pmid: 18796673].
289 Regula J, Polkowski M. CT colonography versus colonoscopy for the detection of advanced neoplasia. N Engl J Med. 2008;358(1):88-9. [pmid: 18175382].
290 Atkin WS, Hart A, Edwards R, et al. Uptake, yield of neoplasia, and adverse effects of flexible sigmoidoscopy screening. Gut. Apr. 1998;42(4):560-5. [pmid: 9616321].
291 Ko CW, Riffle S, Shapiro JA, et al. Incidence of minor complications and time lost from normal activities after screening or surveillance colonoscopy. Gastrointest Endosc. 2006. Dec. 13. [pmid: 17173914].
292 Boellaard TN, Venema HW, Streekstra GJ, et al. Effective radiation dose in CT colonography: is there a downward trend?. Acad Radiol. Sep. 2012;19(9):1127-33. [pmid: 22750132].
293 Jensch S, van Gelder RE, Venema HW, et al. Effective radiation doses in CT colonography: results of an inventory among research institutions. European Radiology. May. 2006;16(5):981-7. [pmid: 16418863].
294 van Gelder RE, Venema HW, Serlie IW, et al. CT colonography at different radiation dose levels: feasibility of dose reduction. Radiology. Jul. 2002;224(1):25-33. [pmid: 12091658].
295 Zalis ME, Barish MA, Choi JR, et al. CT colonography reporting and data system: a consensus proposal. Radiology. Jul. 2005;236(1):3-9. [pmid: 15987959].
296 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials?. Ann Intern Med. Jun. 6. 2006;144(11):850-5. [pmid: 16754927].
297 Hewitson P, Glasziou P, Irwig L, et al. Screening for colorectal cancer using the faecal occult blood test, Hemoccult. Cochrane Database of Systematic Reviews. 2007;(1):CD001216. [pmid: 17253456].
298 California Colorectal Cancer Coalition, American Cancer Society, Operation Access. Improving Access to Colorectal Cancer Screening, Diagnosis, and Treatment in Underserved Communities. 2011.
299 Florida Department of Health. Get the FIT Facts. 2015.
300 Kaiser Permanente Division of Research. 2012 Annual Report: Cancer. 2015.
301 Debarros M, Steele SR. Colorectal cancer screening in an equal access healthcare system. Journal of Cancer. 2013;4(3):270-80. [pmid: 23459768].
302 Department of Veterans Affairs. Colonoscopy Versus Fecal Immunochemical Test in Reducing Mortality From Colorectal Cancer (CONFIRM). 2014. https://clinicaltrials.gov/ct2/show/NCT01239082. Accessed December 15, 2014.
303 Vart G, Banzi R, Minozzi S. Comparing participation rates between immunochemical and guaiac faecal occult blood tests: a systematic review and meta-analysis. Preventive Medicine. Aug. 2012;55(2):87-92. [pmid: 22634386].
304 Mosen DM, Liles EG, Feldstein AC, et al. Participant uptake of the fecal immunochemical test decreases with the two-sample regimen compared with one-sample FIT. Eur J Cancer Prev. Nov. 2014;23(6):516-23. [pmid: 25203483].
305 Zheng S, Chen K, Liu X, et al. Cluster randomization trial of sequence mass screening for colorectal cancer. Dis Colon Rectum. Jan. 2003;46(1):51-8. [pmid: 12544522].
306 Lee JK, Liles EG, Bent S, et al. Accuracy of Fecal Immunochemical Tests for Colorectal Cancer Systematic Review and Meta-analysis. Ann Intern Med. Feb. 4. 2014;160(3):171-81. [pmid: 24658694].
307 Exact Sciences. Additional Update on CMS Reimbursement for Cologuard®. 2015.
308 Ladabaum U, Levin Z, Mannalithara A, et al. Colorectal testing utilization and payments in a large cohort of commercially insured US adults. Am J Gastroenterol. Oct. 2014;109(10):1513-25. [pmid: 24980877].
309 Robertson DJ, Dominitz JA. Stool DNA and colorectal-cancer screening. N Engl J Med. Apr. 3. 2014;370(14):1350-1. [pmid: 24645801].
310 Elmunzer BJ, Hayward RA, Schoenfeld PS, et al. Effect of flexible sigmoidoscopy-based screening on incidence and mortality of colorectal cancer: a systematic review and meta-analysis of randomized controlled trials. PLoS Medicine/Public Library of Science. 2012;9(12):e1001352. [pmid: 23226108].
311 Kaminski MF, Bretthauer M, Zauber AG, et al. The NordICC Study: rationale and design of a randomized trial on colonoscopy screening for colorectal cancer. Eur J Radiol. Jul. 2012;44(7):695-702. [pmid: 22723185].
312 Castells A, Quintero E. Programmatic Screening for Colorectal Cancer: The COLONPREV Study. Dig Dis Sci. 2014:1-9. [pmid: 25445162].
313 Alvarez C, Andreu M, Castells A, et al. Relationship of colonoscopy-detected serrated polyps with synchronous advanced neoplasia in average-risk individuals. Gastrointest Endosc. Aug. 2013;78(2):333-41. [pmid: 23623039].
314 Rex DK, Bond JH, Winawer S, et al. Quality in the technical performance of colonoscopy and the continuous quality improvement process for colonoscopy: recommendations of the U.S. Multi-Society Task Force on Colorectal Cancer. Am J Gastroenterol. Jun. 2002;97(6):1296-308. [pmid: 12094842].
315 Rex DK, Schoenfeld PS, Cohen J, et al. Quality indicators for colonoscopy. Gastrointest Endosc. Jan. 2015;81(1):31-53. [pmid: 25480100].
316 van Rijn JC, Reitsma JB, Stoker J, et al. Polyp miss rate determined by tandem colonoscopy: a systematic review. Am J Gastroenterol. Feb. 2006;101(2):343-50. [pmid: 16454841].
317 Leufkens AM, van Oijen MG, Vleggaar FP, et al. Factors influencing the miss rate of polyps in a back-to-back colonoscopy study. Eur J Radiol. May. 2012;44(5):470-5. [pmid: 22441756].
318 Gralnek IM, Siersema PD, Halpern Z, et al. Standard forward-viewing colonoscopy versus full-spectrum endoscopy: an international, multicentre, randomised, tandem colonoscopy trial. Lancet Oncology. Mar. 2014;15(3):353-60. [pmid: 24560453].
319 Siersema PD, Rastogi A, Leufkens AM, et al. Retrograde-viewing device improves adenoma detection rate in colonoscopies for surveillance and diagnostic workup. World Journal of Gastroenterology. Jul. 14. 2012;18(26):3400-8. [pmid: 22807609].
320 Kahi CJ, Anderson JC, Waxman I, et al. High-definition chromocolonoscopy vs. high-definition white light colonoscopy for average-risk colorectal cancer screening. Am J Gastroenterol. Jun. 2010;105(6):1301-7. [pmid: 20179689].
321 Ikematsu H, Saito Y, Tanaka S, et al. The impact of narrow band imaging for colon polyp detection: a multicenter randomized controlled trial by tandem colonoscopy. Journal of Gastroenterology. Oct. 2012;47(10):1099-107. [pmid: 22441532].
322 Singla S, Keller D, Thirunavukarasu P, et al. Splenic injury during colonoscopy--a complication that warrants urgent attention. Journal of Gastrointestinal Surgery. Jun. 2012;16(6):1225-34. [pmid: 22450952].
323 Patselas TN, Gallagher EG. Splenic rupture: an uncommon complication after colonoscopy. American Surgeon. Mar. 2009;75(3):260-1. [pmid: 19350865].
324 Langer K, Kriegler S, Moser M. Colonoscopy complicated by arterial avulsion and retroperitoneal hemorrhage. Eur J Radiol. 2011;43:Suppl. [pmid: 21590605].
325 Tagg W, Woods S, Razdan R, et al. Hemoperitoneum after colonoscopy. Eur J Radiol. Sep. 2008;40:Suppl-7. [pmid: 18633865].
326 Boenicke L, Maier M, Merger M, et al. Retroperitoneal gas gangrene after colonoscopic polypectomy without bowel perforation in an otherwise healthy individual: report of a case. Langenbecks Arch Surg. Apr. 2006;391(2):157-60. [pmid: 16465554].
327 Gladman MA, Shami SK. Medical mystery: an unusual complication of colonoscopy--the answer. N Engl J Med. Nov. 29. 2007;357(22):2309-10. [pmid: 18046038].
328 Lee CK, Shim JJ, Jang JY. Ceco-colic intussusception with subsequent bowel infarction as a rare complication of colonoscopic polypectomy. Eur J Radiol. 2013;45:Suppl-7. [pmid: 23526500].
329 Cheng YC, Wu CC, Lee CC, et al. Rare complication following screening colonoscopy: ischemic colitis. Digestive Endoscopy. Sep. 2012;24(5):379. [pmid: 22925295].
330 Lambert A, Nguyen SQ, Byrn JC, et al. Small-bowel perforation after colonoscopy. Gastrointest Endosc. Feb. 2007;65(2):352-3. [pmid: 17137862].
331 Ladas SD, Karamanolis G, Ben-Soussan E. Colonic gas explosion during therapeutic colonoscopy with electrocautery. World J Gastroenterol. Oct. 28. 2007;13(40):5295-8. [pmid: 17879396].
332 Shaw D, Gallardo G, Basson MD. Post-colonoscopy appendicitis: A case report and systematic review. World Journal of Gastrointestinal Surgery. Oct. 27. 2013;5(10):259-63. [pmid: 24179623].
333 Gonzalez-Candelas F, Guiral S, Carbo R, et al. Patient-to-patient transmission of hepatitis C virus (HCV) during colonoscopy diagnosis. Virology Journal. 2010;7:217. [pmid: 20825635].
334 Saludes V, Esteve M, Casas I, et al. Hepatitis C virus transmission during colonoscopy evidenced by phylogenetic analysis. Journal of Clinical Virology. Jul. 2013;57(3):263-6. [pmid: 23567025].
335 Colonoscopes may spread HCV and HPV. AIDS Patient Care STDS. May. 2003;17(5):257-8.
336 Fukunaga K, Khatibi A. Glutaraldehyde colitis: a complication of screening flexible sigmoidoscopy in the primary care setting. Ann Intern Med. Aug. 15. 2000;133(4):315. [pmid: 10929189].
337 Hookey LC, Depew WT, Vanner S. The safety profile of oral sodium phosphate for colonic cleansing before colonoscopy in adults. Gastrointest Endosc. Dec. 2002;56(6):895-902. [pmid: 12447305].
338 Rex DK, Schwartz H, Goldstein M, et al. Safety and colon-cleansing efficacy of a new residue-free formulation of sodium phosphate tablets. Am J Gastroenterol. Nov. 2006;101(11):2594-604. [pmid: 17029618].
339 Weir MA, Fleet JL, Vinden C, et al. Hyponatremia and sodium picosulfate bowel preparations in older adults. Am J Gastroenterol. May. 2014;109(5):686-94. [pmid: 24589671].
340 Tan JJ, Tjandra JJ. Which is the optimal bowel preparation for colonoscopy - a meta-analysis. Colorectal Dis. May. 2006;8(4):247-58. [pmid: 16630226].
341 Belsey J, Epstein O, Heresbach D. Systematic review: oral bowel preparation for colonoscopy. Aliment Pharmacol Ther. Feb. 15. 2007;25(4):373-84. [pmid: 17269992].
342 Clark RE, Godfrey JD, Choudhary A, et al. Low-volume polyethylene glycol and bisacodyl for bowel preparation prior to colonoscopy: a meta-analysis. Ann Gastroenterol. 2013;26(4):319-24. [pmid: 24714413].
343 Hammadah M, Gaber L, Raghavan R. Renal cortical necrosis following a colonoscopy. Clinical Nephrology. Jan. 2013;79(1):67-71. [pmid: 22913920].
344 Gonlusen G, Akgun H, Ertan A, et al. Renal failure and nephrocalcinosis associated with oral sodium phosphate bowel cleansing: clinical patterns and renal biopsy findings. Arch Pathol Lab Med. Jan. 2006;130(1):101-6. [pmid: 16390223].
345 Carl DE, Sica DA. Acute phosphate nephropathy following colonoscopy preparation. Am J Med Sci. Sep. 2007;334(3):151-4. [pmid: 17873526].
346 Yu JY, Kim SK, Jang EC, et al. Boerhaave’s syndrome during bowel preparation with polyethylene glycol in a patient with postpolypectomy bleeding. World Journal of Gastrointestinal Endoscopy. May. 16. 2013;5(5):270-2. [pmid: 23678383].
347 Nagler J, Poppers D, Turetz M. Severe hyponatremia and seizure following a polyethylene glycol-based bowel preparation for colonoscopy. J Clin Gastroenterol. Jul. 2006;40(6):558-9. [pmid: 16825941].
348 de Haan MC, van Gelder RE, Graser A, et al. Diagnostic value of CT-colonography as compared to colonoscopy in an asymptomatic screening population: a meta-analysis. European Radiology. Aug. 2011;21(8):1747-63. [pmid: 21455818].
349 McFarland EG, Fletcher JG, Pickhardt P, et al. ACR Colon Cancer Committee white paper: status of CT colonography 2009. Journal of the American College of Radiology. Nov. 2009;6(11):756-72. [pmid: 19878883].
350 Burling D, Wylie P, Gupta A, et al. CT colonography: accuracy of initial interpretation by radiographers in routine clinical practice. Clinical Radiology. Feb. 2010;65(2):126-32. [pmid: 20103434].
351 ACR-SAR-SCBT-MR Practice Parameter for the performance of computer tomography (CT) colonography in adults. 2014. http://www.acr.org/~/media/ACR/Documents/PGTS/guidelines/CT_Colonography.pdf. Accessed December 16, 2014.
352 Poullos PD, Beaulieu CF. Current techniques in the performance, interpretation, and reporting of CT colonography. [Review] [111 refs]. Gastrointestinal Endoscopy Clinics of North America. Apr. 2010;20(2):169-92. [pmid: 20451809].
353 Viatronix. V3D(R)-Colon. 2011.
354 Pickhardt PJ, Hassan C, Laghi A, et al. Clinical management of small (6- to 9-mm) polyps detected at screening CT colonography: a cost-effectiveness analysis. AJR. Nov. American. 2008;(5):1509-16. [pmid: 18941093].
355 Pickhardt PJ, Hassan C, Laghi A, et al. Small and diminutive polyps detected at screening CT colonography: a decision analysis for referral to colonoscopy. AJR. Jan. American. 2008;(1):136-44. [pmid: 18094303].
356 Bildzukewicz NA, Weinstein MS. Appendicitis following virtual colonoscopy: a case report. Journal of Gastrointestinal Surgery. Dec. 2012;16(12):2291-3. [pmid: 22918862].
357 Committee to Assess Health Risks from Exposure to Low Levels of Ionizing Radiation, Board on Radiation Effects Research, Division on Earth and Life Studies, National Research Council of the National Academies. Health risks from exposure to low levels of ionizing radiation: BEIR VII Phase 2. Washington, DC. National Academies Press. 2006.
358 Cardis E, Vrijheid M, Blettner M, et al. Risk of cancer after low doses of ionising radiation: retrospective cohort study in 15 countries. BMJ. Jul. 9. 2005;331(7508):77. [pmid: 15987704].
359 Brenner DJ, Hall EJ. Computed tomography--an increasing source of radiation exposure. N Engl J Med. Nov. 29. 2007;357(22):2277-84. [pmid: 18046031].
360 Einstein AJ, Henzlova MJ, Rajagopalan S. Estimating risk of cancer associated with radiation exposure from 64-slice computed tomography coronary angiography. JAMA. Jul. 18. 2007;298(3):317-23. [pmid: 17635892].
361 Buls N, de MJ, Covens P, et al. Health screening with CT: prospective assessment of radiation dose and associated detriment. JBR-BTR. Jan. 2005;88(1):12-6. [pmid: 15792162].
362 Berrington de GA, Kim KP, Knudsen AB, et al. Radiation-related cancer risks from CT colonography screening: a risk-benefit analysis. AJR. Apr. American. 2011;(4):816-23. [pmid: 21427330].
363 Summers RM, Baecher N, Yao J, et al. Feasibility of simultaneous computed tomographic colonography and fully automated bone mineral densitometry in a single examination. Journal of Computer Assisted Tomography. Mar. 2011;35(2):212-6. [pmid: 21412092].
364 Pickhardt P, Bodeen G, Brett A, et al. Comparison of Femoral Neck BMD Evaluation Obtained Using Lunar DXA and QCT With Asynchronous Calibration From CT Colonography. J Clin Densitom. 2014. May. 28. [pmid: 24880495].
365 Dolan JG, Boohaker E, Allison J, et al. Can Streamlined Multicriteria Decision Analysis Be Used to Implement Shared Decision Making for Colorectal Cancer Screening?. Med Decis Making. 2013. Dec. 3. [pmid: 24300851].
366 Holden DJ, Harris R, Porterfield DS, et al. Enhancing the use and quality of colorectal cancer screening. [Review] [220 refs]. Evidence Report/Technology Assessment. 2010;(190):1-195. [pmid: 20726624].
367 Long MD, Lance T, Robertson D, et al. Colorectal cancer testing in the national Veterans Health Administration. Dig Dis Sci. Feb. 2012;57(2):288-93. [pmid: 21922220].
368 Stock C, Brenner H. Utilization of lower gastrointestinal endoscopy and fecal occult blood test in 11 European countries: evidence from the Survey of Health, Aging and Retirement in Europe (SHARE). Eur J Radiol. Jul. 2010;42(7):546-56. [pmid: 20432204].
369 Khalid-de BC, Jonkers D, Smits K, et al. Participation in colorectal cancer screening trials after first-time invitation: a systematic review. Eur J Radiol. Dec. 2011;43(12):1059-86. [pmid: 22135196].
370 Hassan C, Giorgi RP, Camilloni L, et al. Meta-analysis: adherence to colorectal cancer screening and the detection rate for advanced neoplasia, according to the type of screening test. Alimentary Pharmacology & Therapeutics. Nov. 2012;36(10):929-40. [pmid: 23035890].
371 Littlejohn C, Hilton S, Macfarlane GJ, et al. Systematic review and meta-analysis of the evidence for flexible sigmoidoscopy as a screening method for the prevention of colorectal cancer. British Journal of Surgery. Nov. 2012;99(11):1488-500. [pmid: 23001715].
372 Lo SH, Halloran S, Snowball J, et al. Colorectal cancer screening uptake over three biennial invitation rounds in the English bowel cancer screening programme. Gut. 2014. May. 7. [pmid: 24812001].
373 Mysliwiec PA, Jensen CD, Zhao W, et al. Fecal immunochemical test performance over mulitple rounds of annual testing in an outreach screening program. Gastroenterology. 2015;146(5):S-33.
374 Gellad ZF, Stechuchak KM, Fisher DA, et al. Longitudinal adherence to fecal occult blood testing impacts colorectal cancer screening quality. Am J Gastroenterol. Jun. 2011;106(6):1125-34. [pmid: 21304501].
375 Zauber AG, Winawer SJ, Mills GM, et al. Adherence to screening in a randomized controlled trial of a one-time screening colonoscopy versus program of annual fecal occult blood test (gFOBT): Implications of lower gFOBT adherence to screening on colorectal cancer mortality reduction. Gastroenterology. 2012;142:S82-S83.
376 Lieberman DA, Weiss DG, Harford WV, et al. Five-year colon surveillance after screening colonoscopy. Gastroenterology. Oct. 2007;133(4):1077-85. [pmid: 17698067].
377 Carlson CM, Kirby KA, Casadei MA, et al. Lack of follow-up after fecal occult blood testing in older adults: Inappropriate screening or failure to follow up?. Archives of Internal Medicine. Feb. 14. 2011;171(3):249-56. [pmid: 20937917].
378 Crawford ND, Jones CP, Richardson LC. Understanding racial and ethnic disparities in colorectal cancer screening: Behavioral Risk Factor Surveillance System, 2002 and 2004. Ethnicity & Disease. 2010;20(4):359-65. [pmid: 21305822].
379 Fenton JJ, Tancredi DJ, Green P, et al. Persistent racial and ethnic disparities in up-to-date colorectal cancer testing in medicare enrollees. Journal of the American Geriatrics Society. Mar. 2009;57(3):412-8. [pmid: 19175435].
380 Klabunde CN, Cronin KA, Breen N, et al. Trends in colorectal cancer test use among vulnerable populations in the United States. Cancer Epidemiol Biomarkers Prev. Aug. 2011;20(8):1611-21. [pmid: 21653643].
381 Homayoon B, Shahidi NC, Cheung WY. Impact of asian ethnicity on colorectal cancer screening: a population-based analysis. American Journal of Clinical Oncology. Apr. 2013;36(2):167-73. [pmid: 22441340].
382 Inadomi JM, Vijan S, Janz NK, et al. Adherence to colorectal cancer screening: a randomized clinical trial of competing strategies. Archives of Internal Medicine. Apr. 9. 2012;172(7):575-82. [pmid: 22493463].
383 Burgess DJ, van RM, Grill J, et al. Presence and correlates of racial disparities in adherence to colorectal cancer screening guidelines. Journal of General Internal Medicine. Mar. 2011;26(3):251-8. [pmid: 21088920].
384 Laiyemo AO, Doubeni C, Pinsky PF, et al. Race and colorectal cancer disparities: health-care utilization vs different cancer susceptibilities. J Natl Cancer Inst. Apr. 21. 2010;102(8):538-46. [pmid: 20357245].
385 Yager SS, Chen L, Cheung WY. Sex-based Disparities in Colorectal Cancer Screening. Am J Clin Oncol. 2013. Mar. 4. [pmid: 23466582].
386 Gancayco J, Soulos PR, Khiani V, et al. Age-based and sex-based disparities in screening colonoscopy use among medicare beneficiaries. Journal of Clinical Gastroenterology. Aug. 2013;47(7):630-6. [pmid: 23619827].
387 Clarke N, Sharp L, Osborne A, et al. Comparison of Uptake of Colorectal Cancer Screening Based on Fecal Immunochemical Testing (FIT) in Males and Females: A Systematic Review and Meta-analysis. Cancer Epidemiol Biomarkers Prev. Nov. 6. 2014;24(1):39-47. [pmid: 25378366].
388 Lieberman D. Race, gender, and colorectal cancer screening. Am J Gastroenterol. Dec. 2005;100(12):2756-8. [pmid: 16393231].
389 Cooper GS, Chak A, Koroukian S. The polyp detection rate of colonoscopy: a national study of Medicare beneficiaries. Am J Med. Dec. 2005;118(12):1413. [pmid: 16378787].
390 Yamaji Y, Mitsushima T, Yoshida H, et al. The malignant potential of freshly developed colorectal polyps according to age. Cancer Epidemiol Biomarkers Prev. Dec. 2006;15(12):2418-21. [pmid: 17164364].
391 Agrawal S, Bhupinderjit A, Bhutani MS, et al. Colorectal cancer in African Americans. Am J Gastroenterol. Mar. 2005;100(3):515-23. [pmid: 15743345].
392 Rex DK, Johnson DA, Anderson JC, et al. American College of Gastroenterology guidelines for colorectal cancer screening 2009. Am J Gastroenterol. Mar. 2009;104(3):739-50. [pmid: 19240699].
393 Lansdorp-Vogelaar I, van BM, Zauber AG, et al. Individualizing colonoscopy screening by sex and race. Gastrointest Endosc. 2009;70(1):96-108. [pmid: 19467539].
394 Cotterchio M, Manno M, Klar N, et al. Colorectal screening is associated with reduced colorectal cancer risk: a case-control study within the population-based Ontario Familial Colorectal Cancer Registry. Cancer Causes Control. Sep. 2005;16(7):865-75. [pmid: 16132797].
395 Haug U, Knudsen AB, Brenner H, et al. Is fecal occult blood testing more sensitive for left- versus right-sided colorectal neoplasia? A systematic literature review. Expert Review of Molecular Diagnostics. Jul. 2011;11(6):605-16. [pmid: 21745014].
396 Massat NJ, Moss SM, Halloran SP, et al. Screening and primary prevention of colorectal cancer: a review of sex-specific and site-specific differences. Journal of Medical Screening. 2013;20(3):125-48. [pmid: 24197771].
397 Day LW, Walter LC, Velayos F. Colorectal cancer screening and surveillance in the elderly patient. Am J Gastroenterol. 2012;106(7):1197-206. [pmid: 21519362].
398 Zauber AG, Lansdorp-Vogelaar I, Knudsen AB, et al. Evaluating Test Strategies for Colorectal Cancer Screening Age to Begin, Age to Stop, and Timing of Screening Intervals: A Decision of Colorectal Cancer Screening for the U.S. Preventive Services Task Force from the Cancer Intervention and Surveillance Modeling Network (CISNET). 2009. [pmid: 20722163].
399 Lansdorp-Vogelaar I, Gulati R, Mariotto AB, et al. Personalizing age of cancer screening cessation based on comorbid conditions: model estimates of harms and benefits. Ann Intern Med. Jul. 15. 2014;161(2):104-12. [pmid: 25023249].
400 Lin O, Roy PK, Schembre DB, et al. Screening sigmoidoscopy and colonoscopy for reducing colorectal cancer mortality in asymtomatic persons. Cochrane Database of Systematic Reviews. 2005:CD005201.
401 Hol L, Wilschut JA, van BM, et al. Screening for colorectal cancer: random comparison of guaiac and immunochemical faecal occult blood testing at different cut-off levels. British Journal of Cancer. Apr. 7. 2009;100(7):1103-10. [pmid: 19337257].
402 Hol L, de JV, van Leerdam ME, et al. Screening for colorectal cancer: comparison of perceived test burden of guaiac-based faecal occult blood test, faecal immunochemical test and flexible sigmoidoscopy. European Journal of Cancer. Jul. 2010;46(11):2059-66. [pmid: 20621736].
403 Halloran SP, Launoy G, Zappa M, et al. European guidelines for quality assurance in colorectal cancer screening and diagnosis. First Edition--Faecal occult blood testing. Eur J Radiol. Sep. 2012;44:Suppl-87. [pmid: 23012123].
404 Brown SR, Baraza W. Chromoscopy versus conventional endoscopy for the detection of polyps in the colon and rectum. Cochrane Database of Systematic Reviews. 2010;(10):CD006439. [pmid: 20927746].
405 Kewenter J, Brevinge H. Endoscopic and surgical complications of work-up in screening for colorectal cancer. Dis Colon Rectum. Jun. 1996;39(6):676-80. [pmid: 8646956].
406 Chang CW, Chang WH, Shih SC, et al. Accidental diagnosis of Trichuris trichiura by colonoscopy. Gastrointest Endosc. Jul. 2008;68(1):154. [pmid: 18402953].
407 Kaiser Permanente Care Management Institute. Colorectal cancer screening clinical practice guideline. Oakland, CA. Kaiser Permanente Care Management Institute. 2008.
408 Yee J, Rosen MP, Blake MA, et al. ACR Appropriateness Criteria on colorectal cancer screening. Journal of the American College of Radiology. Sep. 2010;7(9):670-8. [pmid: 20816627].
409 Scottish Intercollegiate Guidelines Network (SIGN). Diagnosis and management of colorectal cancer: A national clinical guideline. Edinburgh. SIGN. 2011.
410 Brink D, Barlow J, Bush K, et al. Colorectal Cancer Screening. Institute for Clinical Systems Improvement. 2012.
411 Qaseem A, Denberg TD, Hopkins RH Jr, et al. Screening for colorectal cancer: a guidance statement from the American College of Physicians. Ann Intern Med. Mar. 6. 2012;156(5):378-86. [pmid: 22393133].
412 National Comprehensive Cancer Network. NCCN Clinical Practice Guidelines in Oncology (NCCN Guidelines): Colorectal cancer screening. National Comprehensive Cancer Network. 2013.