# Discussion

## Summary of Evidence

### Overall

We conducted this review to support the USPSTF in updating its recommendation on screening for CRC. Since its previous recommendation was published in 2008,^87^ we have included 95 new studies. They include 24 studies that assessed the impact of screening on CRC incidence and mortality, 19 new studies that assessed the diagnostic accuracy of screening tests, and 70 new studies that assessed harms.

A number of tests have been studied for their use in screening for CRC in average-risk adults, including colonoscopy, FS, CTC, high-sensitivity gFOBT, various qualitative and quantitative FITs, and mtsDNA test (which includes FIT) (Table 29). These test options have different levels of evidence to support their use, different test performance to detect cancer and precursor lesions, and different risk of serious adverse events. At this time, comparative studies of the different screening tests are limited in their study design and power to detect cancers (and missed/interval cancers), mortality, or serious harms. Therefore, they cannot answer questions of the relative benefit and harms (tradeoffs) between the tests. Taking this in consideration, this systematic review of the available evidence may be used in tandem with microsimulation modeling conducted by CISNET, which addresses issues around the comparative performance, benefit, and harms of available tests, as well as decisions around screening intervals and age to start/stop screening. Additionally, choice of screening test and implementation of screening programs within health systems will depend on a number of factors (not covered in this report) in addition to the comparative performance, including patient preference and available resources (including but not limited to cost).

Table 29 Summary of Evidence by Key Question and Screening Test

KQ | Test | # Studies (k), sample size (n), Design | Summary of Findings^*^ | Body of Evidence Limitations^†^ | Quality | Applicability
KQ1: Effectiveness of screening on CRC mortality | Colonoscopy | k=1 n=88,902 Prospective cohort | After 24 years, CRC specific mortality was lower in persons with self-reported screening colonoscopy (multivariate adjusted HR, 0.32 [95% CI, 0.24–0.45]) compared to those who had never had screening endoscopy. Mortality benefit observed for both proximal and distal CRC. | Single study. No reporting bias. | Fair | Fair- cohort limited to health professionals
KQ1: Effectiveness of screening on CRC mortality | FS | k=4 n=458,002 RCT | FS consistently decreased CRC-specific mortality compared to no screening at 11 to 12 years of followup (IRR, 0.73 [95% CI, 0.66–0.82]). Only 1 trial, PLCO, evaluated more than 1 round of screening. Mortality benefit is limited to distal CRC. | Variation in referral criteria led to differing rates of followup colonoscopy. No reporting bias. | Fair to good | Fair to poor- no longer widely used in US
KQ1: Effectiveness of screening on CRC mortality | gFOBT | k=5 n=442,088 RCT^‡^ | Biennial screening with Hemoccult II compared to no screening (n=404,396) consistently resulted in reduction of CRC-specific mortality, ranging from 9 to 22 percentage points after 2 to 9 rounds of screening with 11 to 30 years of followup (RR, 0.91 [95% CI, 0.84–0.98] at 19.5 years to RR, 0.78 [95% CI, 0.65–0.93] at 30 years). | Variation in number of screening rounds, use of rehydrated samples, definition of “test positive,” and recommended diagnostic followup. No reporting bias. | Fair to good | Poor- Hemoccult II no longer widely used
KQ1: Effectiveness of screening on CRC mortality | Comparative effectiveness | k=12 n=94,526 RCT k=3 n=346,494 Prospective cohort | Trials comparing different screening tests do not provide evidence of comparative benefit in CRC incidence or mortality outcomes. | Studies are not designed to assess screening impact on mortality; limited to a single round of screening, low number of cancers detected, and few interval cancers reported. | Poor to fair | Not applicable
KQ2: Diagnostic accuracy of screening | Colonoscopy | k=4 n=4821 Prospective diagnostic accuracy | In 2 studies (n=1685), colonoscopy missed cancers. In 3 studies (n=2290) comparing colonoscopy to CTC or CTC-enhanced colonoscopy, the per-person sensitivity for adenomas ≥10 mm ranged from 89.1% to 94.7%, and the per-person sensitivity for adenomas ≥6 mm ranged from 74.6% to 92.8%. | Studies are not designed to assess diagnostic accuracy to detect cancer. Limited number of studies with large number of endoscopists, thus applicable to community practice. No reporting bias. | Fair to good | Fair- colonoscopies were conducted or supervised by “experienced” specialists
KQ2: Diagnostic accuracy of screening | FS | None^**^ | Not applicable | Not applicable | Not applicable | Not applicable
KQ2: Diagnostic accuracy of screening | CTC | k=9 n=6497 Prospective diagnostic accuracy | In 1 study (n=2531), CTC missed 1 of 7 cancers. In 7 studies of CTC with bowel prep (n=5328), the per-person sensitivity and specificity to detect adenomas ≥10 mm ranged from 66.7% to 93.5% and 86.0% to 97.9%, respectively; the per-person sensitivity and specificity to detect adenomas ≥6 mm ranged from 72.7% to 98.0% and 79.6% to 93.1%, respectively. Only 3 studies (n=1044) reported sensitivity to detect advanced adenomas, ranging from 87.5% to 100%. In 2 studies (n=1169) of CTC without bowel prep, it appears that sensitivity without bowel prep to detect advanced adenomas, adenomas ≥10 mm, or adenomas ≥6 mm is lower than CTC protocols including bowel prep. | Studies are not designed to assess diagnostic accuracy to detect cancer. Unclear if the variation of test performance is due to differences in study design, populations, bowel prep, CTC imaging itself, or differences in reader experience or reading protocols. No reporting bias. | Fair to good | Fair- mostly single-center studies, the majority of studies (k=7) used 3 or fewer highly trained radiologists, current practice may use lower doses of radiation (therefore different technology and protocols)
KQ2: Diagnostic accuracy of screening | gFOBT | k=3 n=15,969 Prospective diagnostic accuracy | The sensitivity and specificity of Hemoccult SENSA to detect CRC ranged from 61.5% to 79.4% and from 86.7% to 96.4%, respectively. | Verification bias (i.e., screen-negative persons did not receive colonoscopy). No reporting bias. | Fair | Fair to poor- Hemoccult SENSA no longer widely used in US
KQ2: Diagnostic accuracy of screening | FIT | Qualitative k=6 n=36,808 Prospective diagnostic accuracy Quantitative k=7 n=40,134 Prospective diagnostic accuracy | In studies with colonoscopy followup for all, qualitative and quantitative FIT sensitivity varied considerably across different assays for each outcome. Good results were seen from specific FITs with supporting data from more than 1 study, and best results from small studies using more than 1 stool sample or lower than manufacturer-recommended cutoffs. In 4 studies (n=34,857) evaluating 3 FDA-cleared qualitative FITs, OC-Light had the best sensitivity and specificity for CRC (87.5% and 91.0%, respectively, in 1 study, and 78.6% and 92.8% in another). For advanced adenoma, sensitivity and specificity were lower (40.3% and 92.3%, respectively, in 1 study and 28.0% and 93.5% in another). In 9 studies (n=42,310) evaluating 7 quantitative FITs, best results were seen with OC FIT-CHEK, the only FDA-cleared test. Sensitivity and specificity for CRC varied from 73.3% and 95.5%, respectively, to 92.3% and 87.2%. For advanced adenoma, sensitivity and specificity varied from 22.2% and 97.4%, respectively, to 44.1% and 89.8%. | Variation in test performance resulted from the use of 18 different FITs (FIT families), different numbers of stool samples, and to a limited extent, different assay cutoff value. Sparse data on most individual tests limited comparisons. Quantitative FITs included some that are older and now discontinued. In a separate group of studies (k=7), verification bias (i.e., screen-negative persons did not receive colonoscopy) did not change results or conclusions. No reporting bias. | Fair to good | Fair to good- for specific qualitative (OC-Light) and quantitative (OC-FIT CHEK) tests
KQ2: Diagnostic accuracy of screening | mtsDNA | k=1 n=9989 Prospective diagnostic accuracy | mtsDNA assay had better sensitivity but lower specificity compared to a commercial FIT (OC-FIT CHEK) for the detection of CRC and advanced adenoma. The sensitivity and specificity for CRC was 92.3% (95% CI, 84.0 to 97.0) and 84.4% (95% CI, 83.6 to 85.1), respectively; and for advanced adenoma was 42.4% (95% CI, 38.7 to 46.2) and 86.3% (95% CI, 85.5, 87.0), respectively. | Single study. 6% inadequate stool sample. No reporting bias. | Fair | Fair- only 1 mtsDNA test available, incorporates FIT in stool test, Cologuard (Exact Sciences)
KQ2: Diagnostic accuracy of screening | mSEPT9 | k=1 n=1516 Prospective diagnostic accuracy | Weighted sensitivity and specificity of the mSEPT9 assay to detect CRC was 48.2% (95% CI, 32.4 to 63.6) and 91.5% (95% CI, 89.7 to 93.1), respectively. | Single study. Large attrition due to incomplete data or inadequate sample. Analyses conducted in random subsample stratified by colonoscopy findings. No reporting bias. | Fair | Poor- only 1 blood test available and not FDA-approved for screening, Epi proColon Assay (Epigenomics AG)
KQ3: Serious adverse events of screening | Screening program | k=13 n=45,867 RCT | We found no evidence for any serious harms resultant from stool testing other than false-negative results and risk of serious adverse events associated with diagnostic colonoscopy. The rate of perforation in colonoscopies for positive FOBT may be higher, the pooled estimate was 8 perforations (k=6) per 10,000 (95% CI, 2 to 32). Likewise, rates of serious adverse events from followup diagnostic/therapeutic colonoscopy post FS (k=6) is estimated at 14 perforations per 10,000 (95% CI, 9 to 26), and 34 major bleeds per 10,000 (95% CI, 5 to 63). | Serious adverse events not reported in comparator arms (persons without endoscopy). Likely reporting bias of serious harms other than perforation and bleeding. No studies report differential harms by age groups. | Fair | Fair to good- reflects community practice, limited studies in US
KQ3: Serious adverse events of screening | Colonoscopy | k=55 n=10,398,876 24 prospective cohorts or trials, 31 retrospective studies | Serious adverse events from screening colonoscopy or colonoscopy in asymptomatic persons is estimated at 4 perforations (k=26) per 10,000 procedures (95% CI, 2 to 5) and 8 major bleeds (k=22) per 10,000 procedures (95% CI, 5 to 14). Other serious harms were not consistently reported. Risk of perforations, bleeding and other serious harms increase with age. | Only 2 studies reported serious adverse events in persons without colonoscopy (no difference in serious harms other than perforation and bleeding. Likely reporting bias of serious harms other than perforation and bleeding. | Fair | Good- reflects community practice
KQ3: Serious adverse events of screening | FS | k=18 n=331,181 13 prospective cohorts or trials, 5 retrospective studies | Serious adverse events from screening FS are estimated at 1 perforation (k=16) per 10,000 procedures (95% CI, 0.4 to 1.4) and 2 major bleeds (k=10) per 10,000 procedures (95% CI, 1 to 4). | No studies reported serious adverse events in persons without FS. Likely reporting bias of serious harms other than perforation and bleeding. Only 1 study reported differential harms by age groups (no difference with increasing age). | Fair | Good- reflects community practice
KQ3: Serious adverse events of screening | CTC harms | k=15 n=75,354 11 prospective cohorts or trials, 4 retrospective studies | Serious harms from CTC in asymptomatic persons are uncommon. Risk of perforation for screening CTC was less than 2 per 10,000 exams. The range of low-dose ionizing radiation per exam is 1 to 7 mSv. | No studies reported serious adverse events in persons without CTC. More limited evidence in true average-risk screening populations. Likely reporting bias of serious harms other than perforation. No studies report differential harms by age groups. | Fair | Fair to good- radiation exposure per exam may be decreasing over time
KQ3: Serious adverse events of screening | CTC ECF | k=21 n=38,193 retrospective studies | Extracolonic findings, which could be a benefit or harm, are estimated to occur in 41% to 69% of examinations. Similarly, the estimated proportion of these findings that necessitate actual diagnostic followup varies widely from 5% to 37%, with a very small proportion that require any type of definitive treatment (up to 3%). Higher prevalence of ECF with increasing age. | No studies able to quantify net benefit/harms of ECF findings. Varying levels of followup, few studies with final disposition of ECF. Some variation in definition of clinical importance of ECF. Very limited studies comparing ECF by age groups. | Fair | Fair to good- categorization of ECF using C-RADS

* Includes consistency and precision

† Includes reporting bias

‡ Total 6 RCTs identified, but 1 trial (from Finland) has not yet reported mortality outcomes

** No studies meeting inclusion criteria requiring comparison against criterion standard of colonoscopy

Abbreviations: CI = confidence interval; C-RADS = Computed Tomographic Colonography Reporting and Data System; CRC = colorectal cancer; CTC = computer tomographic colonography; ECF = extracolonic findings; k = number of studies; FDA = Food and Drug Administration; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; FOBT = fecal occult blood test; HR = hazard ratio; IRR = incidence rate ratio; mSEPT9 = circulating methylated septin 9 gene deoxyribonucleic acid; mSv = millisievert; mtsDNA = multi-target stool deoxyribonucleic acid; n = number; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; RCT = randomized controlled trial; RR = relative risk

To date, no CRC screening modality has been shown to reduce all-cause mortality. Robust data from well-conducted, population-based screening RCTs demonstrate that both Hemoccult II and FS can reduce CRC mortality. However, FS data are limited to one or two rounds of screening. In addition, Hemoccult II and FS are no longer widely used for screening in the United States. Therefore, we have limited empirical data on true programs of CRC screening and screening modalities used in clinical practice today. Expensive, large population-based RCTs of newer stool tests may not be necessary, as evidence-based reasoning supports that screening with stool tests with sensitivity and specificity that are as good as, or better than, Hemoccult II would result in CRC mortality reductions similar or better than reductions shown in existing trials.296 Based on our review, there are a number of newer stool tests available that meet those requirements, including single-sample testing with OC-Light or OC FIT-CHEK. Stool tests that maximize sensitivity, such as mtsDNA, multisample FITs, or quantitative FIT using lower cutoffs, have lower specificity and therefore need new trials or modeling exercises to understand the tradeoff of more false-positives. Although imperfect, colonoscopy remains the criterion standard for assessing the test performance of other screening tests; however, its superiority in a program of screening has not been established. To date, no trials have reported on the mortality benefit of colonoscopy. Furthermore, colonoscopy is significantly more invasive, with greater accompanying harms (and potential harms of overdiagnosis and/or unnecessary polypectomy/surveillance) than other available testing. Evidence continues to accrue for CTC that suggests adequate detection for CRC and larger potential precursor lesions. Although risk of immediate harms from screening CTC (such as bowel perforation from insufflation) is very low, it is unclear what (if any) true harm is posed by cumulative exposure to low doses of radiation or detection of extracolonic findings. Although a blood test would undoubtedly increase screening rates, the Epi proColon test for circulating mSEPT9 has worse test performance for the detection of CRC than other noninvasive testing.

### Stool Tests

#### gFOBT

We updated and confirmed that Hemoccult II is the only stool CRC screening test that has been shown to significantly decrease CRC-specific mortality by 9 to 22 percent (biennial screening, five studies) or by 32 percent (annual screening, one study) in a program of screening after 11 to 30 years of followup compared to no screening in large, well-designed RCTs. Hemoccult II screening did not affect all-cause mortality. These results are in general agreement with the Cochrane Colorectal Cancer Group update on CRC screening using Hemoccult testing. In this review, overall reduction in CRC mortality across four RCTs was 16 percent (RR, 0.84 [95% CI, 0.78 to 0.90]) at 12–18 years.297

Hemoccult SENSA has replaced Hemoccult II because of its improved sensitivity to detect CRC. Based on three diagnostic accuracy studies, Hemoccult SENSA (three samples) sensitivity ranged from 61.5 to 79.4 percent. The specificity, however, was reported as low as 86.7 percent.

#### FIT

In the United States, many health systems and coordinated screening programs now use FITs, as opposed to gFOBT, to screen for CRC.298–302 FIT testing usually requires only one sample and eliminates dietary and medicinal restrictions, which generally improves ease of and adherence to testing.303,304

No included studies addressed the impact of FIT on CRC mortality. We excluded one large (n=192,261) RCT conducted in rural China that compared single FIT screening to no screening because of the setting (i.e., our inclusion criteria was limited to countries with a “very high” Human Development Index).305 In this trial, a single round of FIT testing had no statistically significant impact on CRC mortality (RR, 0.88 [95% CI, 0.72 to 1.07]) at 8 years of followup. In trials or cohort studies in which Hemoccult II was compared to various FIT assays, test positivity and CRC detection with FIT was consistently higher, although not always significantly so. Patient adherence to FIT was also consistently higher than to gFOBT. Given at least equal and likely better CRC detection and patient adherence, FITs are preferable to gFOBT. FITs are not a class of tests, however, and assay differences result in tests with different diagnostic performance. FIT sensitivity varied considerably across different qualitative and quantitative assays in the included diagnostic accuracy studies. The qualitative OC-Light (n=25,707) and the quantitative OC FIT-CHEK (n=15,029) tests, both available in the United States and cleared by the FDA, performed well in more than one study. Although quantitative FITs are cleared only for qualitative or dichotomous use in the United States, they maintain the advantage of a flexible assay cutoff value (to adjust desired performance characteristics) and potential for automation in high-volume settings. Qualitative assays designed for manual use are ideal for low-volume settings where flexibility is not required. Based on a single stool sample for OC-Light or OC FIT-CHEK, the test performance to detect CRC ranged from 73.3 percent sensitivity and 95.5 percent specificity to 87.5 percent sensitivity and 90.9 percent specificity. In the largest studies, sensitivity to detect CRC was 73.8 percent (95% CI, 62.3 to 83.3) for quantitative OC FIT-CHEK (n=9,989) and 78.6 percent (95% CI, 61.0 to 90.5) for qualitative OC-Light (n=18,296). For these FITs, the sensitivity was higher in small studies that either tested three stool samples (sensitivity, 92.3% [95% CI, 69.3 to 99.2]; specificity, 87.2% [95% CI, 84.7 to 89.4]) or lowered the assay cutoff value (sensitivity, 87.5%; specificity, 90.9%). Specificity decreased with increasing sensitivity. The range of sensitivity and specificity estimates for these selected FITs is similar to the results of a meta-analysis of all FIT types, in which estimated sensitivity was 0.79 (95% CI, 0.69 to 0.86) and estimated specificity was 0.94 (95% CI, 0.92 to 0.95).306

#### mtsDNA (Stool DNA Plus FIT)

The mtsDNA test (Cologuard), concurrently approved by the FDA for marketing and by CMS for coverage in August 2014, combines the results of a FIT and DNA marker assays. It is the most expensive of the stool tests, reimbursed by CMS at $493 per test.307 In comparison, the cost of FITs is generally much lower, with a CMS reimbursement of $23 and a mean commercial reimbursement of $21 per test.308 In one large study (n=9,989), mtsDNA was statistically significantly more sensitive for CRC (92.3%) than OC FIT-CHEK (73.8%) using a recommended single stool sample for each test. In other included FIT studies, OC FIT-CHEK had higher estimated sensitivity when multiple samples or lower assay cutoffs were used. However, comparison of test performances across studies is difficult due to differences in study design and population characteristics. In all cases, increasing sensitivity was accompanied by decreasing specificity. Specificity for the mtsDNA test (84.4%), for example, was lower than for all FIT assays, resulting in the highest false-positive rate.

The high rate of unsatisfactory samples for the mtsDNA test (6.25%) was concerning when compared to the rate for FITs (0.3%). Excluded samples in this study were in part due to leakage in shipping, which the manufacturer reported has since been fixed, as well as a study quality control measure that authors indicate would not be encountered in clinical practice.208 At a programmatic level, information is lacking on patient adherence and the appropriate screening interval, as well as the impact of false-positives as a result of lowered specificity.309

#### Harms of Stool Testing

There are no hypothesized serious adverse events from noninvasive stool testing other than the risk of missed cancers (false-negatives). However, serious adverse events may result from followup diagnostic colonoscopy for positive stool testing. Based on six trials, the rate of perforation in colonoscopies for positive stool testing may be higher than for colonoscopies in average-risk screening populations (see below); the pooled estimate was 8 perforations (95% CI, 2 to 32) per 10,000 diagnostic colonoscopies.

### Endoscopy

#### FS

Four large RCTs evaluating screening FS have been published since the previous USPSTF recommendation on CRC screening. These trials showed that one-time FS (or two rounds of FS in the PLCO trial) consistently reduced CRC-specific mortality compared to no screening at 11 to 12 years of followup (IRR, 0.73 [95% CI, 0.66 to 0.82]). This reduction in mortality, however, was limited to distal CRC, and there was no decrease in all-cause mortality. Our meta-analyses produced similar findings to those from another meta-analysis including the same four trials.310 Despite this robust evidence, recent utilization data in the United States suggest that FS (in combination with stool testing) is very uncommon (<1%).70 Public and clinician perceptions of accuracy of colonoscopy versus FS, given the reach of endoscopy, also play an important role in this issue.83

We found no studies estimating the diagnostic accuracy of FS compared to a colonoscopy reference standard. To date, estimates of FS sensitivity and specificity are based on a limited number of relatively small studies with suboptimal study designs (e.g., tandem FS studies, simulated studies using colonoscopy and assumed FS reach to splenic flexure).90 The sensitivity and specificity for CRC (and advanced adenomas) depend on whether the screening FS used biopsy and the referral criteria used for diagnostic or therapeutic colonoscopy. Screening FS with biopsy does not appear to be commonplace in U.S. practice. The PLCO trial used nonbiopsy referral-based criteria for followup colonoscopy and had the highest referral rate to colonoscopy (about 33%) of all the trials.

#### Colonoscopy

One fair-quality large cohort study using data from the Nurses’ Health Study and the Health Professionals Followup Study found that persons who self-reported screening colonoscopy had a lower CRC-specific mortality rate than persons who never had a screening endoscopy (adjusted HR, 0.32 [95% CI, 0.24 to 0.45]) at 24 years of followup. This reduction in CRC-specific mortality was greater for distal than proximal cancer but statistically and clinically significant for both types. Although this study adjusted for known confounders, the magnitude of association should be interpreted with caution and cannot be compared to the CRC mortality reduction observed in intention-to-treat analyses of FS and Hemoccult II RCTs. Three large RCTs of screening colonoscopy in average-risk adults that examine the long-term outcomes of CRC incidence and mortality are underway. The first is the Northern European Initiative on Colorectal Cancer trial comparing screening colonoscopy to usual care in Norway, Sweden, Poland, and the Netherlands.311 The remaining two trials are comparing screening colonoscopy to FIT; COLONPREV is comparing colonoscopy to biennial FIT in Spain120,312,313 and CONFIRM is comparing colonoscopy to annual FIT in the United States.302

We found a limited number of studies examining the test performance of screening colonoscopy in a community setting. Only four studies, which were primarily designed to evaluate screening CTC and in which colonoscopy was conducted by more than a handful of expert endoscopists, reported sufficient data to determine the sensitivity and specificity of screening colonoscopy. In these studies, colonoscopy was compared to a criterion standard or CTC or CTC-enhanced colonoscopy. However, none of these trials were designed to estimate the test performance for detecting CRC. Based on three studies, the per-person sensitivity for colonoscopy to detect adenomas 10 mm or larger ranged from 89.1 to 94.7 percent and the per-person sensitivity to detect adenomas 6 mm or larger ranged from 74.6 to 92.8 percent. Test performance of screening colonoscopy will vary in clinical practice because of bowel preparation and colonoscopist performance/experience. The American Society for Gastrointestinal Endoscopy, American College of Gastroenterology, and U.S. Multi-Society Task Force have issued guidance and recommendations for the technical performance and quality improvement targets for colonoscopy.314,315

Most studies evaluating the test performance of colonoscopy are small studies that employed a limited number of expert endoscopists. Additionally, most of these studies were not conducted in screening populations. One review conducted by VanRijn and colleagues to assess miss rate determined by tandem colonoscopy (k=6; n=465) found that colonoscopy rarely misses adenomas 10 mm or larger (2.1% [95% CI, 0.3 to 7.3]) but the miss rate increases with smaller-sized adenomas (5–10 mm, 15% [95% CI, 8.0 to 18] and 1–5 mm, 26% [95% CI, 27 to 35]).316 These studies were not conducted in screening populations, however, and were thus excluded from our review. We also excluded a growing body of literature addressing technological advancements in colonoscopy to improve adenoma detection, namely chromoendoscopy or digital/virtual chromoendoscopy (e.g., narrow band imaging, flexible spectral imaging color enhancement, iScan) or endoscopic technologies to increase mucosal surface area inspection (e.g., wide-angle lens or full-spectrum endoscopy, cap-fitted colonoscopy, through-the-scope retrograde viewing device). The vast majority of the studies that evaluated these technological advancements were small, single-center studies that employed a small number of expert endoscopists. Multicenter trials of back-to-back colonoscopy evaluating the Third Eye® Retroscope® (Avantis Medical Systems, Sunnyvale, CA) or wide-angle lens endoscopy demonstrate fewer missed adenomas with enhanced technologies.317,318 To date, based on very limited multicenter randomized trials, it appears that technological advancements (i.e., chromoendoscopy, narrow band imaging, Third Eye Retroscope) can improve detection but data are limited to support widespread adoption in screening or average-risk populations.319–321

#### Harms of Endoscopy

Serious adverse events from screening colonoscopy or colonoscopy in asymptomatic persons are relatively uncommon, with a pooled estimate of 4 perforations (k=26) (95% CI, 2 to 5) and 8 major bleeds (k=22) (95% CI, 5 to 14) per 10,000 procedures. Based on 18 studies, the risk of serious harms following colonoscopy, including perforation and bleeding, is higher with increasing age. Serious adverse events from screening FS are even less common, with a pooled estimate of 1 perforation (k=17) (95% CI, 0.6 to 3) and 3 major bleeds (k=11) (95% CI, 1 to 9) per 10,000 procedures. In addition, FS may require followup diagnostic or therapeutic colonoscopy. The pooled estimate from six FS screening trials was 14 perforations (95% CI, 9 to 26) and 34 major bleeds (95% CI, 5 to 63) per 10,000 followup colonoscopy procedures for positive screening FS. Other serious harms (e.g., cardiopulmonary and other gastrointestinal events) were not consistently reported, and two studies evaluating harms in persons who received colonoscopy versus those who did not found no increased risk of serious harms (including MI, CVA, or other cardiovascular events) as a result of colonoscopy.

Case reports of fatal or near-fatal outcomes in average-risk persons undergoing routine colonoscopy include splenic rupture,322,323 retroperitoneal or intra-abdominal hemorrhage,324,325 retroperitoneal gas gangrene,326,327 bowel infarction or ischemic colitis,241,328,329 small bowel perforation,330 colonic gas explosion with electrocautery,331 and appendicitis or appendiceal abscess.332 In addition, there have been case reports of transmission of communicable diseases (i.e., hepatitis C virus, human papillomavirus) using unsanitized colonoscopes333–335 and chemical colitis from glutaraldehyde, which is used to disinfect endoscopes.336

#### Harms of Bowel Preparation

Common bowel preparation agents for FS include enemas and occasionally oral laxatives. Common bowel preparation agents for colonoscopy or CTC include PEG solution, oral sodium phosphate solution, and sodium picosulphate, with or without additional oral laxatives. Common minor adverse events include nausea, vomiting, abdominal pain, abdominal distension/bloating, anal irritation, headache, dizziness, electrolyte abnormalities (e.g., hyponatremia, hypokalemia, hypocalcemia, hyper- or hypophosphatemia), and poor sleep.

Serious adverse events (e.g., severe dehydration, symptomatic electrolyte abnormalities) are generally limited to persons with major predisposing illnesses.337,338 In clinical practice, sodium phosphate use is generally avoided in persons with renal impairment (such as older patients with reduced glomerular filtration rates), cardiovascular impairment (e.g. congestive heart failure, recent MI), major upper or lower gastrointestinal motility disturbances, gastrointestinal malabsorption, pre-existing electrolyte abnormalities, restricted oral intake (inability to rehydrate), and ascites.337 We found no evidence of clinically significant adverse effects due to bowel preparation that required hospitalization in average-risk screening populations preparing for FS, colonoscopy, or CTC, except for one person with “water intoxication” due to “over anxious bowel cleansing” in preparation for FS17 and another person with severe diarrhea.290 Two included studies that compared PEG versus sodium picosulphate bowel preparation found greater risk of serious harm, including acute kidney injury, for PEG versus sodium picosulphate, especially in older adults (age ≥65 years).234,248 In one recent large population-based retrospective cohort of older adults that we excluded from our review, sodium picosulphate was associated with an increased risk of hospitalization for hyponatremia compared to PEG in adults older than age 66 years.339 Overall, existing systematic reviews on bowel preparation for endoscopy suggest similar tolerability based on number of minor adverse events, no difference in efficacy of preparation, and no clinically significant adverse events from PEG or sodium phosphate.340,341 Low-volume PEG (2 L) with bisacodyl may be better tolerated than full-volume PEG (4 L), with no difference in efficacy.342 Case reports of serious adverse events from bowel preparation in average-risk persons undergoing colonoscopy include acute renal failure and acute phosphate nephropathy in persons who received bowel preparations with sodium phosphate or PEG,337,343–345 one person with ischemic colitis with sodium phosphate,337 one person with symptomatic hypokalemia with sodium phosphate,337 one person with Boerhaave syndrome (barogenic esophageal rupture) with PEG,346 and one person with a seizure secondary to hyponatremia with PEG.347

### CTC

While we found no studies examining the impact of screening CTC on cancer incidence or mortality, there is a growing body of evidence evaluating the test performance of screening CTC in average-risk adults. None of these studies (k=9) were designed to estimate test performance to detect cancer, as the number of cancers in these studies was low (range, 0 to 7 cancers). Based on studies of CTC with bowel preparation (k=7), the per-person sensitivity and specificity to detect adenomas 10 mm or larger ranged from 66.7 to 93.5 percent and 86.0 to 97.9 percent, respectively. The per-person sensitivity and specificity of CTC with bowel preparation to detect adenomas 6 mm or larger ranged from 72.7 to 98.0 percent and 79.6 to 93.1 percent, respectively. Only three studies reported sensitivity to detect advanced adenomas, ranging from 87.5 to 100.0 percent. Based on very limited data (k=2), it appears that sensitivity of CTC without bowel preparation to detect advanced adenomas, adenomas 10 mm or larger, or adenomas 6 mm or larger is lower than for CTC protocols including bowel preparation. Our findings are consistent with an existing systematic review by de Haan and colleagues of five prospective CTC screening studies in average-risk adults, which found that the per-person sensitivity and specificity for large adenomas (>10 mm) was 83.3 to 87.9 percent and 97.6 to 98.7 percent, respectively.348 However, per-person sensitivity and specificity for smaller adenomas (≥6 mm) was lower, at 75.9 to 82.9 percent and 91.4 to 94.6 percent, respectively.

It is unclear if the variation in test performance is due to differences in study design or populations studied or differences in bowel preparation, CTC imaging, reading protocols, and radiologist experience. In the included studies and current practice there is variation in bowel preparation (e.g., full, partial, none) and CTC technical enhancements (e.g., increasing detectors, fecal tagging, electronic cleansing, computer aided detection, insufflation techniques). Because some variation in accuracy is likely due to CTC protocol and/or radiologist ability, both the ACR and the International Collaboration for CT Colonography Standards have recommended practice guidelines and quality metrics, as well as specification for training and certification.349–351 In practice, the standard appears to be a dry preparation (sodium phosphate, magnesium citrate, bisacodyl) rather than a wet preparation (PEG) because of patient preferences and because PEG can leave liquid in the colon that can potentially obscure lesions.352 Fecal tagging now appears to be routinely employed (oral ingestion of high-density oral contrast agent so that residual colonic contents can be differentiated from soft tissue density polyps) and appears to decrease the need for cathartic preparation. Additionally, there are different contrast agents, either barium- or iodine-based (ionic and nonionic), and the choice for which to use is largely based on local experience. Current practice uses multidetector row CT scanners, using much thinner slices with faster scan times, resulting in better imaging and decreased radiation dose. Finally, there are differences in reading software. Currently, V3D® software by Viatronix (Stony Brook, NY) is the only software cleared by the FDA for CTC screening for CRC.353 Commonly used reading software allows for both two- and three-dimensional display. The choice of primary method used appears to depend on radiologist (personal) preference.

Other practice variation that influences the impact and implementation of screening CTC includes colonoscopy referral or surveillance criteria, as well as coordination with colonoscopy resources. Currently, there is consensus that large lesions (≥10 mm) be referred to colonoscopy for polypectomy. There is variation in practice for smaller lesions, such that 6- to 9-mm lesions may be referred to colonoscopy for polypectomy or be monitored with CTC surveillance (with a followup CTC in 3 years), and the smallest lesions (≤5 mm) may be ignored or monitored. The ACR states that persons with lesions of 6–9 mm should be offered colonoscopy and lesions smaller than 5 mm need not be reported.295,349,354,355 Ultimately, referral and/or surveillance criteria should depend on the risk of indwelling cancer in and the natural history of (still uncertain) small and diminutive lesions. Preference for CTC over colonoscopy may be, in part, due to difference in bowel preparation. Ideally, while same-day colonoscopy could avoid duplicate preparation, it may result in suboptimal colonoscopy if limited bowel preparation is used for CTC and would require close coordination between radiology and gastroenterology departments/services.

#### Harms of CTC

Immediate serious adverse events from screening CTC appear to be rare. Based on 14 studies, the risk of perforation with screening CTC was less than 2 perforations per 10,000 examinations. However, perforations were detected radiographically (not symptomatic) and sustained by room-air manual insufflation (no longer used in practice). CTC may also require followup diagnostic or therapeutic colonoscopy, and we did not find sufficient evidence to estimate serious adverse events from colonoscopy followup procedures. There was one case of acute appendicitis in an average-risk adult undergoing routine screening.356

Potential harms from CTC include exposure to radiation, especially if used in a program of screening that requires repeated examinations. Although radiation exposure from screening CTC appears to be decreasing over time due to technological and protocol advancements, the exposure still ranges up to 7 mSv per examination (dual positioning). For radiation produced in CT scanners, the effective dose equivalent (Sv) is the same as absorbed dose (Gy) (i.e., 1 mSv=1 mGy).192 Given that the average amount of radiation exposure from background sources in the United States is about 3.0 mSv per year,357 ionizing radiation from a single CTC examination is low. Even low doses of ionizing radiation, however, may convey a small excess risk of cancer.358,359 We identified no studies directly measuring the risk for stochastic effects (i.e., cancer) caused by radiation exposure from CTC. We can indirectly estimate these adverse effects, however, based on the range of effective radiation dose for CTC reported in the literature and estimates of lifetime attributable risk of malignancy (i.e., all solid cancers and leukemia) from the National Research Council report “Health Risks From Exposure to Low Levels of Ionizing Radiation.”357 Data are inadequate to quantify whether there is risk for noncancer diseases with low-dose radiation exposure.

Most experts in radiation exposure consider the abovementioned report from the National Research Council to be the definitive resource on radiation risk.357 Based on this report, the Council predicts that approximately 1 additional individual per 1,000 would develop cancer (solid cancer or leukemia) from an exposure of 10 mSv above background using the linear no-threshold (LNT) model. In comparison, 420 individuals per 1,000 would be expected to develop cancer from other causes over their lifetimes. Because of limitations in the data used to develop risk models, the risk estimates are uncertain, and variation by a factor of two or three cannot be excluded.357 Multiple organizations support the LNT model to estimate potential harms of radiation exposure of less than 100 mSv, including the Nuclear Regulatory Commission, the International Commission on Radiological Protection, the U.S. National Council on Radiation Protection and Measurements, the United Nations Scientific Committee on the Effects of Atomic Radiation, and the U.K. National Radiological Protection Board. Other organizations, however, believe that the LNT model is an oversimplification and likely overestimates potential harms of low-dose radiation exposure, including the Health Physics Society, the France Academy of Sciences/National Academy of Medicine, and the American Nuclear Society.360 The effective radiation dose in CTC targets the abdomen and would not likely increase the risk of certain prevalent cancers (e.g., cancers of the breast, thyroid, or lung), although the risk for leukemia or abdominal organ cancer may remain. This risk estimate is consistent with other published literature on radiation exposure risk from CT.359,361

Modeled data based on the National Research Council’s assumptions, and using a mean dose of 8 mSv for women and 7 mSv for men per CTC examination, found that the benefits of CTC screening every 5 years (from ages 50 to 80 years) far outweigh any potential radiation risks, with 15 cases of radiation-related cancers per 10,000 persons screened (95% CI, 8 to 28) versus 358 to 519 CRC cases prevented per 10,000 persons screened.362

#### Extracolonic Findings

CTC also detects extracolonic findings, which could be a benefit (e.g., detection of intervenable extracolonic cancer, abdominal aortic aneurysm) or harm (e.g., overdiagnosis, procedural harms from subsequent testing). Extracolonic findings are very common and are estimated to occur in 41 to 69 percent of examinations. Despite this, only approximately 5 to 37 percent of examinations have extracolonic findings that necessitate actual diagnostic followup. An even smaller proportion of examinations has findings that require any type of definitive treatment (≤3%). Therefore, judicious handling of the reporting and diagnostic workup of extracolonic findings is crucial to minimize the burden of testing (and associated cost and harms of testing), as many findings ultimately prove to be of no clinical consequence. Additional reading software may allow for repurposing CTC examinations to obtain bone mineral density from the lumbar spine to screen for osteoporosis if desired/indicated.363,364 It remains unclear if detection of extracolonic findings represents a net benefit or harm based on empirical evidence.

### Contextual Issues

#### Adherence

In clinical practice, uptake and adherence to CRC screening appears to be improving but remains suboptimal. Adherence to screening and followup testing varies widely. Preference for choice of screening test is multifactorial, based on the individual test’s ability to detect and/or prevent cancer, its side effects or adverse effects (including those from bowel preparation and the test itself), the risk of false-positives, and the screening frequency (interval of testing).365 Several patient factors may affect uptake and adherence to screening, including age, sex, socioeconomic status/education, race/ethnicity, acculturation, access to care, health status, risk for cancer, risky health behaviors, and psychosocial factors (including but not limited to patient knowledge, attitudes, and beliefs).366

Recent estimates of prevalence of CRC screening in the United States, based on Behavioral Risk Factor Surveillance System survey data, show that the overall proportion of adults who were “up to date” on CRC screening increased from 54 percent in 2002 to 65 percent in 2010.^70^ About 28 percent of U.S. adults, however, still had never been screened. Colonoscopy remains the most commonly used screening test (about 62%) followed by stool tests (about 10%). As such, other screening modalities are not commonly used.70 Analyses of large insurance databases confirm that colonoscopy is the most commonly used screening test among commercially insured persons in the United States.308 Additionally, uptake may be higher in health systems, particularly health systems with robust information technology infrastructure. In the Veterans Health Administration, for example, 80 percent of patients were “up to date” on CRC screening in 2008–2009.^367^ Uptake of CRC screening also appears to be higher in the United States than in most European countries, such that it may not be valid to extrapolate from CRC screening studies conducted outside the United States. Based on comparative utilization data across 11 European countries (i.e., Austria, Belgium, Denmark, France, Germany, Greece, Italy, the Netherlands, Spain, Sweden, Switzerland) in 2004 to 2005, the overall proportion of adults who were “up to date” on CRC screening using endoscopy varied from 6 to 25 percent, and using stool tests ranged from 4 to 61 percent.368

In general, adherence to screening varies by screening test (and over time), and adherence to screening tests and subsequent colonoscopy (if necessary) is suboptimal. Based on existing systematic reviews and included studies in this review, there appears to be greater adherence to FIT than to gFOBT, greater adherence to single application of stool-based testing than to a single application of endoscopy, and greater adherence to FS than to colonoscopy. Data to estimate adherence to CTC compared to other screening tests are limited; however, these data suggest that adherence to CTC may be greater than to colonoscopy. Overall, there are very limited data on adherence within U.S.-based screening programs and adherence to repeated screening over subsequent screening rounds. Additionally, tests other than colonoscopy may require followup diagnostic or therapeutic colonoscopy, and adherence to followup colonoscopy also varies and is suboptimal.

##### Adherence to Screening

We can estimate adherence to initial screening and subsequent testing in the United States from several types of study designs, including screening trials, studies of interventions to improve screening adherence, and description of existing screening (programs) in clinical practice. Most CRC screening trials were conducted outside the United States; only two have been conducted in the United States.122,127 One of these, the Minnesota Colon Cancer Control Study of screening with Hemoccult II, had 90 percent adherence to at least one round of screening (not reported for individual rounds), which was higher than adherence in Hemoccult II trials conducted outside the United States (range, 60% to 70%) (Table 7). The other, the PLCO trial of screening FS, had 84 percent adherence in the first round and 54 percent in the second round, which was higher than in the FS trials conducted outside the United States (range, 58% to 67% in the first round). None of the comparative effectiveness screening trials designed to evaluate comparative adherence were conducted in the United States (Appendix D). Based on trials conducted in Western European countries, adherence to a single round of gFOBT ranged from 32 to 59 percent, from 32 to 65 percent for FIT, from 28 to 47 percent for FS, from 20 to 39 percent for FS plus stool testing, from 17 to 27 percent for colonoscopy, and approximately 34 percent for CTC. One Dutch trial found greater adherence to CTC than to colonoscopy.128 However, estimates of adherence to colonoscopy and CTC are based on a limited number of studies, again none of which were conducted in the United States. We found no studies comparing the relative adherence of FIT versus mtsDNA testing.

Our findings are consistent with existing systematic reviews of adherence in screening trials. The most comprehensive existing review of adherence included 100 prospective studies of CRC screening, only 10 of which were conducted in the United States.369 This review by Khalid-de Bakker and colleagues included a meta-analysis to determine a pooled estimate of adherence to first-time invitation of screening across a wide range of studies spanning nearly three decades. They found that overall adherence was 47 percent for gFOBT, 42 percent for FIT, 35 percent for FS, 28 percent for colonoscopy, and 22 percent for CTC. One review of screening trials (k=14), again most of which were not conducted in the United States, found that the overall adherence to testing was about 33 percent, adherence to FIT was higher than for gFOBT (k=5; RR, 1.16 [95% CI, 1.03 to 1.3]), and adherence to endoscopy was lower than for stool tests (k=10; RR, 0.67 [95% CI, 0.56 to 0.80]). When considered by type of endoscopy, adherence to FS was not statistically significantly lower than for stool tests (RR, 0.78 [95% CI, 0.59 to 1.04]), and adherence to stool tests was higher than for colonoscopy (RR, 0.57 [95% CI, 0.42 to 0.78]).370 Another existing systematic review of 14 FS studies confirmed that the uptake of FS was lower than for stool-based testing (i.e., gFOBT or FIT).371 One comprehensive systematic review conducted by Holden and colleagues on enhancing the use and quality of CRC screening found a wide variation in adherence to screening in studies designed to improve adherence to CRC screening.366 Adherence in the usual care group (no intervention to improve adherence to screening) ranged from 17 to 51 percent for stool tests, from 5 to 59 percent for colonoscopy, and from 23 to 55 percent for any CRC screening test. Overall, interventions to improve screening rates vary in their effectiveness but can improve adherence from a few percentage points up to 42 percentage points.

We found very sparse data on adherence to screening over time (i.e., subsequent rounds of screening) in U.S. practice. We did not find published adherence rates for Hemoccult II testing over the multiple rounds of screening in the Minnesota trial. In the United Kingdom, adherence to initial gFOBT was 57 percent in the National Health Service Bowel Cancer Screening Programme but only 44 percent completed all three screening rounds.372 One study of adherence to stool testing within an integrated U.S. health system, Kaiser Permanente, showed that the initial adherence to FIT was 47 percent but only 24 percent adhered to annual testing over four rounds.373 A retrospective analysis of Veterans Health Administration medical centers also demonstrated low adherence over multiple rounds, with only 14 percent receiving at least four stool tests over 5 years.374 Another study comparing the adherence of colonoscopy versus gFOBT in the United States found that 85 percent received a one-time colonoscopy compared to 41 percent who adhered to three rounds of screening with gFOBT.375 We found even less data on adherence to followup screening colonoscopy. One small study from the Veterans Health Administration during the 1990s demonstrated that 57 percent of persons with a normal screening colonoscopy returned for a repeat screening colonoscopy (at 5.5-year interval).376 We found no data on adherence to multiple rounds of other screening modalities, including FS, FS plus stool testing, CTC, or mtsDNA.

##### Adherence to Followup Colonoscopy

Screening tests other than colonoscopy may require followup diagnostic or therapeutic colonoscopy, which is not always completed. From the Minnesota trial, for example, authors reported that on average 10 percent of participants had positive Hemoccult II tests and 83 percent underwent a diagnostic evaluation (which most often was colonoscopy). Likewise, in the PLCO trial, 33 percent of persons with screening FS were recommended to follow up with colonoscopy and 77 percent actually received this followup colonoscopy. One current prospective study (n=2,410) in VA patients age 70 years or older found that only 42% of those who had a positive stool test (9%) received a complete colon evaluation within 1 year.377 Of those who did not receive followup testing, however, 38 percent had documentation that comorbidity and preferences did not permit followup (were classified as inappropriate to screen initially). One existing review found that adherence to followup colonoscopy for positive stool testing (within 1 year) in integrated health systems ranged from 44 to 86 percent.366 This review also found that three older single-institution studies from the 1980s to 1990s had similar findings of incomplete followup.

##### Differential Adherence by Age, Sex, and Race/Ethnicity

Based on an existing systematic review, national U.S. survey data, and national Medicare data, it appears that uptake in CRC screening varies by age and race/ethnicity, so that older patients are more likely to be screened than younger patients, until age 80 years, and whites are more likely to be screened than blacks or Latinos.366,378,379 Once adjusted for other factors (e.g., income, insurance, education), however, there was no difference in uptake between whites and blacks. Health insurance coverage and access to care is a major explanatory factor in the United States and often explains observed racial/ethnic differences in screening uptake.380 Additionally, data were much more limited for Asians. Based on one recent study using California Health Interview Survey data, Asians had lower screening uptake than whites, and disaggregated data showed a wide variation in uptake among the different ethnic groups, such that Chinese and Koreans but not other groups had much lower uptake than whites.381 Fewer studies actually directly compared adherence to screening by age or race/ethnicity. One comprehensive existing review focusing on adherence to screening (mainly stool testing) found no consistent pattern or difference by age but did not examine race/ethnicity.369 One recent cluster RCT (n=997) found that adherence to gFOBT and colonoscopy or choice of gFOBT or colonoscopy increased with age and was higher in Latinos and Asians compared to blacks.382 One VA study found overall high adherence to CRC screening, and although blacks had slightly lower adherence (72%) compared to whites (77%), the disparity was attenuated (compared to national averages) and was accounted for by confounders of being unmarried and having lower levels of education.383 Very little data exist to understand disparities in adherence to followup colonoscopy by subgroups. Based on the PLCO trial, however, it appears that blacks had lower adherence (63%) to followup diagnostic colonoscopy after screening FS compared to whites (72%).384

The data are mixed for differences in uptake by sex, such that there does not appear to be a consistent pattern or difference in men versus women.366 However, one recent study using 2007 data from the California Health Interview Survey found that women were less likely to undergo CRC screening than men.385 Uptake was about 26 percent in men versus 24 percent in women for FOBT, 18 percent in men and 15 percent in women for FS, and 50 percent in men and 48 percent in women for colonoscopy. One recent study using Medicare data from 2001–2005 also found lower colonoscopy screening uptake in women.386 One comprehensive existing review focusing on adherence to screening (mainly stool testing) found no consistent pattern or difference by sex.369 Another meta-analysis of FIT screening studies demonstrated lower uptake in men than in women.387

#### Targeted or Tailored Screening

Current CRC screening recommendations are made for all adults, except for differentiation based on age and family history. Those without a family history are recommended to begin CRC screening at age 50 years, the age at which CRC incidence begins to substantially increase. The concept of further customizing CRC screening recommendations has become more compelling as we have learned more about differences by age, sex, and race/ethnicity in the epidemiology of precancerous lesions and CRC.59,388–390 Targeted screening recommendations could potentially address the timing of screening initiation, preferred screening method(s), or both. In theory, tailoring screening recommendations has the potential to improve patient health outcomes, although no empirical data to support this exist at this time. Modeling exercises may be helpful in understanding the net benefit of earlier screening or different preferred screening modalities by age, sex, race/ethnicity, or combinations thereof.

Despite the large range in risk and known risk factors for CRC, risk prediction for CRC is suboptimal, and to date, there is no accepted risk assessment tool to help tailor CRC screening.69 Based on the higher incidence of CRC in blacks (and Native Americans and Alaskan Natives, based on less data), the American College of Gastroenterology and other experts have advocated to consider screening in blacks beginning at age 45 years.391,392 One microsimulation model evaluated tailored screening by race/ethnicity and sex and found that earlier screening in black men and women (age 47 vs. 53 years in whites) could marginally improve life expectancy.393

Others have advocated for different preferred screening methods in blacks and women due to a higher prevalence of proximal cancers. Colonoscopy, as opposed to FS, is associated with a decreased CRC mortality for both proximal and distal cancers, albeit somewhat attenuated for proximal cancers.38–42,394 FS is no longer commonly used in the United States, however, and there is currently no evidence to demonstrate that colonoscopy is more sensitive than stool-based testing or CTC for the detection of proximal cancers. Based on limited/sparse data, both gFOBT and FITs may have higher sensitivity for distal versus proximal CRC,162,186,191,395,396 but results are mixed and there is evidence to suggest that FITs are equally as sensitive for distal and proximal CRC.164 Even less data exist for CTC, as screening CTC studies were not designed or powered to evaluate detection of CRC. One small study (n=307) did not find any variation in sensitivity to detect advanced adenomas by location in colon.49

Overall CRC incidence, and for proximal cancers specifically, is more common with advancing age. Evidence from our review, as well as others, however, that colonoscopy has increasing serious harms with advancing age. The greatest evidence for harms and inadequate bowel preparation is in the very old (age ≥80 years).397 The optimal screening modality for older adults and age to stop screening are beyond the scope of this review. Again, modeling exercises may be helpful in understanding the tradeoff between the different screening modalities as both cancers and harms from colonoscopy become increasingly common with aging. Modeled data show that the net benefit of screening diminishes with age due to competing comorbidity, harms associated with screening, and natural life expectancy.397–399 In 2008, the USPSTF considered modeled data showing that while increases in life expectancy were considerably lower in adults age 75 years and older,398,400 the number and severity of comorbid medical conditions (or comorbidity index) were equally important factors influencing the decision on when to stop screening, as these comorbid conditions adversely affect one’s prognosis after discovery of CRC (e.g., competing source of mortality, worse survival after cancer treatment).397

## Limitations of the Review

Our review focused on the benefit of CRC screening on mortality, the diagnostic performance of generally available CRC screening tests, and the potential serious harms of these screening tests in average-risk adults. Because of limitations in resources, our review addressed some important contextual issues related to screening (e.g., adherence to testing) but could not address several other important issues, including: screening in high-risk adults (those with known family history of CRC), risk assessment to tailor screening, test acceptability, availability/access to screening tests, methods to increase screening adherence, potential harms of overdiagnosis or unnecessary polypectomy, overscreening or misuse of screening, and surveillance after screening. Our review was commissioned along with microsimulation decision models from CISNET, which address ages to start and stop screening, intervals of screening, and targeted/tailored screening. Given our audience, we limited our review to evidence conducted in countries with the highest applicability to U.S. practice. And given resource limitations, only articles published in English were considered for inclusion.

When appropriate, we conducted quantitative analyses. In many instances these analyses were limited by a relatively small number of studies (<10) and/or by high statistical heterogeneity, despite limited clinical heterogeneity allowing for pooled analyses. In synthesizing the evidence on FITs, we, unlike others, did not conduct quantitative analyses due to the very limited number of studies evaluating like FITs using similar study designs. We specifically compared similar tests, as FITs are not a class of tests, with similar assay cutoff values. Finding cutoff values expressed in units comparable across studies (μg Hb/g feces), however, was often difficult. Ultimately, we found that assay cutoff value expressed in μg Hb/g feces did not consistently predict assay performance. This deviated from the conclusions of a meta-analysis of all FIT types,306 likely due to the difference in included studies (we excluded four studies included by Lee and colleagues and included an additional seven studies) and our inability to verify a few of the cutoff values in μg Hb/g feces reported by Lee and colleagues. Last, to illustrate range of performance of FITs, our synthesis included FITs that are now discontinued and several that are not available in the United States and not cleared by the FDA. Additional limitations for each body of evidence are detailed in our summary of evidence table (Table 29).

## Emerging Issues and Future Research Needs

Screening for CRC is a complex and active area of research. Unlike other routinely recommended/conducted cancer screening, there are multiple viable options for CRC screening, with varying levels of evidence to support their use; aim to detect cancers, potential precursor lesions, or both; test acceptability and adherence; intervals of time to repeat screening; need for followup testing (including surveillance incurred); associated serious harms; availability in practice; cost; and advocacy for their use. The best quality evidence, in terms of robust study design and reduction in mortality, is limited to modalities that are no longer routinely used for screening in the United States. Several ongoing trials may fill this evidence gap for currently used tests (Appendix F). This complexity is compounded by technological advancements over time (i.e., to existing tests such as colonoscopy or CTC, and development of new stool or blood tests). Modeling exercises can provide valuable insight into the comparative net benefit of tests in the face of this complexity and (rapid) technological advancements over time. Models synthesize available data to inform the effectiveness of a wider range of testing modalities than possible in practice, including evaluation of newer tests, different test intervals, and different target populations (e.g., average and high risk). Models can, and should, incorporate best evidence about the operating characteristics of new tests. However, because models are based on best available evidence and understanding of disease, they also reflect limitations in our understanding of disease processes. For example, important evidence gaps include our understanding of the clinical importance of smaller lesions (<10 mm), the role of sessile serrated polyps in both the natural history of disease and the performance of screening tests, variation in the disease process across the large intestine (rectum, distal and proximal colon), and variation in the disease process across individuals by age, sex, and race/ethnicity.

We need empirical studies, trials, or well-designed cohort studies in average-risk populations to evaluate the effects of programs of screening using colonoscopy, the best-performing FITs, and CTC on cancer mortality and incidence. These studies should report (if applicable) on the number of screening rounds, intervals of testing, test positivity (with explicit criteria or cutoff values used to define test positivity), adherence to screening and followup, and harms or other burdens of testing incurred. In addition, we need diagnostic accuracy studies to confirm the screening test performance of promising stool tests based on high sensitivity to detect CRC and/or advanced adenomas (e.g., MonoHaem [three stool samples], QuickVue, Hemosure, bioNexia, immoCARE-C, PreventID CC, Hemo Techt NS-Plus, and HM-JACK) with thus far limited reproducibility (i.e., only one study). Likewise, additional diagnostic accuracy studies of screening tests incorporating new technologies with a limited evidence base (e.g., mtsDNA, serum mSEPT9) is also needed, with reporting of percent inadequate or indeterminant results. It is also important that we understand the contribution of technological advancements to existing technology (e.g., enhancements to optical colonoscopy or CTC) on test performance in average-risk adults as well as on reducing harms (e.g., decreasing radiation exposure, less aggressive bowel preparation). Last, the clinical impact of the identification of extracolonic findings remains unknown. More complete and consistent reporting of the downstream benefits and harms from the initial detection (subsequent workup and definitive treatment) of C-RADS E3 and E4 findings need to be published in observational studies or trials with longer-term followup.

## Conclusion

CRC screening continues to be a necessary and active field of research. Since the 2008 USPSTF recommendation, we have more evidence on 1) the effectiveness of FS on reducing CRC mortality, 2) the test performance of screening CTC and decreasing radiation exposure from CTC, and 3) the test performance of a number of promising FITs, including one FIT plus stool DNA test, that are available in the United States and approved by the FDA for screening. Currently used screening modalities, including colonoscopy, FS, CTC, and various high- sensitivity stool-based tests each have different levels of evidence to support their use, different test performance to detect cancer and precursor lesions, and different risks of harms. At this time, comparative studies of the different screening tests cannot answer questions of the relative benefit and harms (tradeoffs) between the tests. Recommendations regarding which screening tests to use, or if there is a hierarchy of preferred screening tests, will depend on the decisionmaker’s criteria for sufficiency of evidence and weighing the net benefit. Actual implementation of recommendations will depend on a number of additional factors, including patient preference and available resources.