# Results

## Key Question 1 What Is the Effectiveness of Screening Programs in Reducing Incidence of and Mortality From CRC?

We included 25 unique fair- to good-quality studies41,109–132 (published in 47 articles41,109–154) to assess the effectiveness or comparative effectiveness of screening tests on CRC incidence and mortality (Table 4). We found one cohort study that examined the effectiveness of screening colonoscopy, four RCTs that examined the effectiveness of FS, no studies that examined the effectiveness of CTC, six trials that examined the effectiveness of Hemoccult II gFOBT, and no studies that examined the effectiveness of high-sensitivity gFOBT, FIT, mtsDNA, or blood tests. Additionally, we found 15 comparative effectiveness studies that were primarily designed to assess the relative uptake and CRC yield between different screening modalities. None of these studies provided mortality data and, generally, these studies were not powered to detect differences in CRC detection.

Table 4 Included Studies for Key Question 1 (Mortality and/or Cancer Incidence)^‡^

Study Design | Colonoscopy | FS | CTC | gFOBT | FIT
Trials (screening versus no screening) | None | Holme, 2014^143^ (NORCCAP) Schoen, 2012^122^ (PLCO) Weissfeld, 2005^154^ Segnan, 2011^124^ (SCORE) Segnan, 2002^149^ Atkin, 2010^109^ (UKFSST) Atkin, 2002^133^ | None | Shaukat, 2013^127^ (Minnesota Study) Mandel, 2000^146^ Mandel, 1993^†,147^ Thomas, 1995^150^ Scholefield, 2012^123^ (Nottingham) Hardcastle, 1996^†,142^ Malila, 2011^119^ Malila, 2008^145^ Lindholm, 2008^†,118^ Faivre, 2004^113^ Kronborg, 2004^†,117^ (Hemoccult II) | None
Comparative effectiveness trials | Quintero, 2012^120^ (COLONPREV) Parra-Blanco, 2006^148^ Stoop, 2012^128^ (COCOS) Segnan, 2007^125^ (SCORE III) | Hol, 2010^*,116^ Hol, 2009^401^ Hol, 2010^402^ Segnan, 2007^125^ (SCORE III) Segnan, 2005^126^ (SCORE II) Rasmussen, 1999^121^ Verne, 1998^131^ Berry, 1997^110^ Brevinge, 1997^111^ | Stoop, 2012^128^ (COCOS) | Hol, 2010^*,116^ Hol, 2009^401^ Hol, 2010^402^ van Rossum, 2008^130^ Rasmussen, 1999^121^ Verne, 1998^131^ Berry, 1997^110^ Brevinge, 1997^111^ | Zubero, 2014^132^ van Roon, 2013^*,129^ van Roon, 2011^152^ Quintero, 2012^120^ (COLONPREV) Hol, 2010^*,116^ Hol, 2009^401^ Hol, 2010^402^ van Rossum, 2008^130^ Denters, 2012^137^ Denters, 2009^138^ Segnan, 2007^125^ (SCORE III) Segnan, 2005^126^ (SCORE II)
Observational | Nishihara, 2013^41^ (HPS, NHS) | None | None | Hamza, 2013^115^ Faivre, 2012^112^ Faivre, 2012^139^ Guittet, 2009^114^ Guittet, 2012^140^ Guittet, 2009^141^ | Hamza, 2013^115^ Faivre, 2012^112^ Faivre, 2012^139^ Guittet, 2009^114^ Guittet, 2012^140^ Guittet, 2009^141^

* Overlapping study populations

† Included in the 2008 USPSTF review73

‡ No included studies for mtsDNA or mSEPT9

Abbreviations: COCOS = COlonoscopy or COlonography for Screening; CTC = computed tomographic colonography; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; HPS = Health Professionals Study; NHS = Nurses’ Health Study; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; UKFSST = UK Flexible Sigmoidoscopy Screening Trial.

### Overall Summary

Well-conducted trial data for one- or two-time FS and stool-based screening programs using Hemoccult II have demonstrated a reduction in CRC mortality and incidence (Table 5). Based on four RCTs (n=458,002) that used intention-to-treat analyses, one- or two-time FS consistently decreased CRC-specific mortality compared to no screening at 11 to 12 years of followup (IRR, 0.73 [95% CI, 0.66 to 0.82]). Based on five RCTs (n=404,396) that used intention-to-treat analyses, biennial screening with Hemoccult II resulted in reduction of CRC-specific mortality compared to no screening, ranging from 9 to 22 percentage points after two to nine rounds of screening with 11 to 30 years of followup (relative risk [RR], 0.91 [95% CI, 0.84 to 0.98] at 19.5 years; RR, 0.78 [95% CI, 0.65 to 0.93] at 30 years). Based on one of these trials, conducted in the United States, annual screening with Hemoccult II after 11 rounds of screening resulted in greater reductions (RR, 0.68 [95% CI 0.56, 0.82]) at 30 years than biennial screening. We found no trials (currently underway) and only one large observational study for the effectiveness of colonoscopy on CRC incidence and mortality. After 24 years of followup, one prospective cohort (n=88,902) found the CRC-specific mortality rate was lower in persons who self-reported at least one screening colonoscopy (multivariate adjusted HR, 0.32 [95% CI, 0.24 to 0.45]) compared to those who had never had screening endoscopy. We could not directly compare the magnitude of benefit in CRC mortality and cancer incidence across tests because of major differences in study design across bodies of literature examining various test types. To date, no CRC screening modality has been shown to reduce all-cause mortality. While no RCTs evaluating the mortality benefit of newer, more sensitive stool testing currently exist, these population-based RCTs of newer stool testing may not be necessary because evidence-based reasoning supports that screening with stool tests with sensitivity and specificity that are as good as, or better than, Hemoccult II would result in CRC mortality reductions similar or better than reductions shown with Hemoccult II.

Table 5 Key Question 1: Overall Summary of Impact of Screening on Colorectal Cancer Incidence and Mortality

Screening test (total #studies, design) (Sample n) | | # rounds | CRC incidence | f/u | CRC mortality | f/u
Screening versus no screening | Colonoscopy (k=1, cohort) (n=88,902) | 1 | Total | 22y | Total | 24 y
Screening versus no screening | Colonoscopy (k=1, cohort) (n=88,902) | 1 | w/polypectomy HR, adj: 0.53 (95% CI, 0.40 to 0.71)^*^ | 22y | HR, adj: 0.32 (95% CI, 0.24 to 0.45)^*^ | 24 y
Screening versus no screening | Colonoscopy (k=1, cohort) (n=88,902) | 1 | negative colo HR, adj: 0.47 (95% CI, 0.39 to 0.57)^*^ | 22y | Distal | 24 y
Screening versus no screening | Colonoscopy (k=1, cohort) (n=88,902) | 1 | Distal | 22y | HR, adj: 0.18 (95% CI, 0.10 to 0.31)^*^ | 24 y
Screening versus no screening | Colonoscopy (k=1, cohort) (n=88,902) | 1 | w/polypectomy HR, adj: 0.37 (95% CI, 0.23 to 0.61)^*^ | 22y | Proximal | 24 y
Screening versus no screening | Colonoscopy (k=1, cohort) (n=88,902) | 1 | negative colo HR, adj: 0.29 (95% CI, 0.21 to 0.39)^*^ | 22y | HR, adj: 0.47 (95% CI, 0.29 to 0.76)^†^ | 24 y
Screening versus no screening | Colonoscopy (k=1, cohort) (n=88,902) | 1 | Proximal | 22y | | 24 y
Screening versus no screening | Colonoscopy (k=1, cohort) (n=88,902) | 1 | w/polypectomy HR, adj: 0.79 (95% CI, 0.52 to 1.19)^*^ | 22y | | 24 y
Screening versus no screening | Colonoscopy (k=1, cohort) (n=88,902) | 1 | negative colo HR, adj: 0.29 (95% CI, 0.21 to 0.39)^*^ | 22y | | 24 y
Screening versus no screening
Screening versus no screening | FS (k=4, RCT) (n=458,002) | 1–2 Q3–5y | Total | 11–12y | Total | 11–12y
Screening versus no screening | FS (k=4, RCT) (n=458,002) | 1–2 Q3–5y | IRR 0.79 (95% CI, 0.75 to 0.85) | 11–12y | IRR 0.73 (95% CI, 0.66 to 0.82) | 11–12y
Screening versus no screening | FS (k=4, RCT) (n=458,002) | 1–2 Q3–5y | Distal | 11–12y | Distal | 11–12y
Screening versus no screening | FS (k=4, RCT) (n=458,002) | 1–2 Q3–5y | IRR 0.71 (95% CI, 0.64 to 0.82) | 11–12y | IRR 0.63 (95% CI, 0.49 to 0.84) | 11–12y
Screening versus no screening | FS (k=4, RCT) (n=458,002) | 1–2 Q3–5y | Proximal | 11–12y | Proximal | 11–12y
Screening versus no screening | FS (k=4, RCT) (n=458,002) | 1–2 Q3–5y | IRR 0.92 (95% CI, 0.84 to 1.02) | 11–12y | IRR 0.90 (95% CI, 0.77 to 1.04) | 11–12y
Screening versus no screening
Screening versus no screening | Hemoccult II (k=5, RCT) (n=404,396) | 2–9 Q2y | Total | 11–28y | Total | 11–30y
Screening versus no screening | Hemoccult II (k=5, RCT) (n=404,396) | 2–9 Q2y | RR range from 0.90 (95% CI, 0.77 to 1.04) from 1.02 (95% CI, 0.93 to 1.12) | 11–28y | RR range from 0.78 (95% CI, 0.65, 0.93) to 0.91 (95% CI, 0.84, 0.98)^‡^ | 11–30y
Screening versus no screening | Hemoccult II (k=5, RCT) (n=404,396) | 2–9 Q2y | Distal | 11–28y | Distal | 11–30y
Screening versus no screening | Hemoccult II (k=5, RCT) (n=404,396) | 2–9 Q2y | NR | 11–28y | NR | 11–30y
Screening versus no screening | Hemoccult II (k=5, RCT) (n=404,396) | 2–9 Q2y | Proximal | 11–28y | Proximal | 11–30y
Screening versus no screening | Hemoccult II (k=5, RCT) (n=404,396) | 2–9 Q2y | NR | 11–28y | NR | 11–30y

* Adjusted for: age, BMI, family history, smoking status, physical activity, diet, vitamin use, aspirin use, NSAID use, cholesterol-lowering drug use, hormone replacement therapy

‡ Annual RR from one trial only 0.68 (0.56, 0.82), 11 rounds, q1y, 30 y follow-up

Abbreviations: adj = adjusted; CI = confidence interval; f/u = followup; HR = hazard ratio; IRR = incidence rate ratio; k = number of studies; n = number; NR = not reported; Q = interval; RCT = randomized controlled trial; RR = relative risk; w/ = with; y = years

Comparative effectiveness studies comparing one screening modality to another are limited to the evaluation of a single round of screening, with low CRC yield (number of cancers detected) and few interval cancers reported. Therefore, these studies do not provide robust direct evidence of comparative benefit on CRC incidence or mortality outcomes.

Based on a single fair-quality prospective cohort study, colonoscopy (as opposed to FS) appears to have mortality benefit for both proximal and distal CRC. Four large FS RCTs confirm that this mortality benefit is limited to distal CRC. Data on subgroups by age and sex are limited and provide mixed findings about possible differential benefit. While one gFOBT trial and three FS trials suggest greater benefits in men than in women, interaction testing for these results was not statistically significant, when reported. The differences in benefit may be due to higher incidence of cancer and cancer-related mortality in men, greater number of proximal cancers in women, or unknown confounders, since randomization in the trials was not stratified by sex.

### Detailed Results

#### Colonoscopy

We found no trials that evaluated the efficacy of screening colonoscopy to reduce CRC and/or mortality. We found one fair-quality prospective cohort study (n=88,902) that evaluated the impact of lower endoscopy on CRC incidence and mortality.41 Using data from two large cohorts in 1988, the Nurses’ Health Study (57,166 women) and the Health Professionals Followup Study (31,736 men), Nishihara and colleagues analyzed the association of screening colonoscopy and FS with the risk of CRC over 22 years and CRC mortality over 24 years. Among this select group of health care professionals, receipt of and reason for endoscopy (e.g., screening) were determined via self-report as part of a questionnaire administered every 2 years. Using a random sample of participants, investigators showed a high concordance of self-report and medical records. Seventy-three percent of endoscopies were performed for screening, including those performed for family history of CRC.

All analyses were stratified by age and sex. Multivariate analyses further adjusted for known or potential risk factors for CRC (i.e., body mass index, smoking status, first-degree relative with CRC, physical activity level, total red meat intake, total calorie intake, alcohol consumption, folate intake, calcium intake, multivitamin use, and regular use of aspirin, nonsteroidal anti-inflammatory drugs, cholesterol-lowering drugs, and hormone replacement therapy). Given the potential selection bias of persons receiving endoscopy versus those who did not, investigators conducted additional CRC incidence analyses adjusting for the propensity scores. Propensity score adjustment analyses were consistent with reported results. Investigators stated that they did not conduct any post hoc analyses. Nonetheless, given the study design, investigators could not address unknown or unmeasured confounders. Other limitations include the measurement of “screening” colonoscopy; thus, it is unclear if the benefit is from a single colonoscopy, multiple colonoscopies, or screening plus surveillance colonoscopies. Because of the nature of this study design, one cannot directly compare the magnitude of effect (association) measured in this observational study with the relative risk reduction measured in the intention-to-treat analyses from RCT trials of other CRC screening tests (i.e., FS, Hemoccult II).

During 24 years of followup, there were 474 deaths due to CRC. The CRC-specific mortality rate was lower in persons with self-reported screening colonoscopy (multivariate HR, 0.32 [95% CI, 0.24, 0.45]) and screening FS (multivariate HR, 0.59 [95% CI, 0.45 to 0.76]) compared to those who had never had screening endoscopy. Results were similar for men and women. Outcomes for all-cause mortality were not reported. This study found that screening colonoscopy was associated with reduced CRC mortality from both distal CRC (multivariate HR, 0.18 [95% CI, 0.10 to 0.31]) and proximal CRC (multivariate HR, 0.47 [95% CI, 0.29 to 0.76]) but FS was not.

During 22 years of followup, there were a total of 1,815 incident cases of CRC. Cancer incidence was lower in persons with self-reported screening endoscopy with polypectomy (multivariate HR, 0.53 [95% CI, 0.40 to 0.71]), negative screening colonoscopy (multivariate HR, 0.47 [95% CI, 0.39 to 0.57]), and negative screening FS (multivariate HR, 0.56 [95% CI, 0.49 to 0.65]) compared to those who had never had screening endoscopy. Results were similar for men and women. Reduction in cancer incidence was observed across all stages of CRC at presentation. Only negative screening colonoscopy was associated with reduced incidence of proximal CRC (multivariate HR, 0.74 [95% CI, 0.57 to 0.96]).

#### FS

We found five trials that evaluated the efficacy of screening FS to reduce CRC and/or mortality. We excluded one early pilot trial that was conducted in Norway (n=399 screened, n=400 control) for poor quality because of a number of limitations (e.g., no true randomization, small study sample, potentially nonrepresentative sample, low adherence, and crossover).17 All four of the fair-quality RCTs (n=458,002) we included were published after the previous USPSTF recommendation (Table 6).109,122,124,143

Table 6 Key Question 1: FS Summary of Effectiveness on Colorectal Cancer Incidence and Mortality From Large Randomized, Controlled Trials

Trial, Year of publication | NORCCAP, 2014^143^ | PLCO, 2012^122,154^ | SCORE, 2011^124,149^ | UKFSST, 2010^109,133^
Country | Norway | US | Italy | UK
Targeted Age, years | 50–64 | 55–74 | 55–64 | 55–64
Program n | IG: 20,572 | IG: 77,445 | IG: 17,136 | IG: 57,099
Program n | CG: 78,220 | CG: 77,455 | CG: 17,136 | CG: 112,939
Number of rounds | 1 | 2 | 1 | 1
Median length of followup, years | 11.2 (IG), 10.9 (CG) | 11.9 (incidence), 12.1 (mortality) | 10.5 (incidence), 11.4 (mortality) | 11.2
Attendance to screening, % | 63 | 1st Screen: 84 2nd Screen: 54 | 58 | 67
CRC, n/n (%) | 1339/98,792 (1.4) | 2299/154,900 (1.5) | 557/34,272 (1.6) | 2524/170,038 (1.5)
Criteria for colonoscopy | Polyp ≥10 mm; adenoma; CRC; positive FOBT | Polyp or mass was detected | Advanced adenoma; CRC; ≥3 adenomas; ≥5 hyperplastic polyps above rectum; inadequate bowel prep with ≥1 polyp | Advanced adenoma; CRC; ≥3 adenomas; ≥20 hyperplastic polyps above rectum
Referred to Colonoscopy, % | 20.4 | 32.9 | 8.6 | 5.2
CRC Incidence rate, per 100,000 p-y RR (95% CI) | Total | Total | Total | Total
CRC Incidence rate, per 100,000 p-y RR (95% CI) | IG: 114.3^‡^ | IG: 119 | IG: 144.1 | IG: 114
CRC Incidence rate, per 100,000 p-y RR (95% CI) | CG: 131.1^‡^ | CG: 152 | CG: 176.4 | CG: 149
CRC Incidence rate, per 100,000 p-y RR (95% CI) | 0.87 (0.76, 1.00)^*^¥ | 0.79 (0.72, 0.85) | 0.82 (0.69, 0.97)^*^ | 0.77 (0.70, 0.84)
CRC Incidence rate, per 100,000 p-y RR (95% CI) | Distal | Distal | Distal | Distal
CRC Incidence rate, per 100,000 p-y RR (95% CI) | IG: 61.9^‡^ | IG: 56 | IG: 87.3 | IG: 62
CRC Incidence rate, per 100,000 p-y RR (95% CI) | CG: 75.0^‡^ | CG: 79 | CG: 114.2 | CG: 98
CRC Incidence rate, per 100,000 p-y RR (95% CI) | 0.83 (0.69, 0.99)^*^ | 0.71 (0.64, 0.80) | 0.76 (0.62, 0.94) | 0.64 (0.57, 0.72)
CRC Incidence rate, per 100,000 p-y RR (95% CI) | Proximal | Proximal | Proximal | Proximal
CRC Incidence rate, per 100,000 p-y RR (95% CI) | IG: 50.6^‡^ | IG: 60 | IG: 56.8 | IG: 50
CRC Incidence rate, per 100,000 p-y RR (95% CI) | CG: 51.2^‡^ | CG: 70 | CG: 62.3 | CG: 51
CRC Incidence rate, per 100,000 p-y RR (95% CI) | 0.99 (0.80, 1.22)^*^ | 0.86 (0.76, 0.97) | 0.91 (0.69, 1.20) | 0.98 (0.85, 1.12)
CRC Incidence rate, per 100,000 p-y RR (95% CI) | Men | Men | Men | Men
CRC Incidence rate, per 100,000 p-y RR (95% CI) | IG: 115.6 (age-adjusted) | IG: 136 | IG: 190.9 | IG: 142.4
CRC Incidence rate, per 100,000 p-y RR (95% CI) | CG: 157.6 (age-adjusted) | CG: 185 | CG: 216.8 | CG: 191.1
CRC Incidence rate, per 100,000 p-y RR (95% CI) | 0.73 (0.60, 0.89) (HR) | 0.73 (0.66, 0.82) | 0.88 (0.71, 1.09) | 0.75 (0.67, 0.83)^*^
CRC Incidence rate, per 100,000 p-y RR (95% CI) | Women | Women | Women | Women
CRC Incidence rate, per 100,000 p-y RR (95% CI) | IG: 109.6 (age-adjusted) | IG: 103 | IG: 98.5 | IG: 88.4
CRC Incidence rate, per 100,000 p-y RR (95% CI) | CG: 125.5 (age-adjusted) | CG: 120 | CG: 136.1 | CG: 110.3
CRC Incidence rate, per 100,000 p-y RR (95% CI) | 0.87 (0.72, 1.06) (HR) | 0.86 (0.76, 0.98) | 0.72 (0.55, 0.96) | 0.80 (0.70, 0.92)^*^
CRC Mortality rate, per 100,000 p-y RR (95% CI) | Total | Total | Total | Total
CRC Mortality rate, per 100,000 p-y RR (95% CI) | IG: 31.9^‡^ | IG: 29 | IG: 34.7 | IG: 36
CRC Mortality rate, per 100,000 p-y RR (95% CI) | CG: 39.7^‡^ | CG: 39 | CG: 44.5 | CG: 52
CRC Mortality rate, per 100,000 p-y RR (95% CI) | 0.80 (0.62, 1.04)^*^ | 0.74 (0.63, 0.87) | 0.78 (0.56, 1.08) | 0.69 (0.59, 0.80)^*^
CRC Mortality rate, per 100,000 p-y RR (95% CI) | Distal | Distal | Distal | Distal †
CRC Mortality rate, per 100,000 p-y RR (95% CI) | IG: 17.5^‡^ | IG: 10 | IG: 18.7 | IG: 14.8
CRC Mortality rate, per 100,000 p-y RR (95% CI) | CG: 20.2^‡^ | CG: 20 | CG: 25.7 | CG: 25.4
CRC Mortality rate, per 100,000 p-y RR (95% CI) | 0.87 (0.61, 1.23)^*^ | 0.50 (0.38, 0.64) | 0.73 (0.47, 1.12) | 0.58 (0.46, 0.74)^*^
CRC Mortality rate, per 100,000 p-y RR (95% CI) | Proximal | Proximal | Proximal | Proximal †
CRC Mortality rate, per 100,000 p-y RR (95% CI) | IG: 13.5^‡^ | IG: 16 | IG: 16.0 | IG: 14.8
CRC Mortality rate, per 100,000 p-y RR (95% CI) | CG: 16.7^‡^ | CG: 17 | CG: 18.7 | CG: 16.9
CRC Mortality rate, per 100,000 p-y RR (95% CI) | 0.81 (0.54, 1.20)^*^ | 0.97 (0.77, 1.22) | 0.85 (0.52, 1.39) | 0.87 (0.68, 1.12)^*^
CRC Mortality rate, per 100,000 p-y RR (95% CI) | Men | Men | | Men †
CRC Mortality rate, per 100,000 p-y RR (95% CI) | IG: 28.6 (age-adjusted) | IG: 32 | | IG: 38.1
CRC Mortality rate, per 100,000 p-y RR (95% CI) | CG: 49.1 (age-adjusted) | CG: 49 | | CG: 57.4
CRC Mortality rate, per 100,000 p-y RR (95% CI) | 0.58 (0.40, 0.85) (HR) | 0.66 (0.53, 0.81) | | 0.66 (0.54, 0.82)^*^
CRC Mortality rate, per 100,000 p-y RR (95% CI) | Women | Women | | Women †
CRC Mortality rate, per 100,000 p-y RR (95% CI) | IG: 34.2 (age-adjusted) | IG: 26 | | IG: 23.4
CRC Mortality rate, per 100,000 p-y RR (95% CI) | CG: 37.4 (age-adjusted) | CG: 29 | | CG: 31.4
CRC Mortality rate, per 100,000 p-y RR (95% CI) | 0.91 (0.64, 1.30) (HR) | 0.87 (0.68, 1.12) | | 0.74 (0.57, 0.97)^*^
All-cause Mortality rate, per 100,000 p-y RR (95% CI) | Total | NR | Total | Total
All-cause Mortality rate, per 100,000 p-y RR (95% CI) | IG: 980.3^‡^ | | IG: 644.2 | IG: 1093
All-cause Mortality rate, per 100,000 p-y RR (95% CI) | CG: 932.9^‡^ | | CG: 666.1 | CG: 1124
All-cause Mortality rate, per 100,000 p-y RR (95% CI) | 1.05 (1.00, 1.10)^‡^ | | 0.97 (0.89, 1.05)^*^ | 0.97 (0.94, 1.00)

* Calculated RR, not study reported

† Data provided by author from personal communication

‡ Data presented here does not match study reported rates due to study adjustment for age

¥ Age-adjusted cancer incidence difference reported in the publication is statistically significant

Abbreviations: CG = control group; CI = confidence interval; FOBT = fecal occult blood test; HR = hazard ratio; IG = intervention group; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; p-y = person-years; RR = relative risk; SCORE = Screening for COlon Rectum; UK = United Kingdom; UKFSST = UK Flexible Sigmoidoscopy Screening Trial; US = United States.

##### Population Characteristics

Only one included trial was conducted in the United States (Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial [PLCO]);122,154 the remaining three trials were conducted in Norway (Norwegian Colorectal Cancer Prevention [NORCCAP]),143 Italy (Screening for Colon Rectum [SCORE]),124,149 and the United Kingdom (U.K. Flexible Sigmoidoscopy Screening Trial [UKFSST]).109,133 All trials started in the 1990s and recruited average-risk adults between the ages of 50 and 74 years. The mean age at baseline across three of the trials was 56 to 60 years (PLCO did not report mean age at baseline but included participants ages 55–74 years). Only two trials reported the underlying percent of participants with family history of CRC, which was approximately 10 percent. One trial, UKFSST, explicitly excluded persons with two or more close relatives with CRC.109 The baseline prevalence of CRC in the trials ranged from 1.4 to 1.6 percent. All trials included an even mix of men and women. Only the U.S. trial, PLCO, reported the race/ethnicity of participants, and this trial included 14 percent nonwhite participants.122

##### FS Protocol

All four included trials evaluated screening FS with a limited bowel preparation (i.e., not a full bowel preparation required for colonoscopy). Two trials used a colonoscope instead of a flexible sigmoidoscope to conduct the FS.124,143 The screening protocol and criteria for referral to diagnostic colonoscopy varied between trials. NORCCAP evaluated FS with or without FIT testing (approximately half of the screening arm also received FIT testing).143 The other trials compared FS to a no-screening control group.109,122,124 PLCO evaluated screening with followup FS at 3 to 5 years. SCORE and UKFSST evaluated one-time FS.122 Referral to diagnostic colonoscopy varied across trials and was likely related to referral criteria:

- UKFSST (5.2% referred to colonoscopy), biopsy-based referral criteria: polyp 10 mm or larger, three or more adenomas, or high-risk findings (including tubulovillous or villous histology, severe dysplasia or malignancy, or ≥20 hyperplastic polyps)109
- SCORE (8.6% referred to colonoscopy), biopsy-based referral criteria: UKFSST criteria plus adenomas 6–9 mm124
- NORCCAP (20.4% referred to colonoscopy), biopsy-based referral criteria: any polyp 10 mm or larger, any adenoma (regardless of size), all CRC, and any positive FIT results143
- PLCO (32.9% referred to colonoscopy), visual (without biopsy) referral criteria: any lesion or polyp considered positive, patients referred to their primary care physician for decision on referral to diagnostic colonoscopy122

##### Study Quality

All included trials were very large fair-quality RCTs. Only PLCO had a traditional randomized trial design in which the control group participants gave consent and were enrolled in the trial. In the European trials, the control groups were not contacted and were unaware of their trial involvement. Adherence to screening ranged from about 58 to 83 percent for the initial FS. The highest adherence rate was observed in PLCO; however, adherence to the subsequent FS was much lower, about 54 percent. Only the PLCO trial reported CRC screening in the control group, and a large proportion of the control group (about 47%) was found to have had some type of lower gastrointestinal endoscopy during the screening phase (0–5 years).122 Details about the number, training, or quality parameters of the endoscopy or endoscopists were not consistently or commonly reported.

##### Outcomes

Despite some heterogeneity in the FS screening protocols, we found it reasonable to quantitatively pool results for reduction in mortality and cancer incidence because of generally similar study design/methods, population characteristics, and length of followup (median followup, approximately 11–12 years). Based on intention-to-treat analyses across the four trials, one-time FS consistently decreased CRC-specific mortality. The pooled IRR for CRC mortality for FS versus no screening across the four studies was 0.73 (95% CI, 0.66 to 0.82; I^2^=0%) (Figure 3). The outcome data from NORCCAP used in our meta-analyses differ slightly from that reported in the publication due to our preference for non–age-adjusted data (for consistency) and the primary publication’s reporting of age-adjusted results. While three of the four trials defined distal cancers to include the descending colon to the rectum, the UKFSST limited its definition of distal to the sigmoid colon and rectum. The pooled reduction in distal but not proximal CRC mortality was statistically significant (IRR, 0.63 [95% CI, 0.49 to 0.84]; I^2^=44.1%) (Figures 4 and 5). In NORCCAP, the FS plus FIT arm had lower CRC-specific mortality than the FS only arm (age-adjusted HR, 0.62 [95% CI, 0.42 to 0.90] vs. 0.84 [95% CI, 0.61 to 1.17], respectively).143 In PLCO, initial plus repeat FS at 3 or 5 years was effective in reducing CRC-specific mortality at about 12 years (RR, 0.74 [95% CI, 0.63 to 0.87]).122

Figure 3 Key Question 1: Forest Plot of FS Screening on Colorectal Cancer Mortality

Abbreviations: CI = confidence interval; IRR = incidence rate ratio; NORCCAP = Norwegian Colorectal Cancer Prevention; PL = Profile Likelihood; p-y = person-years; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; UKFSST = UK Flexible Sigmoidoscopy Screening Trial

* I^2^ = 0%

Figure 3 displays a forest plot of the effect of screening with flexible sigmoidoscopy on colorectal cancer mortality. The pooled incidence rate ratio for the four studies is 0.73 with a 95% CI of 0.66 to 0.82.

Figure 4 Key Question 1: Forest Plot of FS Screening on Distal Colorectal Cancer Mortality

Abbreviations: CI = confidence interval; c-scopy = colonoscopy; IRR = incidence rate ratio; NORCCAP = Norwegian Colorectal Cancer Prevention; PL = Profile Likelihood; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; p-y = person-years; SCORE = Screening for COlon Rectum; UKFSST = UK Flexible Sigmoidoscopy Screening Trial

* I^2^ = 44.1%

Figure 4 displays a forest plot of the effect of screening with flexible sigmoidoscopy on distal colorectal cancer mortality. The pooled incidence rate ratio for the four studies is 0.63 with a 95% CI of 0.49 to 0.84.

Figure 5 Key Question 1: Forest Plot of FS Screening on Proximal Colorectal Cancer Mortality

Abbreviations: CI = confidence interval; c-scopy = colonoscopy; IRR = incidence rate ratio; NORCCAP = Norwegian Colorectal Cancer Prevention; PL = Profile Likelihood; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; p-y = person-years; SCORE = Screening for COlon Rectum; UKFSST = UK Flexible Sigmoidoscopy Screening Trial

* I^2^ = 0%

Figure 5 displays a forest plot of the effect of screening with flexible sigmoidoscopy on proximal colorectal cancer mortality. The pooled incidence rate ratio for the four studies is 0.90 with a 95% CI of 0.77 to 1.04.

Three of the four trials that reported relevant results did not find reductions in all-cause mortality (Figure 6).109,124,143 PLCO did not report all-cause mortality outcomes.

Figure 6 Key Question 1: Forest Plot of FS Screening on All-Cause Mortality

Abbreviations: CI = confidence interval; IRR = incidence rate ratio; NORCCAP = Norwegian Colorectal Cancer Prevention; p-y = person-years; RE = restricted maximum likelihood; SCORE = Screening for COlon Rectum; UKFSST = UK Flexible Sigmoidoscopy Screening Trial

* I^2^ = 59.8%

Figure 6 displays a forest plot of the effect of screening with flexible sigmoidoscopy on all-cause mortality. The pooled incidence rate ratio for the three studies is 1.00 with a 95% CI of 0.94 to 1.06. These results are discussed further in the text.

Intention-to-treat analyses across the four trials consistently found that screening with FS decreased the incidence of CRC. The pooled IRR for CRC incidence for FS versus no screening was 0.79 (95% CI, 0.75 to 0.85; I^2^=0%) (Figure 7). Similar to findings on CRC mortality, the reduction in incidence for distal but not proximal CRC incidence was statistically significant (IRR, 0.71 [95% CI, 0.64 to 0.82]; I^2^=35.3%) (Figures 8 and 9).

Figure 7 Key Question 1: Forest Plot of FS Screening on Colorectal Cancer Incidence

Abbreviations: CI = confidence interval; IRR = incidence rate ratio; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; p-y = person-years; RE = restricted maximum likelihood; SCORE = Screening for COlon Rectum; UKFSST = UK Flexible Sigmoidoscopy Screening Trial

* I^2^ = 0%

Figure 7 displays a forest plot of the effect of screening with flexible sigmoidoscopy on colorectal cancer incidence. The pooled incidence rate ratio for the four studies is 0.79 with a 95% CI of 0.75 to 0.85.

Figure 8 Key Question 1: Forest Plot of FS Screening on Distal Colorectal Cancer Incidence

Abbreviations: CI = confidence interval; IRR = incidence rate ratio; NORCCAP = Norwegian Colorectal Cancer Prevention; PL = Profile Likelihood; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; p-y = person-years; SCORE = Screening for COlon Rectum; UKFSST = UK Flexible Sigmoidoscopy Screening Trial

* I^2^ = 35.3%

Figure 7 displays a forest plot of the effect of screening with flexible sigmoidoscopy on distal colorectal cancer incidence. The pooled incidence rate ratio for the four studies is 0.71 with a 95% CI of 0.64 to 0.82.

Figure 9 Key Question 1: Forest Plot of FS Screening on Proximal Colorectal Cancer Incidence

Abbreviations: CI = confidence interval; IRR = incidence rate ratio; NORCCAP = Norwegian Colorectal Cancer Prevention; PL = Profile Likelihood; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; p-y = person-years; SCORE = Screening for COlon Rectum; UKFSST = UK Flexible Sigmoidoscopy Screening Trial

* I^2^ = 0%

Figure 7 displays a forest plot of the effect of screening with flexible sigmoidoscopy on proximal colorectal cancer incidence. The pooled incidence rate ratio for the four studies is 0.92 with a 95% CI of 0.84 to 1.02

##### Subpopulations

Three trials (NORCCAP, PLCO, and UKFSST) reported CRC mortality estimated separately by age and/or sex (Table 6).109,122,143 All of these trials suggest that the benefit in mortality reduction may be greater for men than for women. PLCO also reported CRC mortality separately by age group. The finding of a greater CRC mortality reduction for older adults than for middle-aged adults, however, was not statistically significant.

All four trials reported CRC incidence separately by age and/or sex.109,122,124,143 Three of the four trials (NORCCAP, PLCO, UKFSST) estimated greater CRC incidence reduction for men than for women.109,122,143 Only PLCO reported statistic tests for differential effects of the intervention by sex, and these results showed borderline statistical significance (p=0.052).122 Two trials (PLCO, SCORE) reported subgroup analyses for older and middle-aged adults but found no statistically significant difference on cancer incidence between these age groups.122,124 Although trials were not powered to detect differential effects of FS across subgroups, results are suggestive of a stronger benefit in men than in women, which may be due to the fact that women had a lower proportion of screen-detected cancers and a higher proportion of proximal cancers than men. We did not conduct pooled analyses for subgroups, as randomization was not stratified by age or sex, and interaction testing for subgroup analyses was not statistically significant.

#### CTC

We found no studies evaluating the effectiveness of screening CTC on cancer incidence or mortality.

#### Stool Tests

##### gFOBT

We found six113,117–119,123,127 fair- to good-quality large population screening trials (reported in 11 articles;113,117–119,123,127,142,145–147,150 n=525,966) that evaluated the effectiveness of gFOBT, specifically Hemoccult II, on mortality (Table 7). While these trials are important for a historical and contextual understanding of CRC screening, our summary of results is brief because Hemoccult II is no longer widely used for CRC screening in the United States. Five of the six trials (conducted in France, Denmark, Sweden, United Kingdom, and the United States) are older trials with longer-term followup of mortality reported,113,117,118,123,127 while one newer trial in Finland has not yet reported mortality outcomes.119

Table 7 Key Question 1: Hemoccult II Summary of Effectiveness on Colorectal Cancer Incidence and Mortality From Large Controlled Trials

Trial, Year of publication | Burgundy, 2004^113^ | Funen, 2004^117^ | Göteborg, 2008^118^ | Finland, 2011^119,145^ | Nottingham, 2012^123,142^ | Minnesota Colon Cancer Control Study, 2013^127,146,147,150^
Country | France | Denmark | Sweden | Finland | England | US
Screen Frequency | Biennial | Biennial | Varied (1 to 9 years) | Biennial | Biennial | Biennial | Annual
Targeted Age | 45–74 | 45–75 | 60–64 | 60–69 | 45–74 | 50–80 | 50–80
Program n | SG: 45,642 CG: 45,557 | SG: 30,967 CG: 30,966 | SG: 34,144 CG: 34,164 | SG: 52,998 CG: 53,002 | SG: 76,056 CG: 75,919 | SG: 15,587 CG: 15,394 | SG: 15,570 CG: 15,394
Number of rounds | 6 | 9 | 2–3 | 2 | 3–5 | 6 | 11
Length of followup, years | 11 | 17 | 19 | 4 | 28 | 30 (18 for incidence) | 30 (18 for incidence)
Attendance to round 1 (%) | 53 | 67 | 62 | 70 | 53 | NR | NR
Attendance to at least 1 round (%) | 70 | 67 | 70 | 92 | 60 | 90 | 90
Round 1 test positivity, % | 2.1 | 1.0 | 3.8^‡^ | 2.3 | 2.1 | NR^‡^ | NR^‡^
All rounds test positivity, % | 1.5 | 1.5 | 4.1 | 2.5 | NR | NR^†^ | NR^†^
CRC in SG, n/n | 699/45,642 | 889/30,967 | 721/34,144 | 126/52,998 | 2279/76,056 | 435/15,550 | 417/15,532
CRC in CG, n/n | 696/45,557 | 874/30,966 | 754/34,164 | 98/53,002 | 2354/75,919 | 507/15,363 | 507/15,363
RR (95% CI) | 1.01 (0.91, 1.12) | 1.02 (0.93, 1.12) | 0.96 (0.86, 1.06) | 1.29 (0.98, 1.69)^*^ | 0.97 (0.91, 1.03) | 0.85 (0.74, 0.96)^*^ | 0.81 (0.71, 0.93)^*^
CRC deaths in SG, n/n | 254/45,642 | 362/30,967 | 252/34,144 | NR | 1176/76,056 | 237/15,587 | 200/15,570
CRC deaths in CG, n/n | 304/45,557 | 431/30,966 | 300/34,164 | NR | 1300/75,919 | 295/15,394 | 295/15,394
RR (95% CI) | 0.84 (0.71, 0.99) | 0.84 (0.73, 0.96) | 0.84 (0.71, 0.99) | NR | 0.91 (0.84, 0.98) | 0.78 (0.65, 0.93) | 0.68 (0.56, 0.82)
All-cause deaths in SG, n/n | NR | 12,205/30,967 | 10,591/34,144 | NR | 40,681/76,056 | 11,004/15,587 | 11,072/15,570
All-cause deaths in CG, n/n | NR | 12,248/30,966 | 10,432/34,164 | | 40,550/75,919 | 10,944/15,394 | 10,944/15,394
RR (95% CI) | NR | 0.99 (0.97, 1.02) | 1.02 (0.99, 1.06) | NR | 1.00 (0.99, 1.02) | 0.99 (0.98, 1.01) | 1.00 (0.99, 1.01)

* Calculated in Stata using iri; exact confidence interval

† From 1976 through 1982, the positivity for rehydrated tests was 9.8% and for tests without rehydration was 2.4%.

‡ Study included rehydrated tests: Göteborg – 91.7% of all tests were rehydrated; Minnesota Colon Cancer Control Study – 82.5% of all tests were rehydrated

Abbreviations: CG = control group; CI = confidence interval; CRC = colorectal cancer; n = number; NR = not reported; RR = relative risk; SG = screened group; US = United States.

Trials primarily evaluated biennial testing, although one also evaluated annual testing.127 Overall, biennial screening with Hemoccult II (k=5; n=404,396) resulted in reduction of CRC-specific mortality, from 9 to 22 percent after two to nine rounds of screening with 11 to 30 years of followup. Trials varied in screening protocols in terms of number of screening rounds, use of rehydrated samples (no longer used in practice), definition of “test positive” (i.e., number of test squares on each slide required to be positive for referral to additional testing), and recommended diagnostic followup for positive results (e.g., FS with or without DCBE, colonoscopy), and had different followup periods and adherence to screening and followup testing. The lowest CRC mortality reduction (RR, 0.91 [95% CI, 0.84 to 0.98] at 19.5 years) was observed in the Nottingham trial (n=151,975), which used three to five rounds of screening that had a higher threshold for test positivity than other gFOBT trials.123 This trial also had slightly lower adherence to testing after adjustment for nonadherence (of the first test). The RR for CRC mortality was equivalent to other studies (data not shown). The CRC mortality reduction observed in the Göteborg trial (n=68,308), which had two to three rounds of screening, was no longer statistically significant at 17 years of followup when deaths due to complications of CRC treatment were included (RR, 0.89 [95% CI, 0.78 to 1.01]).118 Since comparable data on treatment-related CRC deaths are not reported in the other trials, and very limited details about the underlying analysis are reported, this finding is difficult to interpret. Only two studies, Funen and Nottingham, reported CRC mortality by cancer location, and neither found a statistically significant difference in mortality reduction by proximal versus distal CRC.117,123

The Minnesota Colon Cancer Control Study showed that annual screening with Hemoccult II (n=30,964) resulted in reduction of CRC-specific mortality of 32 percent (RR, 0.68 [95% CI, 0.56 to 0.82]), with 11 rounds of screening and 30 years of followup.127

Overall, biennial or annual screening with Hemoccult II did not reduce all-cause mortality. This may be due to the relatively small number of CRC deaths that contribute to overall deaths, limiting the power of screening to affect the all-cause mortality estimates.

In two trials (n=213,908), Funen and Nottingham, CRC-specific mortality reductions were similar for both men and women.117,123 In the Minnesota trial (n=46,551), however, it appears that men had greater CRC-specific mortality reductions compared to women at 30 years of followup (for biennial: RR, 0.63 [95% CI, 0.48 to 0.82] in men vs. 0.92 [95% CI, 0.72 to 1.18] in women; p=0.04 for interaction).127

##### Other Stool Tests

We found no prospective studies evaluating the effectiveness of high-sensitivity gFOBT or FITs on cancer incidence or mortality.

#### Comparative Effectiveness of Different Screening Tests

We found 12 fair-quality trials110,111,116,120,121,125,126,128–132 (published in 16 articles110,111,116,120,121, 125,126,128–132,137,138,148,152) that examined the comparative effectiveness of different screening tests in average-risk screening populations (Table 8). We also found three fair-quality, large prospective cohort studies112,114,115 in six articles112,114,115,139–141 that examined the comparative effectiveness of gFOBT versus FIT in average-risk screening populations (Table 8).

Table 8 Key Question 1: Included Comparative Effectiveness Studies (Reverse Chronological Order)

Study Design | Study | Country | gFOBT | FIT | FS | Colonoscopy | CTC
Trials | Zubero, 2014^132^ | Spain | | X
Trials | van Roon, 2013^*,129^ | The Netherlands | | X^†^
Trials | Quintero, 2012^120,148^ (COLONPREV) | Spain | | X | | X
Trials | Stoop, 2012^128^ (COCOS) | The Netherlands | | | | X | X
Trials | van Roon, 2011^*,152^ | The Netherlands | | X^‡^
Trials | Hol, 2010^*,116^ | The Netherlands | X | X | X
Trials | van Rossum, 2008^130,137,138^ | The Netherlands | X | X
Trials | Segnan, 2007^125^ (SCORE III) | Italy | | X | X | X
Trials | Segnan, 2005^126^ (SCORE II) | Italy | | X | X^**^
Trials | Rasmussen, 1999^121^ | Denmark | X | | X^**^
Trials | Verne, 1998^131^ | UK | X | | X^**^
Trials | Berry, 1997^110^ | UK | X | | X^**^
Trials | Brevinge, 1997^111^ | Sweden | X | | X
Observational | Hamza, 2013^115^ | France | X | X
Observational | Faivre, 2012^112,139^ | France | X | X^‡^
Observational | Guittet, 2009^114,140,141^ | France | X | X

* Overlapping study populations

‡ Compare different number of samples

† Compare intervals

** Study includes a FS+FOBT comparison

Abbreviations: COCOS = COlonoscopy or COlonography for Screening; CTC = computed tomographic colonography; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; SCORE = Screening for COlon Rectum; UK = United Kingdom.

All studies were conducted in Western European countries. Trials were primarily designed to assess the differential uptake (adherence) of testing and relative detection of colorectal lesions. Although these trials include CRC outcomes, the trials are not powered to detect differences in CRC incidence and/or mortality. For example, approximately 6,000 participants per arm would be needed to detect a 0.3 percent difference in CRC incidence with 80 percent power, assuming 100 percent adherence. The trials that have been conducted generally had fewer than 6,000 participants per arm with less than 60 percent adherence to testing.

Because these studies are limited to the evaluation of a single round of screening, low CRC yield (number of cancers detected), and few interval cancers reported, they do not provide robust direct evidence of comparative benefit on CRC incidence or mortality outcomes. These studies are not discussed further, but more details are available in Appendix D.

## Key Question 2 What Are the Test Performance Characteristics of the Different Screening Tests for Detecting CRC, Advanced Adenomas, and/or Adenomatous Polyps Based on Size?

We included 33 unique diagnostic accuracy studies49–52,155–183 (published in 44 articles49–52,155–194) that evaluated CRC screening tests compared to an adequate reference standard (i.e., colonoscopy for adenomas and colonoscopy or robust clinical/registry followup for CRC) (Table 9). We found no diagnostic accuracy studies that compared colonoscopy or FS to a colonoscopy reference standard. In order to approximate test performance of screening tests in community practice, we excluded endoscopy studies primarily conducted in single-center research settings or those with a very limited number of endoscopists. We found nine unique studies that evaluated CTC as a screening modality (three of which were included in our prior review). Four of these nine CTC studies provided data on the diagnostic accuracy of screening colonoscopy conducted by more than just a limited number of endoscopists.50,52,169,183 We found 23 unique studies evaluating high-sensitivity stool-based testing,49,155–162,164,166–168,171–174,177–182 three evaluating high-sensitivity gFOBT,155,156,173 20 evaluating various different FITs,49,155–162,164,166–168,171–174,177–182 and one evaluating a mtsDNA test, which included a FIT component.167 In addition, we used a good-quality AHRQ-funded systematic review to summarize older stool-based DNA screening tests,175 which are no longer available. Finally, we identified only one diagnostic accuracy study that met our inclusion criteria that evaluated mSEPT9.^163^ All of these studies were designed to evaluate a single application of the screening test, as opposed to a program of screening.

Table 9 Included Studies for Key Question 2

Reference Standard | Colonoscopy | FS | CTC | High sensitivity gFOBT | FIT | sDNA +/−FIT | mSEPT9
Colonoscopy or enhanced colonoscopy | CTC studies with relevant colonoscopy data: Zalis, 2012^183^ Johnson, 2008 (ACRIN)50 Johnson,2012^193^ Johnson, 2007^*,169^ Pickhardt, 2003^*,52^ | None | Lefere, 2013^51^ Fletcher, 2013^165^ Zalis, 2012^183^ Graser, 2009^49^ Johnson, 2008^50^ (ACRIN) Johnson, 2012^193^ Kim, 2008^170^ Johnson, 2007^*,169^ Macari, 2004^*,176^ Pickhardt, 2003^*,52^ | None | Hernandez, 2014^166^ Imperiale, 2014^167^ SSED184 Lee, 2014^172^ Levy, 2014^174^ Brenner, 2013^157^ (BliTz) Haug, 2011^189^ Brenner, 2010^187^ Brenner, 2010^186^ Hundt, 2009^191^ Chiu, 2013^162^ Ng, 2013^180^ de Wijkerslooth, 2012^164^ (COCOS) Park, 2010^181^ Graser, 2009^49^ Morikawa, 2005^*,177^ Morikawa, 2007^*,194^ Sohn, 2005^182^ Cheng, 2002^*,160^ Nakama, 1999^*,178^ | Imperiale, 2014^167^ SSED184 Lin, 2012^175^ Haug, 2007^190^ Imperiale, 2004^192^ Ahlquist, 2008^185^ | Church, 2014 163
Differential followup (registry) | None | None | None | Allison, 2007 * 155 Allison, 1996 * 156 Levi, 2011 173 | Chiang, 2014^161^ Chen, 2011^159^ Levi, 2011^173^ Allison, 2007^*,155^ Castiglione, 2007^158^ Grazzini, 2004^188^ Launoy, 2005^*,171^ Allison, 1996^*,156^ Nakama, 1996^*,179^ Itoh, 1996^*,168^ | None | None

* Included in 2008 USPSTF review

Abbreviations: ACRIN = American College of Radiology Imaging Network National CT Colonography Trial; BliTz = Begleitende Evaluierung innovativer Testverfahren zur Darmkrebsfrüherkennung; COCOS = COlonoscopy or COlonography for Screening; CTC = computed tomographic colonography; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; mSEPT9 = circulating methylated septin 9 gene deoxyribonucleic acid; sDNA = stool deoxyribonucleic acid.

### Overall Summary

For this review of screening test accuracy, we primarily focused on the per-person (as opposed to per-lesion) sensitivity and specificity of a single application of each screening test to detect: 1) CRC or advanced neoplasia (a composite outcome of CRC plus advanced adenomas), 2) advanced adenomas (generally defined as adenomas ≥10 mm, with villous components, or with high-grade dysplasia), and 3) adenomatous polyps based on size (e.g., ≥10 or ≥6 mm). Results for adenomas smaller than 6 mm were not commonly reported.

#### Direct Visualization Tests

Only four fair- to good-quality studies (n=4,821) examined the diagnostic accuracy of colonoscopy generalizable to community practice. Although colonoscopy is considered the criterion standard, it can miss cancers. Based on three studies that compared colonoscopy to CTC or CTC-enhanced colonoscopy (n=2,290), the per-person sensitivity for adenomas 10 mm or larger ranged from 89.1 percent (95% CI, 77.8 to 95.7) to 94.7 percent (95% CI, 74.0 to 99.9), and the per-person sensitivity for adenomas 6 mm or larger ranged from 74.6 percent (95% CI, 62.9 to 84.2) to 92.8 percent (95% CI, 88.1 to 96.0) (Table 10).

Table 10 Key Question 2: Overall Summary of Diagnostic Accuracy per Person

Screening test (total # studies) | | AA Sensitivity | AA Specificity | Adenoma ≥10 mm Sensitivity | Adenoma ≥10 mm Specificity | Adenoma ≥6 mm Sensitivity | Adenoma ≥6 mm Specificity
Direct Visualization^†^ | Colonoscopy (k=4) | -- | -- | Low: 89.1 High: 94.7 | 88.7 | Low: 74.6 High: 92.8 | 94.2
Direct Visualization^†^ | CTC (k=9) | -- | -- | -- | -- | -- | --
Direct Visualization^†^ | With bowel prep (k=7) | Low: 87.5 High: 100 | Low: 39.4 High: 87.1 | Low: 66.7 High: 93.5 | Low: 86.0 High: 97.9 | Low: 72.7 High: 98.0 | Low: 79.6 High: 93.1
Direct Visualization^†^ | Without bowel prep (k=2) | 64.0 | -- | Low: 66.7 High: 89.5 | Low: 85.2 High: 97.3 | Low: 57.7 High: 75.0 | Low: 88.3 High: 92.2
Screening test (total # studies) | | CRC Sensitivity | CRC Specificity | AA Sensitivity | AA Specificity | AN Sensitivity | AN Specificity
Stool tests | Differential followup – Hemoccult Sensa (k=2) | Low: 61.5 High: 79.4 | Low: 86.7 High: 96.4 | NA | NA | NA | NA
Stool tests | All colonoscopy followup – Qualitative FIT (k=6) | Low: 54.5 High: 88.9 | Low: 89.4 High: 93.1 | Low: 25.4 High: 71.5 | Low: 56.3 High: 96.4 | Low: 5 High: 73.4 | Low: 56.3 High: 99
Stool tests | OC-Light (k=3) | Low: 78.6 High: 87.5 | Low: 91 High: 92.8 | Low: 28.0 High: 40.3 | Low: 91.3 High: 93.5 | Low: 5 High: 48.4 | Low: 91.3 High: 99
Stool tests | QuickVue (k=2) | -- | -- | 56.2 | 67.9 | Low: 50 High: 59.6 | Low: 69.6 High: 88
Stool tests | All colonoscopy followup – Quantitative FIT (k=9^‡^) | Low: 25 High: 92.3^*^ | Low: 87.2^*^ High: 95.5 | Low: 6 High: 44.1^*^ | Low: 85.8 High: 97.4 | Low: 2.4 High: 76.2 | Low: 85.8 High: 98.8
Stool tests | OC FIT-CHEK (k=5^‡^) | Low: 73.3 High: 92.3^*^ | Low: 87.2^*^ High: 95.5 | Low: 22.2 High: 44.1^*^ | Low: 89.8^*^ High: 97.4 | Low: 25.7 High: 52.8^*^ | Low: 89.8^*^ High: 97.4
Stool tests | Differential followup – Qualitative FIT (k=3) | Low: 68.8 High: 83.3 | Low: 94.4 High: 96.2 | -- | -- | -- | --
Stool tests | Differential followup – Quantitative FIT^**^ (k=3) | Low: 77.1 High: 86.5 | Low: 94.4 High: 96.4 | -- | -- | -- | --
Stool tests | mtsDNA (k=1) | 92.3 | 84.4 | 42.4 | 86.6 | 46.9 | 86.3
Blood test | mSEPT9 (k=1) | 48.2 | 91.5 | -- | -- | -- | --

* Results obtained using lower than manufacturer-recommended cutoff value and 3 stool samples

** Excluding Chen and colleagues159 for study design differences that likely affected diagnostic accuracy calculations; excluding Levi and colleagues173 for few CRC cases.

† Studies were not designed to determine sensitivity/specificity for CRC outcomes

‡ Excluding Graser and colleagues49 for CRC, CRC cases=1; excluding Hernandez and colleagues166 for CRC, CRC cases=5.

Abbreviations: CRC = colorectal cancer; CTC = computed tomographic colonography; FIT = fecal immunochemical test; k = number of studies; mm = millimeter; mtsDNA = multi-target stool deoxyribonucleic acid; mSEPT9 = circulating methylated septin 9 gene deoxyribonucleic acid; NA = not applicable.

Based on nine fair- to good-quality studies of screening CTC (n=6,497), test positivity ranged from 10 to 30 percent. Overall, included studies were not powered to estimate test performance to detect cancer because of low numbers of cancers in these studies (range, 0 to 7 cancers). Based on seven studies of CTC with bowel preparation (n=5,328), the per-person sensitivity and specificity to detect adenomas 10 mm or larger ranged from 66.7 percent (95% CI, 45.4 to 83.7) to 93.5 percent (95% CI, 83.6 to 98.1) and 86.0 percent (95% CI, 84.6 to 87.3) to 97.9 percent (95% CI, 95.7 to 99.1), respectively (Table 10). Likewise, the per-person sensitivity and specificity to detect adenomas 6 mm or larger ranged from 72.7 percent (95% CI, 58.4 to 84.1) to 98.0 percent (95% CI, 90.9 to 99.8) and 79.6 percent (95% CI, 77.1 to 82.0) to 93.1 percent (95% CI, 89.5 to 95.7), respectively. Only three studies (n=1,044) reported sensitivity to detect advanced adenomas, ranging from 87.5 percent (95% CI, 65.6 to 97.3) to 100 percent (95% CI, 89.3 to 100). Two studies (n=1,169) evaluated CTC without using bowel preparation. Although data are much more limited, it appears that sensitivity of CTC without bowel preparation to detect advanced adenomas, adenomas 10 mm or larger, or adenomas 6 mm or larger is lower than for CTC protocols including bowel preparation (Table 10). Although there is some variation in estimates of sensitivity and specificity across included studies, it is unclear if the variation of test performance is due to differences in study design, populations, bowel preparation, CTC imaging, or differences in reader experience or reading protocols.

#### Stool Tests

Currently available stool tests include high-sensitivity gFOBT, FIT, and mtsDNA (stool DNA plus FIT). Three fair-quality trials of Hemoccult SENSA screening addressed high-sensitivity gFOBT. While all studies followed screen-positive participants with colonoscopy, these studies used different methods to follow screen-negative participants (differential followup). Based on two studies (n=10,170) reporting test performance to detect CRC in the entire colon, the sensitivity for CRC ranged from 61.5 percent (95% CI, 35.0 to 83.5) to 79.4 percent (95% CI, 63.8 to 90.3) and specificity from 86.7 percent (95% CI, 85.9 to 87.4) to 96.4 percent (95% CI, 95.6 to 97.2) (Table 10).

We grouped FITs by qualitative (fixed cutoff) and quantitative (adjustable cutoff) test design. We also grouped FITs by study design (i.e., same vs. differential reference standard followup). Fourteen fair- to good-quality studies (n=59,425) that used a colonoscopy reference standard in all participants reported sensitivity and specificity for different qualitative and quantitative FITs; overall the sensitivity for CRC and advanced adenomas varied widely (Table 10). Quantitative FITs included an older, discontinued test that resulted in unusually low sensitivity. We focused on FIT performance characteristics of currently available tests (family of tests) evaluated in more than one study. Two tests, OC-Light® (qualitative; k=3; n=25,924) and OC FIT-CHEK® (quantitative; k=5; n=12,794) (Polymedco; Cortlandt, NY), had relatively high sensitivity and specificity and are cleared by the FDA. Lowest sensitivity with accompanying specificity for CRC in these studies using one stool specimen was 73.3 percent (95% CI, 48.3 to 90.2) and 95.5 percent (95% CI, 94.6 to 96.3), respectively. Similarly, the highest sensitivity and paired specificity was 87.5 percent (95% CI, 54.6 to 98.6) and 90.9 percent (95% CI, 89.2 to 92.4), respectively. In the largest studies, sensitivity ranged from 73.8 percent (95% CI, 62.3 to 83.3) for quantitative (n=9,989) to 78.6 percent (95% CI, 61.0 to 90.5) for qualitative (n=18,296) test categories. In one small study (n=770) that tested three stool specimens, sensitivity was 92.3 percent (95% CI, 69.3 to 99.2) and specificity was reduced to 87.2 percent (95% CI, 84.7 to 89.4). Using the same FITs (OC-Light or OC FIT-CHEK), sensitivities for advanced adenoma were as low as 22.2 percent (95% CI, 17.0 to 28.2; specificity, 97.4% [95% CI, 96.6 to 98.0]) and as high as 40.3 percent (95% CI, 29.8 to 51.4; specificity, 91.3% [95% CI, 90.6 to 91.9]). While higher sensitivities for adenoma were obtained for certain other FITs or by using three specimens, corresponding specificities were reduced. In six fair-quality studies of various FITs that used differential reference standard followup, the lowest sensitivity with accompanying specificity for CRC was 68.8 and 94.4 percent, respectively, and the highest sensitivity and paired specificity was 90.9 and 95.6 percent, respectively, for both types of FITs (excluding results from three additional studies for noncomparable study design or few CRC cases).

Only one stool test using stool DNA testing, the mtsDNA assay Cologuard® (Exact Sciences; Madison, WI), is available for clinical use. One fair-quality study (n=9,989) evaluated the mtsDNA assay compared to a commercial FIT and to colonoscopy, finding statistically significant improved performance for detection of CRC and advanced adenoma compared to OC FIT-CHEK. The increased sensitivity for CRC (92.3% [95% CI, 84.0 to 97.0]) and for advanced adenoma (42.4% [95% CI, 38.9 to 45.9]) compared to FIT is accompanied by reduced specificity (84.4% [95% CI, 83.6 to 85.1]) for CRC and 86.6% [95% CI, 85.9 to 87.2] for adenoma) (Table 10).

#### Blood Test

Only one blood test has been prospectively evaluated in a screening population.163 This test detects circulating methylated SEPT9 DNA. This test was evaluated through a fair-quality, multicenter diagnostic accuracy study (n=1,516) that found that mSEPT9 had a relatively low sensitivity to detect CRC (48.2% [95% CI, 32.4 to 63.6]), with a test positivity of 10.1 percent.

### Detailed Results

#### Colonoscopy

We found no tandem colonoscopy studies that met our inclusion criteria of evaluating screening colonoscopy performance representative of community practice. We found seven diagnostic accuracy studies evaluating CTC in screening populations that also reported on sensitivity and/or specificity of colonoscopy against CTC or CTC-enhanced colonoscopy. The majority of CTC studies, however, were single-institution studies that included a very limited number of expert endoscopists. Four of these studies (n=4,821) included a larger number of endoscopists, and have greater applicability to colonoscopy performance in community practice (Table 11).50,52,169,183

Table 11 Key Question 2: Colonoscopy Summary of Diagnostic Accuracy

Author, Year Quality Country | N analyzed Age Female (%) | Prevalence (%) | Colonoscopy Protocol | Reference Standard | Most advanced finding (per person): CRC Adenoma ≥10 mm Adenoma ≥6 mm | Per Person Sensitivity (95% CI) | Specificity (95% CI) | Per Lesion Sensitivity (95% CI)
Zalis, 2012^183^ Good US | 605 60 47 | CRC: 0.5 AA: NR | Number of Colonoscopists: NR Training: Fellowship-trained staff gastroenterologists Cecal Intubation Rate: NR | CTC informed colonoscopy (segmental unblinding) | 3 19 71 | CRC: 100 (29.2, 100) Adenoma ≥10 mm: 94.7 (74.0, 99.9) Adenoma ≥6 mm: 74.6 (62.9, 84.2) | CRC: NR Adenoma ≥10 mm: 88.7 (85.8, 91.1) Adenoma ≥6 mm: 94.2 (91.8, 96.0) | CRC: NR Adenoma ≥10 mm: 95.5 (77.2, 99.9) Adenoma ≥6 mm: 75.8 (65.9, 84.0)
Johnson, 2008^50^ ACRIN National CT Colonography Trial Good US | 2531 58 52 | CRC: 0.28 AA: NR | Number of Colonoscopists: NR Training: Performed or directly supervised by an experienced gastroenterologist or surgeon Cecal Intubation Rate: NR | Repeat colonoscopy if indicated by CTC | 7 102 203 | NR | NR | CRC: 100 (59.0, 100) Adenoma ≥10 mm: 97.6 (93.1, 99.5) Adenoma ≥6 mm: NR
Johnson, 2007^169^ Fair US | 452 65 44 | CRC: 1.1 AA: NR | Number of Colonoscopists: NR^*^ Training: Performed or directly supervised by an experienced gastroenterologist or surgeon Cecal Intubation Rate: 99% | Repeat colonoscopy if indicated by CTC | 5 21 NR | CRC: 17.9 (0.5, 71.6) Adenoma ≥10 mm: 90.5 (69.6, 98.8) Adenoma ≥6 mm: NR | NR | CRC: 17.9 (0.5, 71.6) Adenoma ≥10 mm: 90.5 (69.6, 98.8) Adenoma ≥6 mm: NR
Pickhardt, 2003^52^ Good US | 1233 58 41 | CRC: 0.16 AA: NR | Number of Colonoscopists: 17 Training: Experienced gastroenterologists or surgeons Cecal Intubation Rate: 99.4% | CTC informed colonoscopy (segmental unblinding) | 2 46 166 | CRC: 50.0 (1.3, 98.7) Adenoma ≥10 mm: 89.1 (77.8, 95.7) Adenoma ≥6 mm: 92.8 (88.1, 96.0) | NR | CRC: 50.0 (1.3, 98.7) Adenoma ≥10 mm: 89.8 (79.1, 96.0) Adenoma ≥6 mm: 90.4 (85.8, 93.8)

* Performed or supervised by 1 of 50 experienced endoscopists

Abbreviations: AA = advanced adenoma; CI = confidence interval; CRC = colorectal cancer; CTC = computed tomography colonography; mm = millimeters; N = no; n = number; NR = not reported; US = United States; Y = yes; 2D = two dimensional; 3D = three dimensional.

##### Population Characteristics

All four of the included trials were conducted in the United States. Three of these trials (n=4,369) were multicenter trials.50,52,183 All studies recruited similar populations of asymptomatic, average-risk adults age 50 years or older. Two studies also included persons age 40 years and older with or without a family history.52,169 The mean age across studies ranged from 58 to 65 years. The baseline prevalence of cancer in the populations ranged from 0.16 to 1.1 percent. The highest prevalence was in the study by Johnson and colleagues with the highest mean age of 65 years.169 Two studies included more than 15 percent nonwhite participants.50,169

##### Colonoscopy Details

Only one study actually reported the number of endoscopists (17). The others suggested a large number of endoscopists without reporting the actual number or were conducted in multiple clinical sites, which suggests a large number of endoscopists. All studies stated that colonoscopies were either conducted (or supervised) by an experienced gastroenterologist or surgeon. Only two studies actually reported the cecal intubation rate (both ≥99%).52,169

##### Study Quality

These four studies were all rated as fair- to good-quality studies. The studies primarily aimed at determining the test accuracy of CTC, which also provided data to calculate the per-person and/or per-lesion sensitivity for CRC, adenomas 10 mm or larger, or adenomas 6 mm or larger. Two studies used colonoscopy enhanced with CTC as their criterion standard.52,183 In this study design, colonoscopy was performed after CTC examination and interpretation, with unblinding of CTC results after examination of each segment of the colon. For any suspected lesion on CTC that measured larger than 5 mm and was not seen on the initial “blinded” colonoscopy, the endoscopists re-examined that segment and could review the CTC image for guidance. In the other two studies, participants could have a repeat colonoscopy if indicated by CTC.50,169 Despite this approach, however, not all the participants recommended to have a repeat colonoscopy received one. In the American College of Radiology Imaging Network (ACRIN) National CT Colonography Trial, for example, only 12 of the 27 persons who were recommended to receive a repeat colonoscopy for lesions detected on CTC actually received the second colonoscopy.50

##### Outcomes

For CRC. In two trials (n=1,685), colonoscopy missed CRCs.52,169 In one fair-quality study (n=452) conducted by Johnson and colleagues, the colonoscopy was performed or supervised by one of 50 staff gastroenterologists or surgeons blinded to CTC findings.169 In this study, repeat colonoscopy was performed on six patients in whom lesions 10 mm or larger were missed that were deemed by consensus to have a high likelihood of being a true neoplasm. Because four of the missed lesions were later determined to be adenocarcinomas, the index colonoscopy only detected one of the five CRC cases. In another study (n=1,233), conducted by Pickhardt and colleagues, colonoscopy was conducted by one of 17 experienced gastroenterologists or surgeons blinded to CTC findings.52 In this study, index colonoscopy results were compared to colonoscopy with segmental unblinding. Colonoscopy detected one of two CRC cases.

For adenomas by size. Per-person and per-lesion sensitivity and specificity for adenomas did not differ significantly within studies, and per-lesion accuracy was more commonly reported. The per-person sensitivity for adenomas 10 mm or larger ranged from 89.1 percent (95% CI, 77.8 to 95.7)52 to 94.7 percent (95% CI, 74.0 to 99.9),183 and the per-person sensitivity for adenomas 6 mm or larger ranged from 74.6 percent (95% CI, 62.9 to 84.2)183 to 92.8 percent (95% CI, 88.1 to 96.0).52 The per-lesion (per-person sensitivity not reported) sensitivity of colonoscopy in ACRIN for adenomas 10 mm or larger was 97.6 percent (95% CI, 93.1 to 99.5).50 Specificity could only be calculated in one of the included studies. This good-quality study (n=605) by Zalis and colleagues observed a per-person specificity for adenomas 10 mm or larger of 88.7 percent (95% CI, 85.8 to 91.1) and 94.2 percent (95% CI, 91.8 to 96.0) for adenomas 6 mm or larger.183 None of these studies reported sensitivity or specificity for lesions smaller than 6 mm.

#### FS

We found no studies that evaluated the test performance of FS against a colonoscopy standard in average-risk screening populations. Our previous review included other study designs that provided miss rates (i.e., one tandem FS study that provided miss rates of FS in the distal colon, two studies with repeat FS in 3 years that provided miss rates in the distal colon) or simulated data based on colonoscopy examinations (i.e., six large cohort studies of screening colonoscopy that provided simulated FS performance with or without biopsy).195–203 None of these studies met the inclusion criteria for our current review.

#### CTC

We found nine diagnostic accuracy studies49–52,165,169,170,176,183 in 10 articles49–52,165,169,170,176,183,193 that evaluated CTC as a screening test in asymptomatic average-risk persons (Table 12). Three of these studies were included in the prior review.52,169,176 Two of the previously included studies were excluded from this review due to use of older, single-detector technology that is no longer applicable to current practice.204,205

Table 12 Key Question 2: Computed Tomographic Colonography Summary of Diagnostic Accuracy

Author, Year Quality Country | N Age Female (%) | Prevalence (%) | CTC Protocol | Reference Standard | Persons with: CRC Advanced Adenoma Adenoma ≥10 mm Adenoma ≥6 mm | Adenoma ≥6 mm Sensitivity (95% CI) Specificity (95% CI) | Adenoma ≥10 mm Sensitivity (95% CI) Specificity (95% CI) | Advanced adenoma Sensitivity (95% CI) Specificity (95% CI) | Advanced Neoplasia Sensitivity (95% CI) Specificity (95% CI)
Lefere, 2013^51^ Fair Portugal | 496 60 60 | CRC: 0.8 AA: 5.6 | Bowel Prep: Y Fecal Tagging: Y Number of Readers: 1 Training: >5000 exams Reading strategy: 3D (with 2D) | Repeat colonoscopy if indicated | 4 32 NR 49 | 98.0 (90.9, 99.8) 91.0 (88.0, 93.4) | NR NR | 100 (89.3, 100) 87.1 (83.8, 89.9) | 100 (92.5, 100) 87.1 (83.8, 89.9)
Graser, 2009^49^ Good Germany | 307 60 45 | CRC: 0.33 AA: 9.5 | Bowel Prep: Y Fecal Tagging: N Number of Readers: 3 Training: >300 exams Reading strategy: 3D (with 2D) | Colonoscopy with segmental unblinding | 1 29 24 45 | 91.1 (80.2, 96.9) 93.1 (89.5, 95.7) | 91.7 (75.9, 98.2) 97.9 (95.7, 99.1) | 96.6 (85.0, 99.6) 39.4 (33.7, 45.2) | 96.7 (85.5, 99.6) 39.4 (33.7, 45.2)
Johnson, 2008^50^ ACRIN^‡^ Good US | 2531 58 52 | CRC: 0.28 AA: NR | Bowel Prep: Y Fecal Tagging: Y Number of Readers: 15 Training: >500 examsβ Reading strategy: 3D (with 2D) | Repeat colonoscopy if indicated | 7 NR^*^ 102 203 | 77.8 (71.8, 83.1) 89.6 (88.4, 90.7) | 90.2 (83.3, 94.8) 86.0 (84.6, 87.3) | NR NR | NR NR
Kim, 2008^170^ Fair South Korea | 241 58 49 | CRC: 0.4 AA: 6.6 | Bowel Prep: Y Fecal Tagging: N Number of Readers: 2 Training: >100 exams Reading strategy: 2D (with 3D) | Single colonoscopy | 1 16 10 44 | 68.5 α^**^ (55.4, 79.7) 88.8 α (83.7, 92.7) | 86.7^†,**^ (63.7, 97.1) 97.3^†^ (94.6, 98.9) | 87.5 (65.6, 97.3) NR | 88.2 (67.3, 97.5) NR
Johnson, 2007^169^ Fair US | 452 65 44 | CRC: 1.1 AA: NR | Bowel Prep: Y Fecal Tagging: N Number of Readers: 3 Training: >1000 exams Reading strategy: 3D (with 2D)¥ | Single colonoscopy | 5 NR^*^ 21 NR | NR NR | 66.7 (45.4, 83.7) 97.6 (95.8, 98.8) | NR NR | NR NR
Macari, 2004^176^ Fair US | 68 55 0 | CRC: NR AA: NR | Bowel Prep: Y Fecal Tagging: N Number of Readers: 1 Training: 5 years experience Reading strategy: NR | Single colonoscopy | NR NR^*^ 3^†^ NR | NR NR | 100^†^ (46.4, 100) 98.5^†^ (93.0, 99.8) | NR NR | NR NR
Pickhardt, 2003^52^ Good US | 1233 58 41 | CRC: 0.16 AA: NR | Bowel Prep: Y Fecal Tagging: Y Number of Readers: 6 Training: >25 exams Reading strategy: 3D (with 2D) | Colonoscopy with segmental unblinding | 2 NR^*^ 46 166 | 88.6 (83.1, 92.7) 79.6 (77.1, 82.0) | 93.5 (83.6, 98.1) 96.0 (94.8, 97.0) | NR NR | NR NR
Fletcher, 2013^165^ Good US | 564 NR 58 | CRC: 0.18 AA: 4.4 | Bowel Prep: N Fecal Tagging: Y Number of Readers: 2 Training: >150 exams Reading strategy: 2D and 3D | Single colonoscopy | 1 25 15 36 | 75.0 (59.3, 86.8) 92.2 (89.7, 94.3) | 66.7 (41.6, 86.0) 97.3 (95.6, 98.4) | 64.0 (44.5, 80.5) NR | 65.4 (46.3, 81.3) NR
Zalis, 2012^183^ Good US | 605 60 47 | CRC: 0.5 AA: NR | Bowel Prep: N Fecal Tagging: Y Number of Readers: 3 Training: >200 exams Reading strategy: 2D and 3D | Colonoscopy with segmental unblinding | 3 NR^*^ 19 71 | 57.7 (46.1, 68.7) 88.3 (85.4, 90.8) | 89.5 (70.3, 97.7) 85.2 (82.2, 88.0) | NR NR | NR NR

* Assumed zero CRC cases

α Any histology ≥6 mm;

† Any histology ≥10 mm

** Sensitivity for adenomas ≥6 mm 72.7 percent (95% CI, 58.4 to 84.1); Sensitivity for adenomas ≥10 mm 90.0 percent (95% CI, 61.9 to 99.0)

‡ National CT Colonography Trial

β Or 1.5 day training session

¥ Study evaluated different reading strategies, data shown reflect primary 3D strategy

Abbreviations: AA = advanced adenoma; CI = confidence interval; CRC = colorectal cancer; n = number; N = no; NR = not reported; mm = millimeters; US = United States; Y = yes; 2D = two dimensional; 3D = three dimensional.

##### Population Characteristics

Six (n=5,453) of the nine studies were conducted in the United States.50,52,165,169,176,183 Three trials (n=4,369) were multicenter trials.50,52,183 The sample sizes for these nine studies ranged from 68 to 2,531. The largest trial (n=2,531) was a multicenter trial (15 centers), the ACRIN National CT Colonography Trial, conducted in the United States.50 All nine studies recruited similar populations: asymptomatic, average-risk adults age 50 years or older. Four studies included persons age 40 years and older with or without a family history.52,165,169,170 The mean age across studies ranged from 55 to 65 years. Only one study (n=452), conducted by Johnson and colleagues, had a mean age of 65 years or older.169 All trials excluded persons with familial hereditary CRC syndromes. Two trials also explicitly excluded persons with family history of CRC in first-degree relatives.49,176 The baseline prevalence of cancer in the populations ranged from 0.16 to 1.1 percent. The highest prevalence was in the study conducted by Johnson and colleagues that also had the highest mean age of 65 years.169 All trials included a reasonably even mix of men and women, except for one small trial (n=68) conducted exclusively in men in a VA medical center setting.176 Most studies did not report the race/ethnicity of participants. Three studies included more than 15 percent nonwhite participants, two studies were conducted in the United States,50,169 and one study was conducted in South Korea.170

##### CTC Protocol

All included studies evaluated multidetector CTC using two examinations (supine and prone), although protocols for bowel preparation, imaging, and reading images varied across studies. Seven studies (n=5,328) evaluated CTC with bowel preparation with50–52 or without fecal tagging,49,169,170,176 and two more recent studies (n=1,169) evaluated CTC without bowel preparation and with fecal tagging.165,183 Studies using bowel preparation varied in the type used, from full preparation with polyethylene glycol (PEG) to more limited preparation using only sodium phosphate or sodium picosulfate. Only one study (n=241), conducted by Kim and colleagues, administered intravenous contrast as part of the CTC protocol.170 There was also variation in the number of detectors, reconstruction interval, collimation, and slice thickness. The number of reading radiologists for each study ranged from one to 15. Seven studies used three or fewer highly trained radiologists,49,51,165,169,170,176,183 and only one trial (n=2,531), ACRIN, used a larger sample of CTC readers (15 radiologists).50 While readers generally used a combination of two- and three-dimensional reading strategies, the primary reading strategy varied.

##### Study Quality

Studies were fair- to good-quality prospective diagnostic accuracy studies evaluating CTC in which all persons also received a colonoscopy. Five studies were good quality.49,50,52,165,183 Limitations of fair-quality studies included limited reporting on study details (e.g., attrition, exclusions due to inadequate CTC or colonoscopy), small number of included participants, and, in one study, attribution of lesions seen on CTC but not colonoscopy as false-positives. The reasons for attrition were not consistently reported, however, followup (n analyzed/n screened) was generally high (>97%). In at least five studies, it appears that some of the attrition was due to incomplete or nondiagnostic CTC (e.g., nonadherence, issues with preparation or CTC examination, technical error).50–52,169,183 Only three studies used the best choice of reference standard (i.e., colonoscopy with segmental unblinding [CTC-enhanced colonoscopy]).49,52,183 Two studies used colonoscopy plus an optional second/repeat colonoscopy triggered by CTC findings as the reference standard.50,51 The remaining four studies used a single colonoscopy only as the reference standard.165,169,170,176 Details about the number, training, or quality parameters of the endoscopists or colonoscopy itself were not consistently or commonly reported.

##### Outcomes

Commonly reported outcomes of the included studies were per-person and per-lesion sensitivity and/or specificity by type or histology (i.e., CRC, advanced adenomas, nonadvanced adenomas) and size (i.e., 6–9, ≥6, or ≥10 mm). The test positivity for CTC ranged from 10 to 30 percent of persons undergoing screening CTC. Test positivity was defined as having at least one lesion 5 or 6 mm or larger and therefore would have resulted in a followup colonoscopy for polypectomy, or at minimum required surveillance CTC.50–52,165,169,170,176,183 Three studies reported on detection of lesions smaller than 6 mm.49,170,176

###### Sensitivity and specificity of CTC with bowel preparation

For CRC. Overall, the number of cancers (20) detected in seven studies that evaluated CTC with bowel preparation (n=5,328) was low, and the actual number of cancers detected ranged from 0 to 7 (Table 12). In only one study, ACRIN (n=2,531), was one of the seven cancers missed. This missed cancer was a 10 mm lesion in the low rectum (not visible on a second review of the CTC image).50

For advanced adenomas or advanced neoplasia. For the three studies that evaluated CTC with bowel preparation (n=1,044), the per-person sensitivity and specificity to detect advanced adenomas ranged from 87.5 percent (95% CI, 65.6 to 97.3) to 100 percent (95% CI, 89.3 to 100) and 39.4 percent (95% CI, 33.7 to 45.2) to 87.1 percent (95% CI, 83.8 to 89.9), respectively (Figure 10).49,51,170 The per-person sensitivity and specificity for advanced neoplasia was similar because the number of cancers was low (Table 12).

Figure 10 Key Question 2: Forest Plot of CT Colonography Sensitivity and Specificity for Advanced Adenomas

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; prep = preparation; Tag = tagging agent; TN = true negative; TP = true positive

Figure 10 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study of CT colonography screening for advanced adenomas. The figure also displays whether the studies used bowel preparation and fecal tagging, as well as the true positives, false negatives, true negatives, and false positives.

For adenomas by size. Across five included studies using bowel preparation (n=4,764), the per-person sensitivity for adenomas 10 mm or larger ranged from 66.7 percent (95% CI, 45.4 to 83.7) to 93.5 percent (95% CI, 83.6 to 98.1).49,50,52,169,170 Across four studies using bowel preparation (n=4,523), the per-person specificity for adenomas 10 mm or larger ranged from 86.0 percent (95% CI, 84.6 to 87.3) to 97.9 percent (95% CI, 95.7 to 99.1).49,50,52,169 The pooled estimate for sensitivity was 89.2 percent (95% CI, 82.0 to 96.4; I^2^=56.9%) and for specificity was 94.4 percent (95% CI, 88.9 to 1.00; I^2^=98.4%) (Figure 11).

Figure 11 Key Question 2: Forest Plot of CT Colonography Sensitivity and Specificity for Adenomas ≥10 mm

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; prep = preparation; Tag = tagging agent; TN = true negative; TP = true positive

Figure 11 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study of CT colonography screening for adenomas measuring 10 mm or larger. The figure also displays whether the studies used bowel preparation and fecal tagging, as well as the true positives, false negatives, true negatives, and false positives.

The per-person sensitivity for adenomas 6 mm or larger across five included studies using bowel preparation (n=4,808) ranged from 72.7 percent (95% CI, 58.4 to 84.1) to 98.0 percent (95% CI, 90.9 to 99.8).49–52,170 Across four studies using bowel preparation (n=4,567), the per-person specificity for adenomas 6 mm or larger ranged from 79.6 percent (95% CI, 77.1 to 82.0) to 93.1 percent (95% CI, 89.5 to 95.7).49–52 The pooled estimate for sensitivity was 86.5 percent (95% CI, 77.7 to 95.2; I^2^=90.0%) and for specificity was 88.3 percent (95% CI, 82.5 to 94.1; I^2^=96.5%) (Figure 12).

Figure 12 Key Question 2: Forest Plot of CT Colonography Sensitivity and Specificity for Adenomas ≥6 mm

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; prep = preparation; Tag = tagging agent; TN = true negative; TP = true positive

Figure 12 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study of CT colonography screening for adenomas measuring 6 mm or larger. The figure also displays whether the studies used bowel preparation and fecal tagging, as well as the true positives, false negatives, true negatives, and false positives.

Only three studies (n=616) reported test accuracy information for lesions smaller than 6 mm.49,170,176 We could not calculate per-person sensitivity or specificity using reported data. In two studies (n=548), the per-lesion sensitivity for adenomas smaller than 6 mm ranged from 41.0 percent (95% CI, 32.6 to 49.8) to 59.2 percent (95% CI, 51.1 to 66.9).49,170 In two studies (n=375), the per-lesion sensitivity for any polyp (regardless of histology) smaller than 6 mm ranged from 11.5 percent (95% CI, 5.9 to 20.0) to 38.4 percent (95% CI, 33.0 to 44.1).170,176

Clinical and statistical heterogeneity. We caution readers in interpreting pooled point estimates, given the large statistical heterogeneity, particularly around estimates of specificity and test accuracy around smaller adenomas. Instead, we suggest focusing on the 95% CI or range of estimates across the individual studies. However, the high statistical heterogeneity for specificity is in part due to the high degree of precision around estimates from individual studies. As described above, there is variation among CTC imaging and reading protocols, as well as additional variation in the study design and population characteristics among the studies. Because of the limited number of studies and the number of variables contributing to the clinical heterogeneity, it is yet unclear what are the key determinants accounting for the variation in test performance. There is some evidence, although not definitive, to suggest that fecal tagging improves sensitivity, from this body of evidence. It is unclear from this body of evidence if primary two- or three-dimensional reading strategy or radiologist choice of primary reading strategies improves sensitivity.

Only three studies reported sensitivity to detect advanced adenomas or advanced neoplasia, and while the sensitivity varied, there were no particular outliers.49,51,170 Only two studies reported specificity to detect advanced adenomas or advanced neoplasia.49,51 One study in particular, conducted by Graser and colleagues, observed a very low specificity for advanced adenoma or advanced neoplasia.49 This good-quality study employed a limited number of CTC readers using a primary three-dimensional reading strategy against a criterion standard of colonoscopy with segmental unblinding. The CTC protocol did not use fecal tagging. Although the specificity for advanced neoplasia was low, this study showed a relatively high specificity for adenomas 10 mm and 6 mm or larger. This study also showed relatively high corresponding sensitivities for the detection of all types of lesions. Identification of more subcentimeter lesions, which will necessarily have a lower prevalence of advanced histology, resulted in lower specificity for advanced neoplasia.

For adenomas 10 mm or larger, one study conducted by Johnson and colleagues observed lower sensitivity than in the other studies.169 This fair-quality study was conducted in a somewhat older population (mean age, 65 years) with a higher prevalence of cancer, using a limited number of CTC readers using a primary three-dimensional reading strategy. The CTC protocol did not use fecal tagging. The authors reported that the CTC examinations were conducted prior to standard fecal tagging and insufflation practices. For adenomas 6 mm or larger, the sensitivity was more variable compared to larger or more advanced lesions; however, there were no specific outliers. Two studies that employed a larger number of CTC readers found lower specificities for adenomas 10 mm or larger50 and those 6 mm or larger.52 The lower specificities did not correlate with higher sensitivities in these studies. Both of these studies used fecal tagging and primary three-dimensional reading strategies. Given the heterogeneity in these studies, it is inconclusive if the lower specificities observed were due to the greater number of CTC readers.

Subpopulations. Four studies of CTC with bowel preparation reported on the distribution of lesions in the colon.49–52 The percent of adenomas 10 mm or larger in the distal colon was 49 to 73 percent, and the percent of adenomas 6–9 mm was 48 to 66 percent. Only one study reported sensitivity and specificity of lesions by location in the colon.49 This good-quality study (n=307), conducted by Graser and colleagues, evaluated CTC with bowel preparation and without fecal tagging against colonoscopy with segmental unblinding. The sensitivity for advanced adenomas did not vary significantly by location (proximal, 88.9% [95% CI, 58.6 to 98.8] vs. distal, 91.7% [95% CI, 75.9 to 98.2]). One study, ACRIN,50 reported post hoc analyses for sensitivity and specificity by age in a subsequent publication.193 This study (n=2,531) evaluated CTC with bowel preparation and fecal tagging against colonoscopy (with an option for a second-look colonoscopy if indicated). This study found nonstatistically significant lower per-person sensitivities for the detection of adenomas or cancers in persons age 65 years and older (n=477) compared to those younger than age 65 years (n=2,054). The per-person sensitivity for adenomas or cancers 10 mm or larger in older adults compared to middle-aged adults was 82.1 percent (95% CI, 64.4 to 94.4) and 91.5 percent (95% CI, 83.7 to 96.7), respectively. Likewise, the per-person sensitivity for adenomas or cancers 6 mm or larger in older adults compared to middle aged adults was 71.5 percent (95% CI, 56.5 to 85.4) and 81.3 percent (95% CI, 74.5 to 88.2), respectively. No tests for interaction were reported for these subgroup analyses. The authors noted that there were differences in bowel preparation and distention by age group.

Sensitivity and specificity of CTC without bowel preparation. Only two studies (n=1,169) evaluated CTC performance without bowel preparation but with fecal tagging (Table 12).165,183 Both studies were good-quality and conducted in the United States. Neither study was designed to estimate the diagnostic accuracy to detect CRC, as the total number of CRC cases was very low (4 cancers). One study (n=564), conducted by Fletcher and colleagues, reported a per-person sensitivity and specificity for detection of adenomas 10 and 6 mm or larger that appeared comparable to those studies using bowel preparation, although the sensitivity for detection of advanced neoplasia was lower at 65.3 percent (95% CI, 44.3 to 82.8).165 In the second study (n=605), conducted by Zalis and colleagues, the per-person sensitivity and specificity for detection of adenomas 10 mm or larger appeared comparable to those studies using bowel preparation, although the sensitivity for adenomas 6 mm or larger was lower (57.7% [95% CI, 45.4 to 69.4]).183 This study did not report test performance for advanced adenomas or advanced neoplasia. Given the clinical heterogeneity among studies with and without bowel preparation, it is unclear from these two studies if lower sensitivities for detection of certain lesions are due to lack of bowel preparation use or other differences in study design, population, or CTC protocol.

#### High-Sensitivity gFOBT

##### Study Details

Three fair-quality trials (n=15,969) reported results of high-sensitivity gFOBT (Hemoccult SENSA) in adults at average risk for CRC (Table 13).155,156,173 Two of these studies were included in the previous systematic review.155,156 Two were multicenter studies155,173 and one was conducted at a single medical center.156 Two studies were conducted in the United States155,156 and one was conducted in Israel.173 Two studies followed gFOBT-positive patients with colonoscopy and all studies followed screen-negative patients over 2 years using registry data. In one study, gFOBT-positive patients were followed by sigmoidoscopy and, if positive, colonoscopy.156 In another study, gFOBT-negative patients were recommended to have sigmoidoscopy.155 Mean or median age was not reported, but studies included individuals age 50 years or older; 50 to 60 percent of the enrolled population were women in two reporting studies.155,156 The prevalence of CRC ranged from 0.3 to 0.55 percent across studies. Allison and colleagues reported results only for distally located lesions (results not shown in Table 13).155

Table 13 Key Question 2: Hemoccult SENSA Summary of Diagnostic Accuracy

Author, Year Quality Country | Recruitment Setting | Inclusion Criteria | Followup | N Analyzed Female (%) | Prevalence (%) | Number of Samples | Cutoffs ng Hb/ml buffer μg Hb/g feces | CRC Cases | CRC Sensitivity (95% CI) Specificity (95% CI)
Levi, 2011^173^ Fair Israel | 9 primary care clinics | Asymptomatic people; 50–75 years; patients of selected 9 primary care clinics of Clalit Health Services | Colonoscopy for FOBT+; registry followup for 2 years after the last FOBT was performed. | 2266 NR | CRC: 0.55 AA: NR | NR | Positive test = any of the 6 windows is positive NR | 13 | 61.5 (35.0, 83.5) 96.4 (95.6, 97.2)
Allison, 1996^156^ Fair US | Single Kaiser Permanente Medical Center | 50 years of age or older; scheduled for a personal health appraisal | FS for all positive tests. If FS found a neoplasm, then referred to colonoscopy. If FS was negative, FOBT screen was repeated at 6 and 12 mo. Colonoscopy to anyone wishing to undergo one. Computerized databases were searched for two years after screening for interval CRC. | 7904 59.3 | CRC: 0.43 AA: 1.3 | 3 | Blue color diffused into a 0.5-cm margin around the specimen within 1 min NR | 34 | 79.4 (63.8, 90.3) 86.7 (85.9, 87.4)

Abbreviations: AA = advanced adenoma; CI = confidence interval; CRC = colorectal cancer; N = number; NR = not reported; US = United States.

##### Outcomes

Levi and colleagues, with a total of 13 CRC cases, reported a sensitivity of 61.5 percent (95% CI, 35.0 to 83.5) and a specificity of 96.4 percent (95% CI, 85.9 to 87.4) for CRC (Table 13).173 Allison and colleagues had a total of 34 CRC cases and reported a sensitivity of 79.4 percent (95% CI, 63.8 to 90.3) and a specificity of 86.7 percent (95% CI, 85.9 to 87.4) for CRC.156 The 95 percent CIs for sensitivity overlapped across the two studies. In a later study and for the subset of distal lesions only, Allison and colleagues reported a sensitivity of 64.3 percent (95% CI, 38.4 to 84.8) and a specificity of 90.1 percent (95% CI, 89.3 to 90.8).155

#### FIT

The analysis of FIT studies is limited by several sources of heterogeneity, including the reference standard used to follow screening results and various attributes of FIT tests. In addition, study populations varied widely within FIT test categories. For these reasons, we decided against quantitative pooling of diagnostic accuracy results and instead qualitatively examined study results according to appropriate categories (see the Methods section). Briefly, we focused first on study designs that follow FIT screening with colonoscopy for all study participants, regardless of FIT result; then we evaluated studies with differential followup. For each study design, we examined categories of included FIT assays broadly by qualitative and quantitative methods and more specifically by test “family” (Table 14).

Table 14 Description of Included Fecal Immunochemical Tests

Test Family | Test Name | Type of Test | Test Principle | Cutoff, ng Hb/mL buffer | Cutoff, μg Hb/g feces | Manufacturer (Current information, preferentially for US distribution, if applicable) | Test Name Aliases | FDA-cleared?
Hemosure | Hemosure | Qualitative | Immunochromatographic | 50^†^ | 50^*^ | W.H.P.M., Inc., Irwindale, CA | -- | Yes
Hemoccult ICT | Hemoccult ICT | Qualitative | Immunochromatographic | -- | 300^*^ | Beckman Coulter, Inc | FlexSure OBT | Yes
immoCARE-C | immoCARE-C | Qualitative | Immunochromatographic | 50^*^ | 30^*^ | CAREdiagnostica, Voerde, Germany | Hemocare | Yes
MonoHaem | MonoHaem | Qualitative | Immunochromatographic | -- | 1,050^***^ | Silenus Laboratories Proprietary Ltd., Wilmington, DE (distributor for Chemicon International, Inc) | -- | Yes
QuickVue | QuickVue iFOB | Qualitative | Immunochromatographic | 50^*^ | 50^*^ | Quidel, San Diego, CA | -- | Yes
OC Light | OC-L FIT-CHEK (manual) | Qualitative | Immunochromatographic | 50^*^ | 10^**^ | Eiken Chemical Co., Tokyo, Japan, distributed in the US by Polymedco, Inc., Cortlandt Manor, NY | OC-Light | Yes
OC (FIT-CHEK) | OC FIT-CHEK (using the OC-Auto Micro 80 Analyzer) | Quantitative^‡^ | Latex agglutination, measured as optical change | 100^*^ | 20^†^ | Eiken Chemical Co., Tokyo, Japan, distributed in the US by Polymedco, Inc., Cortlandt Manor, NY | OC-Auto, OC-Micro (using OC-Auto reagents) | Yes
OC (FIT-CHEK) | OC FIT-CHEK (using the OC-Sensor Diana automated analyzer) | Quantitative^‡^ | Latex agglutination, measured as optical change | 100^*^ | 20^†^ | Eiken Chemical Co., Tokyo, Japan, distributed in the US by Polymedco, Inc., Cortlandt Manor, NY | OC-Diana, OC-Sensor (using OC-Sensor Diana reagents) | Yes
OC (Hemodia) | OC-Hemodia (manual) | Qualitative | Visual particle agglutination | | 40^**^ | Eiken Chemical Co., Tokyo, Japan | | Discontinued^1^
OC (Hemodia) | OC-Hemodia (automated, since 2000) | Quantitative^‡^ | Latex agglutination, measured as optical change | 100^**^ | 20^**^ | Eiken Chemical Co., Tokyo, Japan | OC-Sensor micro (using OC-Hemodia reagents) | Discontinued^1^
Clearview (casette) | Clearview iFOB Complete (casette) | Qualitative | Immunochromatographic | 50^†^ | 6 ug Hb^†^ | Alere Inc., Waltham, MA | -- | Yes
Clearview (test strip) | Clearview ULTRA iFOB (test strip) | Qualitative | Immunochromatographic | 50^2^ | 50^2^ | Inverness Medical Innovation, Inc., now Alere, Inc., Waltham, MA | -- | Discontinued^2^
FOB advanced | FOB advanced | Qualitative | Immunochromatographic | 50^†^ | -- | ulti med, Ahrensburg, Germany | -- | No
PreventID CC | PreventID CC | Qualitative | Immunochromatographic | 10^**^ | -- | Preventis, Bensheim, Germany | -- | No
Bionexia (Hb) | Bionexia FOBplus | Qualitative | Immunochromatographic | 40^†^ | -- | Biomerieux, Marcy l’Etoile, France [originally supplied by Dima Diagnostika] | -- | No
Bionexia (Hb-Hp) | Bionexia Hb-Hp Complex | Qualitative | Immunochromatographic | 25^†^ | -- | Biomerieux, Marcy l’Etoile, France [originally supplied by Dima Diagnostika] | -- | Discontinued? [not available on Biomerieux website]
Magstream/Hemselect | HemeSelect | Qualitative | Reverse passive hemagglutination | Samples diluted 1:8 showing erythrocyte agglutination | 100–200^†^ | Fujirebio, Tokyo, Japan, distributed by Beckman-Coulter, Inc., Brea, CA | Immudia HemSp | Discontinued^1^
Magstream/Hemselect | Magstream 1000/Hem SP | Quantitative^‡^ | Magnetic particle agglutination | 20^**^ | 67^**^ | Fujirebio, Tokyo, Japan | (Based on HemeSelect/Immudia HemSp) | No
RIDASCREEN (Hb) | RIDASCREEN Hemoglobin | Quantitative^‡^ | Enzyme immunoassay | -- | 2^†^ | R-Biopharm AG, Darmstadt, Germany | -- | No
RIDASCREEN (Hb-Hp) | RIDASCREEN Hemoglobin-Haptoglobin Complex | Quantitative^‡^ | Enzyme immunoassay | -- | 2^†^ | R-Biopharm AG, Darmstadt, Germany | -- | No
FOB Gold | FOB Gold | Quantitative^‡^ | Latex agglutination, measured as optical change | 100 ** [CE marked for user-defined cutoff] | 17^**^ | Sentinel Diagnostics, Milan, Italy | -- | No
Hemo Techt | Hemo Techt NS-Plus C system | Quantitative^‡^ | Colloidal gold agglutination measured as optical change | -- | 19 | Alfresa Pharma Co., Osaka, Japan | -- | No
HM-JACK | HM-JACK | Quantitative^‡^ | Latex agglutination, measured as optical change | 8 | 20 | Kyowa Medex Co., Ltd., Tokyo, Japan | -- | No

1 per Lee 2014^306^

2 per Levy 2014^174^

* from FDA summary

† from manufacturer website or calculated from information provided

** from published literature

*** Calculated from information provided in device manual; also reported by Halloran and colleagues;403 different cutoff of 0.2 mg/g feces (200 μg/g feces) reported by Nakama and colleagues178

‡ Quantitative results may be transformed into qualitative results using the manufacturer’s or a user-defined cutoff. In the US, quantitative FITs have been FDA-cleared only for qualitative use.

Abbreviations: CA = California; DE = Deleware; FDA = Food and Drug Administration; g = gram; Hb = hemoglobin; ng = nanogram; MA = Massachusetts; ml = milliliter; NY = New York; μg = microgram; US = United States.

##### Studies With Colonoscopy Followup for All

We found 14 diagnostic accuracy studies49,157,160,162,164,166,167,172,174,177,178,180–182 (published in 20 articles49,157,160,162,164,166,167,172,174,177,178,180–182,184,186,187,189,191,194) that evaluated FIT as a screening test in asymptomatic, average-risk persons and followed all screenees (both screen-negatives and screen-positives) with a diagnostic colonoscopy (Table 15). Three of these studies were included in the previous review.160,177,178 We excluded one of the previously included studies from this review because the study was conducted in high-risk patients.206 One study (Begleitende Evaluierung innovativer Testverfahren zur Darmkrebsfrüherkennung [BliTz]) is discussed twice in the results because the authors published a set of articles with a subsample and different FITs than the most recent publication.157,186

Table 15 Fecal Immunochemical Test (With or Without Stool DNA) Study Characteristics, All Colonoscopy Followup (Ordered Reverse Chronologically)

Author, Year Quality Country | Recruitment Setting | Inclusion Criteria | Mean or Median Age (years) | Female (%) | Prevalence (%) | N Analyzed | Test Name (Family Name)
Hernandez, 2014^166^ Good Spain | Multicenter (3 tertiary hospitals) | Asymptomatic men and women; aged 50–69 years; included in the COLONPREV study in Galacia and Euskadi; offered colonoscopy during the inclusion period | Mean 57.6 | 50.4 | CRC: 0.6 AA: 11.8 | 779 | OC-Sensor (OC (FIT-CHEK))
Imperiale, 2014^167^ Fair US; Canada | 90 private-practice and academic sites | Asymptomatic; 50–84 years; average risk for CRC; scheduled to undergo screening colonoscopy | Mean 64.2 | 53.7 | CRC: 0.65 AA: 6.9 | 9989 | OC FIT-CHEK (assumed automated version, based on cutoff value) (OC (FIT-CHEK)) Cologuard (mtsDNA= FIT plus sDNA)
Lee, 2014^172^ Good South Korea | Korean Association of Health Promotion | Received annual physical check-ups at the Gangnam branch of the Korean Association of Health Promotion (KAHP) during the period of July 2012 and March 2013. KAHP provides health checkups to >1 million annually in 16 branch clinics across Korea | Median 58 | 52 | CRC: NR AA: NR | NR | Hemo Techt NS-Plus C system (Hemo Techt NS-Plus C system)
Levy, 2014^174^ Fair US | University of Iowa Healthcare | 40–75 years; scheduled for a screening colonoscopy (subgroup of total n) | Mean 56.9 | 59.2 | CRC: NR AA: NR | 44 | clearview ULTRA iFOB (test strip) (Clearview (test strip))
Levy, 2014^174^ Fair US | University of Iowa Healthcare | 40–75 years; scheduled for a screening colonoscopy (subgroup of total n) | Mean 56.9 | 59.2 | CRC: NR AA: NR | 308 | Clearview iFOB complete (cassette) (Clearview (cassette))
Levy, 2014^174^ Fair US | University of Iowa Healthcare | 40–75 years; scheduled for a screening colonoscopy (subgroup of total n) | Mean 56.9 | 59.2 | CRC: NR AA: NR | 217 | OC-Light (OC Light)
Levy, 2014^174^ Fair US | University of Iowa Healthcare | 40–75 years; scheduled for a screening colonoscopy (subgroup of total n) | Mean 56.9 | 59.2 | CRC: NR AA: NR | 52 | QuickVue (QuickVue)
Brenner, 2013^157^ (BliTz) Good Germany | 20 Gastroenterology practices | Participants of screening colonscopy; average risk; 55 years or older | Mean 62.7 | 50.8 | CRC: 0.67 AA: 9.3 | 2235 | RIDASCREEN Hemoglobin (RIDASCREEN (Hb)) RIDASCREEN Hemoglobin-Haptoglobin Complex (RIDASCREEN (Hb-Hp)) OC FIT-CHEK (using the OC-Sensor Diana automated analyzer) (OC (FIT-CHEK))
Brenner, 2010^186^ (BliTz) Good Germany | 20 Gastroenterology practices | Participants of the German colonscopy screening program | Median 63 | 49.4 | CRC: 0.8 AA: 9.8 | 1330 | immoCARE-C (immoCARE-C) FOB advanced (FOB advanced) PreventID CC (PreventID CC) Bionexia FOBplus (Bionexia (Hb)) QuickVue iFOB (QuickVue) Bionexia Hb/Hp Complex (Bionexia (Hb-Hp))
Chiu, 2013^162^ Good Taiwan | Health check-ups at a university hospital | Adults who underwent screening colonoscopy as part of thorough health check-ups at the Health Management Center of National Taiwan University Hospital; aged 50 years or older | Mean 59.8 | 40.8 | CRC: 0.15 AA: 3.5 | 18,296 | OC-LIGHT
Ng, 2013^180^ Fair Hong Kong | Bowel cancer screening community center | 50–70 years; no symptoms in the past 6 months suggestive of CRC (hematochezia, melena, anorexia, change in bowel habit or weight loss greater than 5 kg; no screening test for CRC performed in the past 5 years | Mean 57.7 | 54.7 | CRC: 0.48 AA: 4.3 | 4539 | Hemosure (Hemosure)
de Wijkerslooth, 2012^164^ Good The Netherlands | Population-based screening pilot | Asymptomatic individuals of the Amsterdam and Rotterdam regions | Median 60 | 49 | CRC: 0.64 AA: 8.8 | 1256 | OC-Sensor (automated, inferred from text) (OC (FIT-CHEK))
Park, 2010^181^ Fair South Korea | 4 tertiary medical centers | Asymptomatic, average-risk people; 50–75 years; undergoing screening colonoscopy | Mean 59.3 | 48.6 | CRC: 1.7 AA: 7.7 | 770 | OC-MICRO (OC (FIT-CHEK))
Graser, 2009^49^ Good Germany | NR | >50 years old; free of colonic symptoms (e.g., melanic stools, hematocheiza, diarrhea, changes in stool frequency or abdominal pain) | Mean 60.5 | 45 | CRC: 0.33 AA: 8.4 | 285 | FOB Gold (FOB Gold)
Morikawa, 2005^177^ Fair Japan | Single hospital or associated clinic | Asymptomatic volunteers who participated in a comprehensive health exam | Mean 48 | 28 | CRC: 0.4 AA: 3.0 | 21805 | Magstream 1000/Hem SP (Magstream/HemeSelect)
Sohn, 2005^182^ Fair Korea | National Cancer Center, Korea | Subjects visiting the Center for Cancer Prevention and Detection for a medical check-up | Mean 48.9 | 43.3 | CRC: 0.3 AA: 1.8 | 3794 | OC-hemodia, using an OC-sensor analyzer (OC (Hemodia))
Cheng, 2002^404^ Fair Taiwan | Health screening program at a single cancer center | NR | Mean 46.8 | 44.8 | CRC: 0.22 AA: 1.0 | 7411 | OC-Light (OC Light)
Nakama, 1999^178^ Fair Japan | NR | Asymptomatic; participating in a medical check-up for colorectal cancer; 40 years and older | NR | NR | CRC: 0.39 AA: NR | 4611 | Monohaem (Monohaem)

Abbreviations: AA = advanced adenoma; BliTz = Begleitende Evaluierung innovativer Testverfahren zur Darmkrebsfrüherkennung; CRC = colorectal cancer; FIT = fecal immunochemical test; N = number; NR = not reported; US = United States.

Population characteristics. Of the 14 included studies of FITs, eight were conducted in Asia (Japan, Taiwan, Hong Kong, or South Korea),160,162,172,177,178,180–182 four were conducted in Europe (Germany, the Netherlands),49,157,164,166 one was conducted in the United States,174 and one, which compared a FIT to the mtsDNA test (includes a FIT), was conducted in the United States and Canada.167 Five of these studies were single-center studies,160,162,177,180,182 six were multicenter studies,157,164,166,167,172,181 and three studies did not provide sufficient description.49,174, 178 Overall, study sample size ranged from 285 to 21,805. Participants were described as asymptomatic and at average risk for CRC or as volunteers in general health or CRC-specific screening programs. The age threshold for participant enrollment was most often 50–55 years, but when reported, was 40 years in two studies.174,178 Reported mean age varied from 46.8 to 64.2 years. The proportion of women enrolled in these studies ranged from about 40 to 60 percent, except for 28 percent in one study.177 Baseline prevalence of cancer ranged from 0.15 to 1.7 percent and appeared to be poorly correlated with mean or median age. Most studies did not report race/ethnicity of participants, including seven conducted in Asia. Two studies reported less than 10 percent nonwhite participants, one in the Netherlands and one in the United States,164,174 and one study (conducted in the United States and Canada) reported 16 percent nonwhite participants.167

FITs. Results from 19 FIT families (hereafter referred to as FITs) were reported in the included studies (Table 15). Some FITs were utilized in different versions (e.g., manual vs. various options for automation) or in combination with assays for other analytes. Not all FITs have been reviewed or cleared for marketing in the United States by the FDA, and some FITs have since been discontinued by the manufacturer. One study (BliTz, in multiple publications) compared multiple FITs across the same participant population (Table 15),157,186 one study utilized four different FITs over time in different study subgroups,174 and one study compared a FIT to the mtsDNA assay, which includes a FIT (see “Stool-Based DNA and mtsDNA Tests” section).167 The number of patient samples analyzed by any one FIT ranged from 44 to 21,805.

Study quality. In this category of diagnostic accuracy or screening program studies, in which all participants received a colonoscopy, five studies were rated good-quality49,157,162,164,166 and nine studies were rated fair-quality.160,167,172,174,177,178,180–182 Limitations of fair-quality studies included incomplete reporting, potential selection bias, thresholds for a positive FIT result tested and selected after results were evaluated, and substantive or inappropriate exclusion of participant results from analysis. In one study, 58 percent of participants were younger than age 50 years and the study enrolled 2.5 times as many men as women, making the study less representative.177 In another study, only 78 percent of enrolled participants had results that were evaluable.167 In general, details about the number, training, or quality parameters of the endoscopists or colonoscopy itself were not consistently or commonly reported across all studies.

Outcomes. We grouped the most commonly reported outcomes as CRC, advanced neoplasia (CRC and advanced adenoma), and advanced adenoma. Although the definition of advanced adenoma varied somewhat across studies, variation was limited. A few studies reported results for all adenomas. No studies reported results by adenoma or polyp size categories. Five studies reported results by location (distal, proximal) but did not do so consistently for the same outcome.157,162,167,177,186 Three studies reported results by sex157,177,182 and two studies by age groups.177,182 Subgroup results by sex, age, and location in colon are briefly discussed but data are sparse.

Sensitivity and specificity of qualitative FIT for CRC. Four studies (n=34,857), each of which utilized one of three FDA-cleared qualitative FITs (OC-Light, Hemosure® [Irwindale, CA], MonoHaem® [Merck Millipore, Billerica, MA]), reported diagnostic accuracy for CRC outcomes (Table 16).160,162,178,180 CRC prevalence ranged from 0.15 to 0.48, and the number of CRC cases detected ranged from 16 to 28. Across studies, the highest sensitivity for CRC, along with concordant specificity, was 88.9 percent (95% CI, 68.9 to 97.6) and 93.1 percent (95% CI, 92.4 to 93.8), respectively (Figure 13). The lowest sensitivity with paired specificity was 54.5 percent (95% CI, 32.3 to 73.7) and 89.4 percent (95% CI, 88.4 to 90.2), respectively (Figure 13). Sensitivity results for CRC were not clearly associated with assay cutoff value and may have been confounded by differing numbers of stool samples tested. The best results for an FDA-cleared, one-sample FIT were obtained with OC-Light (assay cutoff, 10 μg Hb/g feces), at a sensitivity of 87.5 percent (95% CI, 65.6 to 97.3) and specificity of 91.0 percent (95% CI, 90.3 to 91.6),160 although another study using the same assay reported somewhat poorer sensitivity at 78.6 percent.162 CIs were widely overlapping between the two studies. The lowest sensitivity was for Hemosure (assay cutoff, 50 μg Hb/g feces), for a manufacturer-recommended single sample. The MonoHaem FIT had the highest sensitivity in this group, even though it has the highest cutoff (about 1,000 μg Hb/g feces) due to the manufacturer’s recommendation of testing three different stool samples. MonoHaem sensitivities for CRC using one- and two-stool samples were 55.6 and 83.3 percent (data not shown).

Table 16 Qualitative Fecal Immunochemical Test Summary of Diagnostic Accuracy (All Colonoscopy Followup)

Author, Year Quality Country | Test Name (Family^*^) | Number of Stools Sampled | Cutoff, ng Hb/mL buffer | Cutoff, ug Hb/g feces | N | Prevalence (n, %) | CRC Sensitivity (95% CI) Specificity (95% CI) | Advanced Adenoma Sensitivity (95% CI) Specificity (95% CI) | Advanced Neoplasia Sensitivity (95% CI) Specificity (95% CI)
Levy, 2014^174^ Fair US | Clearview iFOB complete (cassette) [Clearview (cassette)] | NR | 50 | 6^*^ | 308 | CRC: NR AA: NR | NR | NR | 13 (2, 41) 86 (82, 90)
Levy, 2014^174^ Fair US | clearview ULTRA iFOB (test strip) [Clearview (test strip)] | NR | 50 | 50^*^ | 44 | CRC: NR AA: NR | NR | NR | 20 (1, 72) 92 (79, 98)
Levy, 2014^174^ Fair US | OC-Light | NR | 50 | 10^*^ | 217 | CRC: NR AA: NR | NR | NR | 5 (0, 26) 99 (96, 100)
Levy, 2014^174^ Fair US | QuickVue | NR | 50 | 50^*^ | 52 | CRC: NR AA: NR | NR | NR | 50 (1, 99) 88 (76, 95)
Chiu, 2013^162^ Good Taiwan | OC-Light | 1 | 50 | 10 | 18296 | CRC: 28 (0.15) AA: 632 (3.5) | 78.6 (61.0, 90.5) 92.8 (92.4, 93.2) | 28.0 (24.6, 31.6) 93.5 (93.1, 93.9 | 30.2 (26.7, 33.7) 93.6 (93.2, 93.9)
Ng, 2013^162,180^ Fair Hong Kong | Hemosure | NR | 50^*^ | 50 | 4539 | CRC: 22 (0.48) AA: 197 (4.3) | 54.5 (32.3, 73.7) 89.4 (88.4, 90.2) | 37.1 (30.5, 43.9) 90.6 (89.7, 91.4 | 38.8 (32.5, 45.4) 90.6 (89.7, 91.4)
Brenner, 2010^186^ (BliTz) Good Germany | Bionexia FOBplus | NR | 40^*^ | NR | 1319 | CRC: 11 (0.8) AA: 130 (9.8) | NR | 52.3 (43.8, 60.8) 79.6 (77.3, 81.9 | 56.0 (47.8, 64.0) 79.6 (77.3, 81.9)
Brenner, 2010^186^ (BliTz) Good Germany | Bionexia Hb/Hp Complex | NR | 25^*^ | NR | 1328 | CRC: 11 (0.8) AA: 130 (9.8) | NR | 71.5 (63.4, 78.8) 56.3 (53.5, 59.2 | 73.4 (65.2, 80.5) 56.3 (53.5, 59.2)
Brenner, 2010^186^ (BliTz) Good Germany | FOB advanced | NR | 50^*^ | NR | 1330 | CRC: 11 (0.8) AA: 130 (9.8) | NR | 26.9 (19.9, 35.0) 91.3 (89.6, 92.8 | 30.5 (23.4, 38.4) 91.3 (89.6, 92.8)
Brenner, 2010^186^ (BliTz) Good Germany | immoCARE-C | NR | 50^*^ | 30^*^ | 1319 | CRC: 11 (0.8) AA: 130 (9.8) | NR | 25.4 (18.5, 33.3) 96.4 (95.2, 97.3 | 29.8 (22.7, 37.7) 96.4 (95.2, 97.3)
Brenner, 2010^186^ (BliTz) Good Germany | PreventID CC | NR | 10^*^ | NR | 1330 | CRC: 11 (0.8) AA: 130 (9.8) | NR | 49.2 (40.7, 57.8) 81.3 (79.0, 83.5 | 53.2 (45.0, 61.3) 81.3 (79.0, 83.5)
Brenner, 2010^186^ (BliTz) Good Germany | QuickVue iFOB [QuickVue] | NR | 50^*^ | 50^*^ | 1330 | CRC: 11 (0.8) AA: 130 (9.8) | NR | 56.2 (47.6, 64.5) 67.9 (65.2, 70.5 | 59.6 (51.3, 67.4) 69.6 (66.9, 72.1)
Cheng, 2002^160^ Fair Taiwan | OC-Light | NR | 50^*^ | 10^*^ | 7411 | CRC: 16 (0.22) AA: 77 (1.0) | 87.5 (65.6, 97.3) 91.0 (90.3, 91.6) | 40.3 (29.8, 51.4) 91.3 (90.6, 91.9 | 48.4 (38.4, 58.5) 91.3 (90.6, 91.9)
Nakama, 1999^178^ Fair Japan | Monohaem | 1 | NR | ~1000^*^ | 4611 | CRC: 18 (0.39) AA: NR | 55.6 (33.2, 76.2) 96.7 (96.1, 97.2) | NR | 35.2 (25.9, 45.3) 97.1 (96.6, 97.6)
Nakama, 1999^178^ Fair Japan | Monohaem | 2 | NR | ~1000^*^ | 4611 | CRC: 18 (0.39) AA: NR | 83.3 (61.9, 95.1) 95.3 (94.6, 95.9) | NR | 57.1 (46.9, 67.0) 96.0 (95.4, 96.6)
Nakama, 1999^178^ Fair Japan | Monohaem | 3 | NR | ~1000^*^ | 4611 | CRC: 18 (0.39) AA: NR | 88.9 (68.9, 97.6) 93.1 (92.4, 93.8) | NR | 61.5 (51.3, 71.0) 93.9 (93.2, 94.6)

* Refer to Table 14 for source of cutoff

† If different than the test name

Abbreviations: AA = advanced adenoma; BliTz = Begleitende Evaluierung innovativer Testverfahren zur Darmkrebsfrüherkennung; CI = confidence interval; CRC = colorectal cancer; Hb = hemoglobin; ml = milliliter; n = number; ng = nanogram; NR = not reported; μg = microgram.

Figure 13 Key Question 2: Forest Plot of FIT Sensitivity and Specificity for Colorectal Cancer

Abbreviations: CI = confidence interval; FIT = fecal immunochemical test; qual = qualitative; quant = quantitative; ug/g = micrograms per gram

Figure 13 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study of FIT screening for colorectal cancer. The figure also displays the test family name, cutoff value, and number of samples.

Sensitivity and specificity of qualitative FIT for advanced adenomas. Four studies (n=31,576) using eight qualitative FITs (OC-Light, Hemosure, bioNexia® FOBplus and bioNexia Hb/Hp Complex [bioMérieux, Marcy-l’Étoile, France]; FOB Advanced [ulti med, Ahrensburg, Germany]; immoCARE-C [CAREdiagnostica, Voerde, Germany]; PreventID® CC [Preventis GmbH, Bensheim, Germany]; QuickVue® [Quidel, San Diego, CA]) reported diagnostic accuracy outcomes for advanced adenoma (Table 16).160,162,180,186 Two of these studies utilized OC-Light.160,162 One study (BliTz) compared six FITs within the same population.186 Cutoff values across FITs, where reported, ranged from 10 to 50 μg Hb/g feces. Advanced adenoma prevalence ranged from 1.0 to 9.8 percent across studies; lowest prevalence was associated with lowest mean age. Among tests with cutoff values reported in μg Hb/g feces, sensitivity for advanced adenoma was highest at 56.2 percent (95% CI, 47.6 to 64.5), with accompanying specificity of 67.9 percent (95% CI, 65.2 to 70.5). Lowest sensitivity was 25.4 percent (95% CI, 18.5 to 33.3), with specificity of 96.4 percent (95% CI, 95.2 to 97.3). Variation in results was not clearly related to cutoff value (Figure 14).

Figure 14 Key Question 2: Forest Plot of FIT Sensitivity and Specificity for Advanced Adenomas

Abbreviations: CI = confidence interval; FIT = fecal immunochemical test; qual = qualitative; quant = quantitative; ug/g = micrograms per gram

Figure 14 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study of FIT screening for advanced adenomas. The figure also displays the test family name, cutoff value, and number of samples.

Sensitivity and specificity of qualitative FIT for advanced neoplasia. Six studies (n=36,808) that assessed 11 qualitative FITs (Clearview® iFOB Complete [cassette] and Clearview ULTRA iFOB [test strip] [Alere, Waltham, MA]; OC-Light; QuickVue; Hemosure; bioNexia FOBplus; bioNexia Hb/Hp Complex; FOB Advanced; immoCARE-C; PreventID CC; MonoHaem) with cutoff values ranging from 6 to 50 μg Hb/g feces reported diagnostic accuracy results for advanced neoplasia (Table 16).160,162,174,178,180,186 Six of these FITs have been cleared by the FDA. Among FITs with cutoff values reported in μg Hb/g feces, sensitivity was highest at 61.5 percent (95% CI, 51.3 to 71.0), with accompanying specificity of 93.9 percent (95% CI, 93.2 to 94.6), and lowest at 5.0 percent (95% CI, 0 to 26.0), with specificity of 99.0 percent (95% CI, 96.0 to 100.0) (Figure 15). The lowest sensitivities were obtained in a study with very small sample sizes for a succession of four FITs.174 Brenner and colleagues compared six FITs within a screening program (n=1,330).186 Of the FDA-cleared tests in these rare FIT comparison studies, the highest and most consistent sensitivities were obtained by QuickVue (50.0% [95% CI, 1.0 to 99.0] and 59.6% [99% CI, 51.3 to 67.4]) but at a loss of corresponding specificity (88.0% [95% CI, 76.0 to 95.0] and 69.6% [95% CI, 66.9 to 72.1]). In two larger studies, OC-Light had variable sensitivities of 30.2 percent (95% CI, 26.7 to 33.7) and 48.4 percent (95% CI, 38.4 to 58.5), with accompanying specificities of 93.6 percent (95% CI, 93.2 to 93.9) and 91.3 percent (95% CI, 90.6 to 91.9).160,162 The narrow range of FIT cutoff values was not helpful in explaining variability in this group of studies and for this outcome.

Figure 15 Key Question 2: Forest Plot of FIT Sensitivity and Specificity for Advanced Neoplasia

Abbreviations: CI = confidence interval; FIT = fecal immunochemical test; qual = qualitative; quant = quantitative; ug/g = micrograms per gram

Figure 15 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study of FIT screening for advanced neoplasia. The figure also displays the test family name, cutoff value, and number of samples.

Sensitivity and specificity of quantitative FIT for CRC. Nine studies (n=42,310) that evaluated seven quantitative FITs (OC FIT-CHEK/OC-Sensor MICRO/OC-Sensor; RIDASCREEN® Haemoglobin and RIDASCREEN Haemo-/Haptoglobin Complex [R-Biopharm, Darmstadt, Germany]; FOB Gold® [Sentinel Diagnostics, Milan, Italy]; MagStream 1000/HemSp® [Fujirebio, Tokyo, Japan]; OC-Hemodia [Eiken Chemical, Tokyo, Japan]; Hemo Techt NS-Plus [Alfresa Pharma, Osaka, Japan]) reported diagnostic accuracy for CRC outcomes (Table 17).49,157,164,166,167,172,177,181,182 CRC prevalence in these studies ranged from 0.3 to 1.7 percent and the number of CRC cases detected ranged from 1 to 79. Five studies used a version of the FDA-cleared OC FIT-CHEK assay.157,164,167,181 FIT cutoff values ranged primarily from 2 to 20 μg Hb/g feces, with the exception of the MagStream 1000 assay (cutoff, about 100–200 μg Hb/g feces). The best results for these tests were seen with the OC FIT-CHEK family of assays, with sensitivities in studies testing one stool sample as low as 73.3 percent (95% CI, 48.3 to 90.2), with corresponding specificity of 95.5 percent (95% CI, 94.6 to 96.3), to as high as 87.5 percent (95% CI, 54.6 to 98.6), with specificity of 90.9 percent (95% CI, 89.2 to 92.4). These results are comparable to the best results obtained using qualitative FITs. Sensitivity to detect CRC was higher using lower cutoff values. The best sensitivity for the OC FIT-CHEK (92.3% [95% CI, 69.3 to 99.2]) was obtained by testing three consecutive stool samples in one small study but resulted in a loss of specificity (87.2% [95% CI, 84.7 to 89.4]).181 Other assays generally had lower sensitivities (or were tested on few cancer cases) and are either discontinued or otherwise not available in the United States.

Table 17 Quantitative Fecal Immunochemical Tests (With or Without Fecal DNA) Summary of Diagnostic Accuracy (All Colonoscopy Followup)

Author, Year Quality Country | Test Name [Family]^†^ | Number of Stools Sampled | Cutoff, ng Hb/mL buffer | Cutoff, ug Hb/g feces | N | Prevalence (n, %) | CRC Sensitivity (95% CI) Specificity (95% CI) | Advanced Adenoma Sensitivity (95% CI) Specificity (95% CI) | Advanced Neoplasia Sensitivity (95% CI) Specificity (95% CI)
Hernandez, 2014^166^ Good Spain | OC-Sensor [OC (FIT-CHEK)] | 1 | 50 | 10 | 779 | CRC: 5 (0.6) AA: 92 (11.8) | 100 (62.1, 100) 92.0 (89.9, 93.7) | NR | 35.0 (26.1, 44.9) 95.2 (93.4, 96.6)
Hernandez, 2014^166^ Good Spain | OC-Sensor [OC (FIT-CHEK)] | 1 | 100 | 20 | 779 | CRC: 5 (0.6) AA: 92 (11.8) | 100 (62.1, 100) 93.5 (91.6, 95.1) | NR | 32.0 (23.3, 41.7) 96.5 (94.9, 97.7)
Hernandez, 2014^166^ Good Spain | OC-Sensor [OC (FIT-CHEK)] | 2 | 50 | 10 | 779 | CRC: 5 (0.6) AA: 92 (11.8) | 100 (62.1, 100) 87.6 (85.1, 89.8) | NR | 42.3 (32.8, 52.2) 91.2 (88.9, 93.2)
Hernandez, 2014^166^ Good Spain | OC-Sensor [OC (FIT-CHEK)] | 2 | 100 | 20 | 779 | CRC: 5 (0.6) AA: 92 (11.8) | 100 (62.1, 100) 90.0 (87.8, 92.0) | NR | 37.1 (28.0, 47.0) 93.3 (91.2, 95.0)
Imperiale, 2014^167^ Fair US; Canada | OC FIT-CHEK (assumed automated version, based on cutoff value) | 1 | 100 | 20^*^ | 9989 | CRC: 65 (0.65) AA: 658 (6.9) | 73.8 (62.3, 83.3) 93.4 (92.9, 93.9) | 23.8 (20.8, 26.9) 94.8 (94.4, 95.3 | 27.7 (24.8, 30.9) 94.8 (94.4, 95.3)
Imperiale, 2014^167^ Fair US; Canada | Cologuard (mtsDNA) | 1 | NR | NR | 9989 | CRC: 65 (0.65) AA: 658 (6.9) | 92.3 (84.0, 97.0) 84.4 (83.6, 85.1) | 42.4 (38.9, 45.9) 86.6 (85.9, 87.2 | 46.4 (43.0, 49.8) 86.6 (85.9, 87.2)
Lee, 2014^172^ Good South Korea | Hemo Techt NS-Plus C system | NR | NR | 6.3 | NR | CRC: NR (NR) AA: NR (NR) | 85.7 (57.2, 98.2) 94.0 (92.6, 95.2) | NR | 76.2 (52.8, 91.8) 94.3 (92.9, 95.4)
Brenner, 2013^157^ (BliTz) Good Germany | OC FIT-CHEK (using the OC-Sensor Diana automated analyzer) | 1 | 100 | 20 | 2220 | CRC: 15 (0.67) AA: 207 (9.3) | 73.3 (48.3, 90.2) 95.5 (94.6, 96.3) | 22.2 (17.0, 28.2) 97.4 (96.6, 98.0 | 25.7 (20.3, 31.7) 97.4 (96.6, 98.0)
Brenner, 2013^157^ (BliTz) Good Germany | RIDASCREEN Hemoglobin | 1 | NR | 2 | 2220 | CRC: 15 (0.67) AA: 207 (9.3) | 60.0 (35.3, 81.2) 95.4 (94.5, 96.2) | 20.8 (15.7, 26.7) 97.1 (96.3, 97.7 | 23.4 (18.2, 29.3) 97.1 (96.3, 97.7)
Brenner, 2013^157^ (BliTz) Good Germany | RIDASCREEN Hemoglobin-Haptoglobin Complex | 1 | NR | 2 | 2235 | CRC: 15 (0.67) AA: 207 (9.3) | 53.3 (29.4, 76.1) 95.4 (94.5, 96.2) | 17.9 (13.1, 23.5) 96.8 (95.9, 97.5 | 20.3 (15.4, 25.9) 96.8 (95.9, 97.5)
de Wijkerslooth, 2012^164^ Good The Netherlands | OC-Sensor (automated, inferred from text) [OC (FIT-CHEK)] | 1 | 50 | 10 | 1256 | CRC: 8 (0.64) AA: 111 (8.8) | 87.5 (54.6, 98.6) 90.9 (89.2, 92.4) | 34.2 (25.9, 43.4) 93.3 (91.8, 94.6 | 37.8 (29.5, 46.7) 93.3 (91.8, 94.6)
de Wijkerslooth, 2012^164^ Good The Netherlands | OC-Sensor (automated, inferred from text) [OC (FIT-CHEK)] | 1 | 100 | 20 | 1256 | CRC: 8 (0.64) AA: 111 (8.8) | 75.0 (40.8, 94.4) 94.8 (93.4, 95.9) | 27.9 (20.2, 36.8) 97.0 (95.9, 97.9) | 31.1 (23.3, 39.8) 97.0 (95.9, 97.9)
Park, 2010^181^ Fair South Korea | OC-MICRO [OC (FIT-CHEK)] | 3 | 50 | 10^*^ | 770 | CRC: 13 (1.7) AA: 59 (7.7) | 92.3 (69.3, 99.2) 87.2 (84.7, 89.4) | 44.1 (31.9, 56.8) 89.8 (87.4, 91.9 | 52.8 (41.3, 64.0) 89.8 (87.4, 91.9)
Park, 2010^181^ Fair South Korea | OC-MICRO [OC (FIT-CHEK)] | 3 | 100 (other cutoffs available: 50, 75, 125, 150) | 20^*^ | 757 | CRC: 13 (1.7) AA: 59 (7.7) | 92.3 (69.3, 99.2) 90.1 (87.8, 92.1) | 33.9 (22.8, 46.5) 92.1 (89.9, 94.0 | 44.4 (33.4, 56.0) 92.1 (89.9, 94.0)
Graser, 2009^49^ Good Germany | FOB Gold | 2 | 14 | NR | 285 | CRC: 1 (0.33) AA: 24 (8.4) | 100.0 (14.7, 100.0) NR | 29.2 (14.1, 48.9) 85.8 (81.1, 89.6 | 32.0 (16.4, 51.5) 85.8 (81.1, 89.6)
Morikawa, 2005^177^ Fair Japan | Magstream 1000/Hem SP [Magstream/HemeSelect] | 1 | 20 | 100–200 | 21805 | CRC: 79 (0.4) AA: 648 (3.0) | 65.8 (54.9, 75.6) 94.6 (94.3, 94.9) | NR | 27.1 (24.0, 30.4) 95.1 (94.8, 95.4)
Sohn, 2005^182^ Fair Korea | OC-hemodia, using an OC-sensor analyzer [OC (Hemodia)] | 1 | 100 | 20^*^ | 3794 | CRC: 12 (0.3) AA: 67 (1.8) | 25.0 | 6.0 | 2.4 (1.3, 3.9) 98.8 (98.4, 99.2)

* Refer to Table 14 for source of cutoff

† If different than the test name

Abbreviations: AA = advanced adenoma; AN = advanced neoplasia; BliTz = Begleitende Evaluierung innovativer Testverfahren zur Darmkrebsfrüherkennung; CI = confidence interval; CRC = colorectal cancer; g = gram; Hb = hemoglobin; ml = milliliter; ng = nanogram; NR = not reported; μg = microgram.

Sensitivity and specificity of quantitative FIT for advanced adenomas. Six studies (n=18,329) using six quantitative FITs (OC FIT-CHEK/OC-Sensor/OC-Sensor MICRO; RIDASCREEN Haemoglobin; RIDASCREEN Haemo-/Haptoglobin Complex; FOB Gold; OC-Hemodia) reported diagnostic accuracy outcomes for advanced adenoma (Table 17).49,157,164,167, 172,181,182 Four of these studies used OC FIT-CHEK (on different or unspecified automated analyzers).157,164,167,181 Cutoff values ranged from 2 to 20 μg Hb/g feces, where reported. Where reported, adenoma prevalence ranged from 1.8 to 9.3 percent across studies; the lowest prevalence appeared associated with lowest mean age. The study with the lowest prevalence of advanced adenoma (1.8%) used the now discontinued OC-Hemodia and reported the lowest sensitivity of 6.0 percent (no corresponding specificity reported).182 Excluding this study, the lowest sensitivity among single-sample, FDA-cleared FITs used in four studies was 22.2 percent (95% CI, 17.0 to 28.2), with corresponding specificity of 97.4 percent (95% CI, 96.6 to 98.0), and the highest was 33.6 percent (95% CI, 25.6 to 42.4) with specificity of 89.8 percent (95% CI, 87.4 to 91.9). A higher sensitivity (44.1% [95% CI, 31.9 to 56.8]) was obtained using this FIT in a small study that tested three stool samples and used a lower cutoff value.181

Sensitivity and specificity of quantitative FIT for advanced neoplasia. Nine studies (n=42,310) that used seven quantitative FITs (OC FIT-CHEK/OC-Sensor/OC-Sensor MICRO; RIDASCREEN Haemoglobin; RIDASCREEN Haemo-/Haptoglobin Complex; FOB Gold; OC-Hemodia; MagStream 1000/HemSp; Hemo Techt NS-Plus) with cutoff values ranging from 2 to 100 μg Hb/g feces reported diagnostic accuracy results for advanced neoplasia (Table 17).49,157, 164,166,167,172,177,181,182 Only one of the FITs (OC FIT-CHEK family) is currently available and cleared by the FDA. For this FIT, the highest sensitivity using a single stool sample was 37.8 percent (95% CI, 29.5 to 46.7), with specificity of 93.3 percent (95% CI, 91.8 to 94.6), and the lowest sensitivity was 25.7 percent (95% CI, 20.3 to 31.7), with specificity of 97.4 percent (95% CI, 96.6 to 98.0). Sensitivity to detect advanced neoplasia was higher using lower cutoff values. A higher sensitivity of 52.8 percent was obtained for this same FIT using three stool samples and a lower cutoff value in a small study.181 Overall, the highest sensitivity for advanced neoplasia (76.2%) was obtained using Hemo Techt NS-Plus, a FIT that is not available in the United States.

Subpopulations. Only a small number of studies reported FIT results by population subgroups and for various outcomes. In general, FIT sensitivities sometimes appeared higher for distal than for proximal lesions, but differences were not consistently apparent or statistically significant. Sensitivities for the reported outcomes tended to be higher in men than in women. Little data were reported for age subgroups.

Two studies of qualitative FITs reported subgroup results.162,191 Chiu and colleagues reported no statistically significant difference in OC-Light sensitivity for CRC by distal (82.3%) versus proximal (72.7%; p=0.44) location.162 The difference was statistically significant, however, for advanced adenoma, with a sensitivity for distal versus proximal lesions of 31.6 versus 22.5 percent, respectively (p<0.001). The BliTz study evaluated six qualitative tests, two of which are cleared by the FDA (immoCARE-C, QuickVue iFOB). Neither FIT showed a significant difference in sensitivity for any adenoma by location.186,191 None of these studies reported statistical testing for interaction.

Three studies of quantitative FITs reported subgroup results (one study, BliTz,157,186,187,189,191 is presented twice since it has a subsample of the population with different FITs).177,182,194 Morikawa and colleagues reported FIT (MagStream 1000/HemSp) sensitivity for advanced adenoma in the distal location of 26.1 percent compared to 11.2 percent in the proximal location (p<0.001).194 The pattern was similar for advanced neoplasia in this and one other study (BliTz), where the reported FIT (RIDASCREEN Haemoglobin) sensitivity was higher for distal (43.9%) than for proximal (29.6%) lesions (p=0.04).189 The latter study also reported a sensitivity for advanced neoplasia that was higher in men (47.7% [95% CI, 40.0 to 55.6]) than in women (30.7% [95% CI, 21.8 to 40.8]).187 Morikawa and colleagues reported that FIT sensitivity for advanced adenoma was higher in men (23.9%) than in women (16.7%) but an estimate of statistical significance was not available.194 There were no obvious differences in FIT sensitivity by age. Sohn and colleagues reported FIT (OC-Hemodia) sensitivity by sex and age categories, but the specific FIT used had poor sensitivity in general and was discontinued, and results were inconclusive.182 Again, none of the studies reported tests of interaction for included subgroup analyses.

##### Studies With Differential Colonoscopy or Registry Followup

Nine diagnostic accuracy studies (n=873,663)155,156,158,159,161,168,171,173,179 in 10 articles155,156,158,159, 161,168,171,173,179,188 evaluated FIT as a screening test in asymptomatic, average-risk persons and followed screen-positive participants with diagnostic colonoscopy (or FS plus barium enema161), but followed screen-negative participants for interval cancers for 1–3 years by administrative database or cancer registry (Table 18). In one study that reported results only for distally located lesions, participants who screened negative by FIT were followed with FS, and all participants were followed for 2 years by administrative database.155 Because participants received different followup depending on the results of their screening tests (test-referral bias), these studies as a group are considered lower quality and were not rated higher than fair quality.

Table 18 Fecal Immunochemical Test Study Characteristics, Differential/Registry Followup (Ordered Reverse Chronologically)

Author, Year Quality Country | Recruitment Setting | Inclusion Criteria | Differential Followup | Mean or Median Age (years) | % Female | Prevalence (%) | N Analyzed | Test Name [Family Name]^†^
Chiang, 2014^161^ Fair Taiwan | Nationwide screening program | 50–69 years; living in Taiwan | Colonoscopy or FS with barium enema for FIT+. All participants were linked to the Taiwan Cancer Registry | Mean 58 | 61.6 | CRC: 2493 (0.3) AA: NR | 3365 | Monohaem
Chen, 2011^159^ Fair Taiwan | Community-based colorectal cancer screening program | 40–69 years | Colonoscopy for FOBT+; repeat screening and/or national cancer registry for FOBT-; staggered entry, minimum 1 year followup | 52.10 | 63.1 | CRC: 150 (0.32) AA: NR | 46,355 | OC-Sensor (assumed automated based on reported cutoff) [OC (FIT-CHEK)]
Levi, 2011^173^ Fair Israel | 9 primary care clinics | Asymptomatic people; 50–75 years; patients of selected 9 primary care clinics of Clalit Health Services | Colonoscopy for FOBT+; registry followup for 2 years after the last FOBT was performed. | NR | NR | CRC: 19 (0.55) AA: NR | 1204 | OC-Micro [OC (FIT-CHEK)]
Allison, 2007^*,155^ Fair US | 3 Northern California Kaiser Permanente medical centers | Kaiser Foundation Health Plan members; ≥ 50 years | Colonoscopy (FOBT/FIT+); FS (FOBT/FIT-) with colonoscopy recommended for those with advanced colorectal neoplasms; at least 2 year followup using administrative databases for all patients | NR | 52.5 | CRC: 14 (0.3) AA: 128 (2.7) | 5356 | FlexSure OBT [Hemoccult ICT]
Castiglione, 2007^158^ Fair Italy | Population-based screening program | Ages 50–70; living in 19 municipalities in the Province of Florence; attending FOBT screening during stated dates | FIT-positives were offered colonoscopy; FIT-negatives with interval cancers in following 2 years were identified in a regional cancer registry | NR | 52.2 | CRC: 83 (0.30) AA: 219 (0.80) | 27,503 | OC-Hemodia, developed with OC-Sensor instrument
Launoy, 2005^171^ Fair France | General practitioner and occupational physician practices | Living in Cotentin; 50–74 years; seeing their physician for a regular consultation | All positive tests were invited to undergo colonoscopy; all negatives were followed up using a registry for 2 years (80% of cases were followed up for 2 years; 93% for 18 months; 100% with 12 months) | NR | 56.9 | CRC: 28 (0.38) AA: NR | 7421 | Magstream 1000 [Magstream/HemeSelect]
Allison, 1996^156^ Fair US | Single Kaiser Permanente medical center | 50 years of age or older; scheduled for a personal health appraisal | FS for all positive tests. If FS found a neoplasm, then referred to colonoscopy. If FS was negative, FOBT screen was repeated at 6 and 12 mo. Colonoscopy to anyone wishing to undergo one. Computerized databases were searched for two years after screening for interval CRC. | NR | 59.3 | CRC: 35 (0.43) AA: 107 (1.3) | 7493 | HemeSelect [Magstream/HemeSelect]
Itoh, 1996^168^ Fair Japan | Worker colorectal cancer screening program | Aged 40 or above; workers at a Japanese corporation | Colonoscopy if test positive. If a target disease was detected or suspected a barium enema was given on the same day. 2-year followup using insurance claims for missed cancers. | NR | 13.9 | CRC: 89 (0.32) AA: NR | 27,860 | OC-Hemodia (automated)
Nakama, 1996^179^ Fair Japan | Community screening in Nagano prefecture | Over 40 years of age | Colonoscopy (barium enema in 2% of cases) for FIT+; registry followup for 3 years | NR | NR | CRC: 14 (0.42) AA: NR | 3365 | Monohaem

* Note that Allison, 2007^155^ only reports distal lesions and that data is not presented in the following tables.

† If different than the test name

Abbreviations: AA = advanced adenomas; CI = confidence interval; CRC = colorectal cancer; FIT = fecal immunochemical test; N = number; NR = not reported; US = United States.

Results from seven FITs were reported in the nine differential followup studies (Table 18).155,156, 158,159,161,168,171,173,179 Four studies were conducted in Asia (Japan, Taiwan),159,161,168,179 two were conducted in Europe (France, Italy),158,171 two were conducted in the United States by the same group,155,156 and one study was conducted in Israel.173 Five studies reported results from screening programs,158,159,161,168,179 three from multicenter designs,155,171,173 and one from a single medical center.156

Because participants who screened negative were followed via administrative database or cancer registries for cancer outcomes in most studies, only CRC outcomes were considered for this group of studies. Three studies (n=38,361) utilized qualitative FITs156,158,179 (Table 19), which were OC-Hemodia and HemeSelect® (Beckman Coulter), both now discontinued, and MonoHaem (available and cleared by the FDA). Sensitivities for CRC using qualitative assays and 2-year followup for interval cancers ranged from 80.7 percent (95% CI, 70.6 to 88.6) to 83.3 percent (95% CI, 51.6 to 97.9), omitting results from the discontinued HemeSelect, which also has a high cutoff value (300 μg Hb/g feces179). Specificity ranged from 94.4 to 96.3 percent across all tests. Allison and colleagues reported sensitivity (81.8%) and specificity (96.9%) only for distal CRC using FlexSure OBT (Beckman Coulter), with an assay cutoff of 300 μg Hb/g feces (n=5,356) (data not shown).155

Table 19 Qualitative Fecal Immunochemical Tests Summary of Diagnostic Accuracy, Differential/Registry Followup

Author, Year Quality Country | Test Name [Family]^†^ | Number of Samples | Cutoff, ng Hb/mL buffer | Cutoff, μg Hb/g feces | N Analyzed | CRC Cases | Sensitivity (95% CI) | Specificity (95% CI)
Castiglione, 2007^158^ Fair Italy | OC – Hemodia, developed with OC-Sensor instrument [OC (Hemodia)] | NR | 100 | 20^*^ | 27,503 | 83 | 80.7 (70.6, 88.6) | 96.2 (96.0, 96.5)
Allison, 1996^156^ Fair US | HemeSelect [Magstream/HemeSelect] | 3 | Erythrocyte agglutination at a sample dilution of 1:8 | 300^*^ | 7493 | 32 | 68.8 (50.0, 83.9) | 94.4 (93.8, 94.9)
Nakama, 1996^179^ Fair Japan | Monohaem (1 year followup) | 1 | NR | 20^*^ | 3365 | 11 | 90.9 (58.7, 99.8) | 95.6 (94.9, 96.3)
Nakama, 1996^179^ Fair Japan | Monohaem (2 year followup) | 1 | NR | 20^*^ | 3365 | 12 | 83.3 (51.6, 97.9) | 95.6 (94.9, 96.3)
Nakama, 1996^179^ Fair Japan | Monohaem (3 year followup) | 1 | NR | 20^*^ | 3365 | 14 | 71.4 (41.9, 91.6) | 95.6 (94.9, 96.3)

* Refer to Table 14 for source of cutoff

† If different than the test name

Abbreviations: CI = confidence interval; CRC = colorectal cancer; FIT = fecal immunochemical test; g = gram; Hb = hemoglobin; mL = milliliter; n = number; ng = nanogram; NR = not reported; μg = microgram; US = United States.

Five studies (n=82,840) utilized quantitative FITs (Table 20).159,161,168,171,173 Three of these studies used the FDA-cleared OC FIT-CHEK family of FITs;159,161,173 one of these studies compared OC FIT-CHEK to HM-JACK (A. Menarini Diagnostics, Firenze, Italy) in the context of a nationwide screening program linked to a cancer registry.161 A third study used OC-Hemodia (discontinued).168 All of these FITs have cutoffs in the range of 10–20 μg Hb/g feces. A fourth study used the MagStream 1000 (not cleared by the FDA) with a cutoff of 100–200 μg Hb/g feces.171 Three studies followed FIT screen-negative participants for 2 years using cancer registries or an administrative database; these studies reported only on evaluable participants and excluded those without appropriate followup.168,171,173 Chen and colleagues159 reported on a community-based screening program with staggered entry and variable, minimum 1-year followup. Participants who initially screened positive by FIT but refused followup by colonoscopy were included in diagnostic accuracy calculations. Thus, study design may at least partly explain the low sensitivity of 45 percent for OC-Sensor. Two other studies reported sensitivities of about 86 percent and specificities of about 95 percent for two FITs.168,171 Chiang and colleagues reported sensitivities of 77.1 and 73.7 percent, with corresponding specificities of 96.4 and 96.3 percent, for OC-Sensor and HM-JACK, respectively.161 Levi and colleagues, also using OC-Sensor but evaluating three stool samples, detected all of the CRC cases (n=6) in their study.173

Table 20 Quantitative Fecal Immunochemical Tests Summary of Diagnostic Accuracy, Differential/Registry Followup

Author, Year Quality Country | Test Name [Family]^†^ | Number of Stool Samples | Cutoff, ng Hb/mL buffer | Cutoff, ug Hb/g feces | N Analyzed | CRC Cases | Sensitivity (95% CI) | Specficity (95% CI)
Chiang, 2014 Fair Taiwan | OC-Sensor [OC (FIT-CHEK)] | 1 | 100 | 20 | 747,076 | 1546 | 77.1 (75.2, 78.9) | 96.4 (96.4, 96.5)
Chen, 2011^159^ Fair Taiwan | OC-Sensor (assumed automated based on reported cutoff) [OC (FIT-CHEK)] | 1 | 100 | 20^*^ | 46,355 | 202 | 45.0 (38.3, 51.9) | 95.8 (95.6, 96.0)
Levi, 2011^173^ Fair Israel | OC-Micro [OC (FIT-CHEK)] | 3 | 70 | NR | 1204 | 6 | 100.0 (54.1, 100.0) | 87.7 (85.7, 89.5)
Launoy, 2005^171^ Fair France | Magstream 1000 [Magstream/HemeSelect] | 2 | 20 | 100–200^*^ | 7421 | 28 | 85.7 (67.3, 96.0) | 94.4 (93.9, 95.0)
Itoh, 1996^168^ Fair Japan | OC-Hemodia (automated) | 1 | 50 | 10^*^ | 27,860 | 89 | 86.5 (77.6, 92.8) | 94.9 (94.6, 95.2)

* Refer to Table 14 for source of cutoff

† If different than the test name

Abbreviations: CI = confidence interval; CRC = colorectal cancer; FIT = fecal immunochemical test; g = gram; Hb = hemoglobin; mL = milliliter; N = number; ng = nanogram; NR = not reported; ug = microgram.

#### Stool-Based DNA and mtsDNA Tests

In 2012, we published a systematic review on stool-based DNA testing to screen for CRC in average-risk adults.175 We rated the 2012 systematic review good-quality according to the methods of the current review. We found one diagnostic accuracy study for a mtsDNA test published after this review.167 Our 2012 AHRQ-funded systematic evidence review used similar inclusion criteria and quality assessment as this review, and found only three studies that evaluated the performance of stool-based DNA tests in asymptomatic persons.185,190,192 Because the stool-based DNA tests evaluated in these studies are no longer offered by the manufacturer, we describe results here briefly. The best evidence came from two studies (n analyzed=5,004) that evaluated a multimarker stool-based DNA test, a prototype to a later version that was clinically available as PreGen-Plus™ (Exact Sciences).185,192 The sensitivity to detect CRC for this prototype was discordant between the two studies (25% [95% CI, 5 to 57] vs. 51.6% [95% CI, 34.8 to 68.0]), although the CIs overlapped. Sensitivity for advanced adenomas was similarly poor in both studies (19% [95% CI, 5 to 42] and 15.1% [95% CI, 12.0 to 19.0]). Between-study differences, such as differences in study populations, do not clearly account for the differences in test sensitivity. Specificity for advanced neoplasia ranged from 93.6 percent (95% CI, 92.9 to 94.3) to 96 percent (95% CI, 95 to 97) (Table 21). From that review we concluded that there was insufficient evidence regarding the clinical accuracy of stool-based DNA tests in persons at average risk for CRC.

Table 21 Stool-Based DNA Test Summary of Diagnostic Accuracy

Author, year Quality Country | CRC prevalence (%, n/n) | N analyzed Age Female (%) | Test | Test positivity | Completion rate | Sensitivity (95% CI) | Specificity (95% CI) | Limitations
Ahlquist, 2008^185^ SDT-1: Fair SDT-2: Poor | 0.5% (19/3764) | 2497 60 54 | SDT-1 (prototype sDNA version 1.0) | 5.2% (129/2497) | 98.2% (3766/3834) | CRC: 25 (5, 57) Advanced adenomas: 19 (5, 42) Advanced neoplasia: 20 (14, 26) | CRC: 95 (94, 96) Advanced adenomas: NA Advanced neoplasia: 96 (95, 97) | Small sample size for SDT-2 with limited sampling of controls, authors tried to weight sensitivity for proportion of screen relevant neoplasia in the entire population, but did not presented weighted adjustment for all outcomes Poor precision around outcome measures Subset of patients did not get instructions on dietary restrictions required for FOBT, very low sensitivities reported for FOBT which are not consistent with best known estimates
Ahlquist, 2008^185^ SDT-1: Fair SDT-2: Poor | 0.5% (19/3764) | 217 66 50 | SDT-2 (sDNA version 2.0) | 35% (77/217) | 98.2% (3766/3834) | CRC: 58 (36, 80)^*^ Advanced adenomas: 39 (26, 52)^*^ Advanced neoplasia: 40 (32, 49) | CRC: NR Advanced adenomas: NR Advanced neoplasia: NR
Haug, 2007^190^ Poor | 1.6% (NR) | 441 NR NR | KRAS testing | 8% (70/875) | NR | CRC: 0 (NR) Advanced adenomas: 0 (NR) | CRC: NR Advanced adenomas: NR | Application of reference standard was opportunistic (patient who got colonoscopy were referred for colonoscopy) Average time between index and reference tests not presented, patients had to have colonoscopy within 2 years
Imperiale, 2004^192^ Fair | 0.7% (31/4404) | 2507 70 55 | SDT-1 (prototype sDNA version 1.0) | 8.2% (205/2505) | 88.3% (4845/5486) | CRC: 51.6 (34.8, 68.0) Advanced adenomas: 15.1 (12.0, 19.0) Advanced neoplasia: 17.7 (NR) | CRC: 92.8 (92.0, −93.5)^*^ Advanced adenomas: Not calculated Advanced neoplasia: 93.6% (92.9, 94.3)^*^ | Analysis focused on subset of patients, only basic demographic data presented detailing differences between full cohort and analyzed subset Poor precision around outcome measures Very low sensitivities reported for FOBT which are not consistent with best known estimates
Imperiale, 2004^192^ Fair | 0.7% (31/4404) | 2507 70 55 | Hemoccult II | 5.8% (146/2505) | 92.2% (5060/5486) | CRC: 12.9 (5.1, 28.9) Advanced adenomas: 10.7% (8.0 to 14.1%) Advanced neoplasia: 10.8% (NR) | CRC: 94.6 (94.0, 95.3)^*^ Advanced adenomas: Not calculated Advanced neoplasia: 95.2% (94.695.8%)^*^

* Weighted sensitivities and CI calculated

Abbreviations: CRC = Colorectal cancer; NA = not applicable; NR = not reported; SDT-1 = sDNA version 1.0; SDT-2 = sDNA version 2.0.

The same manufacturer (Exact Sciences) of stool-based DNA tests included in the prior review reconfigured one of its tests to include assays to detect hypermethylation of the promoter regions of the BMP3 and NDRG4 genes, point mutations in the KRAS gene, and the beta-actin gene (used as a reference gene for quantity of human DNA), as well as a FIT for human hemoglobin.167,207 The quantitative results for each DNA marker and FIT are incorporated into a logistic-regression algorithm that has been validated for a cutoff value of 183 to designate a positive result. This mtsDNA assay, Cologuard, is substantially different from previous stool-based DNA tests by this manufacturer.

One fair-quality diagnostic accuracy study (evaluable n=9,989) conducted at 90 clinical sites in the United States and Canada compared the results of the mtsDNA test to colonoscopy and a commercially available FIT (OC FIT-CHEK) (Tables 15 and 17).167 Participants were asymptomatic adults ages 50 to 84 years at average risk for CRC and scheduled to undergo screening colonoscopy. Overall, the cancer prevalence in this study was 0.65 percent and advanced adenoma prevalence was 6.9 percent. Enrollment was weighted toward those age 65 years and older and, as a result, 63 percent of the evaluable participants were in this age category. Of the participants who originally consented to the mtsDNA study, 13.8 percent could not be evaluated because they withdrew consent (3.6%), did not have colonoscopy (9.1%), or did not submit a stool sample (1%). Of the remaining evaluable participants, 6.25 percent lacked mtsDNA test results because of specimen leakage or lack of a necessary repeat specimen (4.3%) or had technical failure (1.9%). In comparison, 0.3 percent of evaluable participants were excluded because the sample had insufficient hemoglobin for FIT detection. In response to a letter, the authors of the study note that the collection device seal has been improved to prevent leakage.208 Other limitations included unclear lack of independence of interpretation of the index and reference tests and slight differences between the evaluable and nonevaluable populations. mtsDNA testing detected 60 of 65 patients with cancer who were identified by colonoscopy. The sensitivity of the mtsDNA test for CRC was statistically significantly improved compared to the FIT (92.3% [95% CI, 84.0 to 97.0] vs. 73.8% [95% CI, 62.3 to 83.3], respectively; p=0.002) (Table 17).167 Specificity for CRC, however, was statistically significantly lower for the mtsDNA test than for the commercial FIT (84.4% [95% CI, 83.6 to 85.1] vs. 93.4% [95% CI, 92.9 to 93.9], respectively), indicating a higher false-positive rate with mtsDNA. The pattern of results was similar for advanced adenoma (Table 17), with noticeably improved sensitivity for mtsDNA but a consequent reduction in specificity.

#### mSEPT9 DNA Test

We found only one study that evaluated the test performance of a blood test to screen for CRC in asymptomatic, average-risk adults. This fair-quality multicenter prospective nested case-control study (Prospective Evaluation of Septin 9 or PRESEPT), evaluated the mSEPT9 marker using the first generation of a commercially available polymerase chain reaction assay, Epi proColon® (Epigenomics, Germantown, MD).163 The assay was designed to detect circulating methylated SEPT9 DNA as a marker for CRC (not precursors of CRC).

This study initially included 7,920 asymptomatic adults from 32 clinical sites in the United States and Germany who met inclusion criteria, were age 50 years or older, and had an average risk for CRC. This study excluded persons with previous colonoscopy, previous cancer or adenomas, iron deficiency anemia, blood in stool, or family history of CRC. Eighty-seven percent of persons were available for analyses, with attrition mainly due to incomplete data or inadequate sample quality. Of the participants available for analyses (n=6,874), the mean age was 61 years, 55 percent were women, and the prevalence of underlying CRC was 0.8 percent. Participants had their blood drawn for the mSEPT9 assay at least 1 day before the colonoscopy bowel preparation, with an average of 14 days prior to preparation. All patients included in the analyses had colonoscopies performed by board-certified endoscopists at the respective clinical site. The overall adenoma detection rate was 44.8 percent. It is assumed but not reported that the endoscopist was blinded to mSEPT9 assay test results. Interpretation of the mSEPT9 assay was independent of colonoscopy and pathology findings.

For the analyses, study investigators identified a subset of persons (n=1,516) using random sampling stratified by colonoscopy findings, including all 53 cancers, 315 of the 666 advanced adenomas, 210 of the 2,359 nonadvanced adenomas, and 938 of the 3,796 persons without evidence of disease. The test positivity rate in this subset was 10.1 percent (153/1,510). Weighted sensitivity and specificity of the mSEPT9 assay to detect CRC calculated from this subset was 48.2 percent (95% CI, 32.4 to 63.6) and 91.5 percent (95% CI, 89.7 to 93.1), respectively. Test sensitivity to detect CRC increased with increasing CRC tumor stage. Sensitivity for distal (53.3% [95% CI, 34.7 to 72.4]) and proximal CRC (39.4% [95% CI, 14.2 to 68.2]) was not statistically significantly different (p=0.28). Test sensitivity to detect advanced adenomas was 11.2 percent (95% CI, 7.2 to 15.7); however, the assay was not designed to detect advanced adenomas.

## Key Question 3 What Are the Adverse Effects of the Different Screening Tests? Do Adverse Effects Vary by Important Subpopulations?

We included 98 fair- to good-quality studies48–52,111,113,120–122,128,131,147,149,160,162,165,169,170,175,176,180, 183,209–282 (in 113 articles17,33,48–52,111,113,118,120–122,127,128,131,133,136,147,149,153,160,162,165,169,170,175,176,180,183, 209–282) that evaluated the harms of CRC screening (Table 22). This group included 14 studies that evaluated a screening program (stool testing or FS and subsequent diagnostic colonoscopy harms), 55 studies that evaluated screening colonoscopy, 18 studies that evaluated screening FS, and 15 studies that evaluated CTC in asymptomatic adults. In addition, 12 CTC studies provided estimates of radiation exposure per examination, and 21 CTC studies reported information on extracolonic findings. Although extracolonic findings can be either a benefit or harm, a summary is included in this section. While we found no additional studies examining the harms of stool testing, we did not hypothesize any harms for these noninvasive tests other than diagnostic inaccuracy (i.e., false-positive or false-negative testing) or downstream harms of diagnostic followup seen in “program of screening.” We also found no empirical studies that directly addressed issues of harms related to overdiagnosis. Although we address the diagnostic (in)accuracy of a single test application in Key Question 2 (i.e., sensitivity [false-negatives] and specificity [false-positives]), our review did not specifically address harms around missed or interval cancers.

Table 22 Included Studies for Key Question 3^*^

Colonoscopy | | | FS | | CTC | | FOBT Program | FS Program
Adeyemo, 2014^209^ Bielawska, 2014^215^ Blotiere, 2014^216^ Layton, 2014^248^ Zafar, 2014^282^ Adler, 2013^210^ Castro, 2013^219^ Chiu, 2013^162^ Chukmaitov, 2013^221^ Cooper, 2013^222^ Dominitz, 2013^226^ Hamdani, 2013^232^ Kim, 2013^243^ Ng, 2013^180^ Stock, 2013^273^ Tam, 2013^276^ Ho, 2012^234^ Pox, 2012^263^ Quintero, 2012^120^ (COLONPREV) Rutter, 2012^267^ | Sagawa, 2012^268^ Stoop, 2012^128^ (COCOS) Suissa, 2012^275^ Zalis, 2012^183^ Ferlitsch, 2011^48^ Loffeld, 2011^251^ Senore, 2011^269^ (SCORE III) Ko, 2010^245^ Lorenzo-Zungia, 2010^252^ Xirasagar, 2010^281^ Arora, 2009^212^ Bair, 2009^213^ Berhane, 2009^214^ Bokemeyer, 2009^217^ Crispin, 2009^224^ Hsieh, 2009^236^ Kamath, 2009^239^ Quallick, 2009^264^ Singh, 2009^271^ | Warren, 2009^280^ Kang, 2008^240^ Johnson, 2008^50^ (ACRIN) Johnson,2012^193^ Mansmann, 2008^254^ Rabeneck, 2008^265^ Kim 2007^242^ Ko, 2007^291^ Levin, 2006^249^ MACS group, 2006^255^ Rathgaber, 2006^266^ Strul, 2006^274^ Cotterhill, 2005^223^ Korman, 2003^247^ Cheng, 2002^160^ Nelson, 2002^256^ Sieg, 2001^270^ | Kim, 2013^243^ Tam, 2013^276^ Schoen, 2012^122^ (PLCO) Senore, 2011^269^ (SCORE III) Viiala, 2007^278^ MACS group, 2006^255^ Segnan, 2005^126^ (SCORE II) Gondal, 2003^283^ Hoff, 2009^284^ Atkin, 2002^133^ (UKFSST) Jain, 2002^238^ Levin, 2002^250^ Segnan, 2002^149^ (SCORE) Hoff, 2001^235^ (Telemark Polyp Study I) Thiis-Evensen, 1999^17^ Hoff, 1996^33^ Rasmussen, 1999^121^ | Wallace, 1999 279 Atkin, 1998 290 Verne, 1998 131 Brevinge, 1997 111 | Zafar, 2014^282^ Fletcher, 2013^165^ Iafrate, 2013^237^ Lefere, 2013^51^ Cash, 2012^218^ Durbin, 2012^227^ Stoop, 2012^128^ (COCOS) Zalis, 2012^183^ Macari, 2011^253^ O’Connor, 2011^257^ Pickhardt, 2011^259^ Kim, 2010^285^ Pickhardt, 2010^260^ Veerappan, 2010^277^ Graser, 2009^49^ An, 2008^211^ | Flicker, 2008^229^ Johnson, 2008^50^ (ACRIN) Johnson,2012^193^ Kim, 2008^244^ Kim, 2008^170^ Pickhardt, 2008^288^ Kim, 2007^242^ Pickhardt, 2007^261^ MACS group, 2006^255^ Pickhardt, 2006^262^ Sosna, 2006^272^ Chin, 2005^220^ Edwards, 2004^228^ Ginnerup, 2003^230^ Gluecker, 2003^231^ Hara, 2000^233^ | Parente, 2013^258^ Quintero, 2012^120^ (COLONPREV) Dancourt, 2008^225^ MACS group, 2006^255^ Faivre, 2004^113^ Kewenter, 1996^405^ (Göteborg) Lindholm, 2008^118^ Mandel, 1993^147^ (Minnesota) Shaukat, 2013^127^ | Schoen, 2012^122^ (PLCO) Segnan, 2005^126^ (SCORE III) Gondal, 2003^283^ (NORCCAP) Hoff, 2009^284^ Atkin, 2002^133^ (UKFSST) Segnan, 2002^149^ (SCORE) Rasmussen, 1999^121^

* No articles included for harms of mSEPT9 or mtsDNA

Abbreviations: ACRIN = American College of Radiology Imaging Network National CT Colonography Trial; COCOS = COlonoscopy or COlonography for Screening; MACS = Multicentre Austrailian Colorectal-neoplasia Screening; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; UKFSST = UK Flexible Sigmoidoscopy Screening Trial.

### Overall Summary

Serious adverse events from screening colonoscopy or colonoscopy in asymptomatic persons is estimated at 4 perforations (k=26) (95% CI, 2 to 5) and 8 major bleeds (k=22) (95% CI, 5 to 14) per 10,000 procedures. Serious adverse events from screening FS are even less common, with a pooled estimate of 1 perforation (k=17) (95% CI, 0.6 to 3) and 3 major bleeds (k=11) (95% CI, 1 to 9) per 10,000 procedures. FS, however, may require followup diagnostic or therapeutic colonoscopy. From six FS screening trials, the pooled estimate was 14 perforations (95% CI, 9 to 26) and 34 major bleeds (95% CI, 5 to 63) per 10,000 followup colonoscopy procedures for positive screening FS. While we found no studies addressing serious harms of stool-based (or blood/serum-based) tests, patients with false-positive test results also experience the risk of serious adverse events associated with diagnostic colonoscopy. The rate of perforation for followup colonoscopies for stool-positive testing may be higher—the pooled estimate was 8 perforations (k=6) (95% CI, 2 to 32) per 10,000 diagnostic colonoscopy procedures.

Other serious harms from endoscopy are not routinely reported or defined. Very few studies of endoscopy harms reported rates of adverse events in nonendoscopy comparator arms. Only two studies compared harms other than perforation and bleeding in a control group; both of these studies did not find a statistically significantly higher risk of serious harms due to colonoscopy (including myocardial infarction [MI], cerebrovascular accident [CVA], other cardiovascular events, and mortality). Because of reporting bias around serious harms other than perforation and bleeding, as well as the lack of evidence for other serious harms attributable to colonoscopy in limited studies with control groups (k=2), we did not quantitatively pool these rates of serious harms.

Eighteen studies provided analyses of differential harms of colonoscopy by age (groups). These studies generally found increasing rates of serious adverse events with increasing age, including perforation and bleeding. Only one study provided data on differential harms of FS by age, and this study did not find an increased risk of serious adverse events with increasing age.

Based on 15 studies, there is little to no risk of serious adverse events (e.g., symptomatic perforation) for screening CTC. While CTC may also require followup diagnostic or therapeutic colonoscopy, we did not find sufficient evidence to estimate serious adverse events from colonoscopy followup. CTC also entails exposure to low-dose ionizing radiation (range, 1 to 7 mSv). CTC also detects extracolonic findings, which could be a benefit or harm. Extracolonic findings are very common and are estimated to occur in 41 to 69 percent of examinations, although approximately 5 to 37 percent of examinations have extracolonic findings that necessitate actual diagnostic followup. An even smaller proportion of examinations have findings that require any type of definitive treatment (≤3%). From empirical evidence to date, it remains unclear if detection of extracolonic findings represents a net benefit or harm.

### Detailed Results

#### Screening Programs

##### gFOBT or FIT

Based on included studies for Key Question 1 and reported harms from national stool testing–based CRC screening programs, the main source of serious harms comes from diagnostic colonoscopies conducted after gFOBT or FIT positive results (Table 23). Only one included study was conducted in the United States, the Minnesota Colon Cancer Control Study, which evaluated Hemoccult II.147 Studies had varying number of rounds of screening (range, 1 to 11). Based on seven CRC screening studies (five trials and two cohort studies), the test positivity for stool testing ranged from 1.5 to 4.1 percent for gFOBT and 3.2 to 6.9 percent for FIT. Given the limited number of included studies (k=6), the estimates of harms are imprecise; nonetheless, the pooled estimate was 8 perforations (95% CI, 2 to 32; I^2^=60%) (Figure 16) and 1.9 major bleeds (95% CI, 5 to 64; I^2^=83%) (Figure 17) per 10,000 followup diagnostic colonoscopy procedures. From a single round of stool-based screening, assuming a 5 percent test positivity rate and 100 percent adherence to recommended followup colonoscopy, 1 to 16 persons would have a perforation and 2 to 32 persons would have major bleeding per 100,000 persons screened. Other types of serious harms were not commonly reported. No included studies reported differential diagnostic colonoscopy harms by age (groups).

Table 23 Key Question 3: Summary Table of Serious Adverse Events From Colonoscopy in Screening Programs

Screening Strategy | Study Quality | Recruited Population Country | Study Design Followup | Test Positivity, % Colonoscopies, n | Perforation, n (%) | Bleeding, n (%) | Mortality, n (%) | Other serious events, n (%)
gFOBT/FIT | Parente, 2013^258^ Fair | FIT positives Italy | Prospective NR | 6.2 (round 1); 5.8 (round 2) 4373 | 2 (0.05) | 5 (0.1) | NR | Hospitalization^††^: 5 (0.1)
gFOBT/FIT | Quintero, 2012^120^ Fair | FIT positives Spain | Prospective NR | 7.2 587 | 0 (0) | 8 (1.4) | NR | Hypotension or bradycardia: 2 (0.3)
gFOBT/FIT | Dancourt, 2008^225^ Fair | FOBT or FIT positives France | Prospective NR | 9.0 1205 | 0 (0) | 0 (0) | NR | NR
gFOBT/FIT | MACS group, 2006^255^ Fair | FIT positives Australia | Prospective 4 weeks | 3.2 4 | 0 (0) | 0 (0) | 0 (0) | 0 (0)
gFOBT/FIT | Faivre, 2004^113^ Fair | FOBT positives France | Prospective NR | 1.5 1298 | 0 (0) | 0 (0) | NR | NR
gFOBT/FIT | Kewenter, 1996^118,405^ Fair | FOBT positives (FS) or those with an adenoma above the sigmoid (colo) Sweden | Prospective NR | 4.1 FS: 2108 Colo: 190 | FS: 3 (0.1) Colo: 2 (1.1) | FS: 0 (0) Colo: 1 (0.5) | NR | NR
gFOBT/FIT | Mandel, 1993^127,147^ Good | FOBT positives US | Prospective NR | 2.4 (unhydrated slides) 9.8 (hydrated slides) 12246 | 4 (0.03) | 11 (0.09) | NR | NR
FS^†^ | Schoen, 2012^122^ PLCO Fair | FS positives€ US | Prospective NR | 28 17,672¥ | 19 (0.1) | NR | NR | NR
FS^†^ | Segnan, 2005^126,†^ SCORE II Fair | FS positivesθ Italy | Prospective NR | 7.6 332 | NR | 1 (0.3) | NR | Hospitalization^††^: 1
FS^†^ | Gondal, 2003^283,284^ NORCCAP Fair | FS or FS/FIT positivesα Norway | Prospective NR | 20.4 (FS or FS/FIT) 2524 | 6 (0.2) | 4 (0.2) | NR | Hospitalization^††^: 4 (0.2) Syncope: 24 (1.0)
FS^†^ | Atkin, 2002^133^ Fair | Patients with polyps meeting high-risk criteria^‡^ UK | Prospective 30 days | 5.3 2051 | 4 (0.2) | 9 (0.4) | 1 (0.05) | Hospitalization^††^: 9
FS^†^ | Segnan, 2002^149^ SCORE Fair | FS positivesδ Italy | Prospective 30 days | 8.4 775 | 1 (0.1) | 1 (0.1) | NR | 0 (0)
FS^†^ | Rasmussen, 1999^121^ Fair | FS or gFOBT positives£ Denmark | Prospective NR | 18–25 (FS); 1.4–4.9 (gFOBT) 502 | 0 (0) | 0 (0) | 0 (0) | 0 (0)

* Study has a comparison group

† Harms from the screening FS reported in Table 24

‡ High risk polyps included any of: diameter 1 cm or larger; three or more adenomas; tubulovillous or villous histology; severe dysplasia or malignancy; and 20 or more hyperplastic polyps above the distal rectum.

α FS positive includes any polyp ≥10 mm or a finding of any bioptically verified neoplasia, irrespective of its size

¥ exams, not patients

€ FS positive includes detection of a polyp or mass

δ FS positives includes those who had one distal polyp larger than 5 mm, or inadequate bowel preparation and at least one polyp, or invasive colorectal cancer. In a few cases the referral to colonoscopy was made by the endoscopist, based on his or her clinical judgment.

£ Persons with possible neoplasia detected at FS (all polyps >3 mm in diameter, and/or mucosal ulcerations, and/or stricturing carcinoma; persons with a positive Hemoccult II test

θ Subjects with polyps that were 10 mm or larger, as well as those who had “ high-risk ” polyps smaller than 10 mm (i.e., patients whose polyps had any of the following features at histologic examination: more than two adenomas, a villous component of more than 20%, or high-grade dysplasia) were referred for colonoscopy. Subjects who had inadequate bowel preparation were also referred for colonoscopy if at least one polyp was identified during sigmoidoscopy.

†† Hospitalizations are not mutually exclusive from the perforation and serious bleeding patients

Abbreviations: FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; FOBT = fecal occult blood test; gFOBT = guaiac fecal occult blood test; MACS = Multicentre Austrailian Colorectal-neoplasia Screening; n = number; NORCCAP = Norwegian Colorectal Cancer Prevention; NR = not reported; PLCO = Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; UK = United Kingdom; US = United States; UKFSST = UK Flexible Sigmoidoscopy Screening Trial.

Figure 16 Key Question 3: Forest Plot of Perforations From Followup Diagnostic/Therapeutic Colonoscopy, Post Fecal Occult Blood Test*

* I^2^ = 60.04%

Abbreviations: CI = confidence interval; PL = Profile Likelihood

Figure 16 displays a forest plot of perforations from followup diagnostic/therapeutic colonoscopy, post fecal occult blood test. The pooled event rate is 8 perforations per 10,000 procedures, with a 95% CI of 2 to 32 per 10,000.

Figure 17 Key Question 3: Forest Plot of Major Bleeding From Followup Diagnostic/Therapeutic Colonoscopy, Post Fecal Occult Blood Test*

Abbreviations: CI = confidence interval; PL = Profile Likelihood

I^2^ = 83.02%

Figure 17 displays a forest plot of major bleeding from followup diagnostic/therapeutic colonoscopy, post fecal occult blood test. The pooled event rate is 19 major bleeds per 10,000 procedures, with a 95% CI of 5 to 64 per 10,000.

##### FS

Screening programs of FS can accrue harms from either the screening FS or followup diagnostic or therapeutic colonoscopy. For harms of screening attributed to FS alone, please see the section below. Five included trials for Key Question 1 evaluating FS screening reported harms from followup colonoscopy (Table 23). Only one trial, PLCO, was conducted in the United States.122 This was also the only trial that evaluated more than a single round of screening. Based on these trials, 5 to 33 percent of participants received diagnostic or therapeutic colonoscopy. Again, given the limited number of studies (k=5), the estimates of harms are imprecise. The pooled estimate was 1.4 perforations (95% CI, 9 to 26; I^2^=0%) (Figure 18) and 3.4 major bleeds (95% CI, 5 to 63; I^2^=8%) (Figure 19) per 10,000 followup colonoscopy procedures after positive screening FS. Therefore, from one round of FS screening, assuming a 25 percent referral rate to colonoscopy and 100 percent adherence to recommended followup, approximately 22 to 65 persons would have a perforation and 12 to 158 persons would have major bleeding per 100,000 persons screened; this is in addition to harms accrued directly from FS (6 to 30 perforations and 10 to 90 major bleeds) (see below). Other reported serious harms included hospitalizations, MI, and syncope, but because these were not commonly reported, we do not provide a summary estimate of their likelihood of occurrence. No included studies reported differential diagnostic or therapeutic colonoscopy harms by age (groups).

Figure 18 Key Question 3: Forest Plot of Perforations From Followup Diagnostic/Therapeutic Colonoscopy, Post Flexible Sigmoidoscopy*

* I^2^ = 0%

Abbreviations: CI = confidence interval; PL = Profile Likelihood

Figure 18 displays a forest plot of perforations from followup diagnostic/therapeutic colonoscopy, post flexible sigmoidoscopy. The pooled event rate is 14 perforations per 10,000 procedures, with a 95% CI of 9 to 26 per 10,000.

Figure 19 Key Question 3: Forest Plot of Major Bleeding From Followup Diagnostic/Therapeutic Colonoscopy, Post Flexible Sigmoidoscopy*

* I^2^ = 7.57%

Abbreviations: CI = confidence interval; PL = Profile Likelihood

Figure 19 displays a forest plot of major bleeding from followup diagnostic/therapeutic colonoscopy, post flexible sigmoidoscopy. The pooled event rate is 7 major bleeds per 10,000 procedures, with a 95% CI of 5 to 12 per 10,000.

#### FS

We found 18 fair- or good-quality studies111,121,122,126,131,133,149,235,238,243,250,255,269,276,278,279,283,290 (in 21 articles17,33,111,121,122,126,131,133,149,235,238,243,250,255,269,276,278,279,283,284,290) that evaluated serious harms from screening FS in a general-risk population (Table 24). Five of these studies were retrospective cohort studies designed to assess for harms of screening FS;238,243,250,276,278 the remaining 13 were prospective.111,121,122,126,131,133,149,235,255,269,279,283,290 Five studies were conducted in the United States.122,238,250,276,279 The length of followup to determine harms was not commonly reported, but when reported, was approximately 1 month. Despite some clinical heterogeneity, given the stringency of our inclusion criteria, and focusing on estimates of harms in the community practice setting, we quantitatively combined rates for commonly reported serious harms (i.e., perforation and bleeding). Other serious harms (e.g., hospitalization, MI, syncope, serious gastrointestinal conditions other than perforation/bleeding) were not commonly or consistently defined and/or reported.

Table 24 Key Question 3: Summary Table of Serious Adverse Events From Screening Flexible Sigmoidoscopy

Study Design | Study Quality | Recruited Population Country | Number of Endoscopists Completion Rate, % | Mean Age, years Female, % | Followup | Sigmoidoscopies, n | Perforation, n (%) | Bleeding, n (%) | Mortality, n (%) | Other serious events, n (%)
Prospective | Schoen, 2012^122^ Fair | Screening US | NR NR | NR 50 | NR | 67,071 | 3 (0.004) | NR | NR | NR
Prospective | Senore, 2011^269^ Fair | Screening Italy | NR NR | NR 49 | 30 days | 1502 | 0 (0) | 12 (0.8)δ | NR | Hospitalization: 16 ED: 2 Other: 18 (CVD, hernia, severe pain, hypotension)
Prospective | MACS group, 2006^255^ Fair | Screening Australia | NR NR | NR 49 | 4 weeks | 52 | 0 (0) | 0 (0) | NR | 0 (0)
Prospective | Segnan, 2005^126^ Fair | Screening Italy | NR 87 (to distal) | NR 52^‡^ | NR | 4466 | NR | 0 (0) | NR | Syncope: 1
Prospective | Gondal, 2003^283,284^ Fair | Screening Norway | NR NR | NR 66 | NR | 12,960 | 0 (0) | 0 (0) | NR | Syncope: 26 Other: 1 (PE)
Prospective | Atkin, 2002^133^ Fair | Screening UK | NR NR | NR 50 | 30 days | 40,332 | 1 (0.002) | 12 (0.03) | 6 (0.01) | Hospitalization: 12 MI: 2 Syncope: 95 Other: 1 (PE)
Prospective | Segnan, 2002^149^ Fair | Screening Italy | NR 84 (to distal) | NR 50 | 30 days | 9911 | 1 (0.01) | 0 (0) | NR | Other: 4 (colitis, seizure)
Prospective | Hoff, 2001^17,33,235^ Fair | Screening Norway | NR NR | NR NR | NR | 355 | 0 (0) | 0 (0) | 0 (0) | Hospitalization: 1^**^ Other: 0
Prospective | Rasmussen, 1999^121^ Fair | Screening Denmark | 15 85 (60 cm) | NR NR | NR | 2235 | 0 (0) | 0 (0) | 0 (0) | Other: 0 (0)
Prospective | Wallace, 1999^279^ Fair | US Screening | 18 77 (50 cm) | 59 50 | NR | 3701 | 0 (0) | 0 (0) | 0 (0) | NR
Prospective | Atkin, 1998^290^ Fair | Screening UK | NR NR | NR NR | NR | 1285 | NR | 40 (3.1)δ | 1 (0.08) | Hospitalization: 1 MI: 1 Syncope: 1 Other^†^: 1 (severe diarrhea)
Prospective | Verne, 1998^131^ Fair | Screening UK | 1 NR | NR 49 | NR | 1116 | 0 (0) | 0 (0) | NR | Other: 0 (0)
Prospective | Brevinge, 1997^111^ Fair | Screening Sweden | NR NR | NR 49 | NR | 1431 | NR | 1 (0.07) | NR | Other: 1 (diverticulitis)
Retrospective | Kim, 2013^243^ Fair | Mixed (including symptomatic) South Korea | NR NR | NR 63 | NR | 20,653 | 1 (0.005) | NR | NR | NR
Retrospective | Tam, 2013^276^ Fair | Screening US | NR NR | NR NR | NR | 46,158 | 1 (0.002) | NR | 5 (0.004)β | Other: 4 (0.003) (“long-term complications”)β
Retrospective | Viiala, 2007^278^ Fair | Screening Australia | NR 73 (50 cm) | 60 41 | NR | 3402 | 0 (0) | 0 (0) | NR | NR
Retrospective | Jain, 2002^238^ Fair | Screening US | NR NR | NR NR | NR | 5017 | 0 (0) | 0 (0) | 0 (0) | NR
Retrospective | Levin, 2002^250^ Fair | Screening US | NR NR | 61 49 | 4 weeks | 109,534 | 2 (0.002) | 2 (0.002) | 10 (0.009) | MI: 33 Other^†^: 3 (GI serious adverse events)

* Study has a comparison group

** Unclear if this hospitalization is from the bowel prep for FS or colonoscopy

† Other serious adverse events are mutually exclusive from perforation, bleeding, MI, syncope

‡ All groups screened

δ Unspecified bleeding

β For those with perforations only (n=26), includes patients with perforations from mixed population colonoscopy as well as screening FS (n=132,259).

Abbreviations: cm = centimeters; CVD = cardiovascular disease; ED = emergency department; FS = flexible sigmoidoscopy; GI = gastrointestinal; MACS = Multicentre Austrailian Colorectal-neoplasia Screening; MI = myocardial infarction; n = number; PE = pulmonary embolism; UK = United Kingdom; US = United States.

Based on 16 studies (n=329,698),121,122,126,131,133,149,235,238,243,250,269,276,278,279,283,290 we found that perforations from FS in average-risk screening populations were relatively uncommon, with a pooled point estimate of 1 perforation per 10,000 procedures (95% CI, 0.4 to 1.4; I^2^=18.4%) (Figure 20). Based on 10 studies (n=137,987),111,121,131,133,149,235,238,250,278,279 we found that major bleeding episodes from FS were also relatively uncommon, with a pooled point estimate of 2 major bleeding episodes per 10,000 procedures (95% CI, 0.7 to 4; I^2^=52.5%) (Figure 21). Because of limitations in reporting, it is unclear if perforation and bleeding result from FS with biopsy. Exploratory meta-regressions were limited because of the number of included studies; nonetheless, none of the study-level characteristics investigated appeared to significantly affect estimates of FS harms.

Figure 20 Key Question 3: Forest Plot of Perforations From Flexible Sigmoidoscopy* **

* I^2^ = 18.39%

** One trial has been excluded from the meta-analysis due to very small n (n=52).255 There were no episodes of serious bleeding or perforation in the study.

Abbreviations: CI = confidence interval; n = number; RE = restricted maximum likelihood;

Figure 20 displays a forest plot of perforations from flexible sigmoidoscopy. The pooled event rate is 0.74 perforations per 10,000 procedures, with a 95% CI of 0.40 to 1.35 per 10,000.

Figure 21 Key Question 3: Forest Plot of Major Bleeding From Flexible Sigmoidoscopy* **

* I^2^ = 52.52%

** One trial has been excluded from the meta-analysis due to very small n (n=52).255 There were no episodes of serious bleeding or perforation in the study.

Abbreviations: CI = confidence interval; n = number; RE = restricted maximum likelihood;

Figure 21 displays a forest plot of major bleeding from flexible sigmoidoscopy. The pooled event rate is 1.76 major bleeds per 10,000 procedures, with a 95% CI of 0.70 to 4.41 per 10,000.

No studies reported serious harms (other than mortality) as compared to a nonscreened group. There was no difference in all-cause mortality between screened and unscreened groups. Average age in these studies was not commonly reported. No studies appeared to be conducted in exclusively older adults. Only one study provided information on differential harms by age, and found that age (50–59, 60–69, and 70–79 years) was not a significant predictor of risk for serious adverse events due to FS.250

#### Colonoscopy

We found 55 fair- or good-quality studies that evaluated serious harms from colonoscopy (Table 25).48,50,120,128,160,162,180,183,209,210,212,214–217,221–224,226,232,234,236,239,240,242,243,247,248,251,252,254–256,263–266,268–271,273–276,280,281,291 213,219,245,249,267,282 Twenty-four studies were conducted explicitly and exclusively in screening populations (or reported harms specific to the screening subgroup);48,50, 120,128,160,162,180,183,210,214,217,223,224,242,248,255,256,263,269,273–275,281,282 five studies were conducted in asymptomatic (but not necessarily screening) populations213,219,245,249,267 and 26 studies were conducted in mixed populations (including nonscreening colonoscopies).209,212,215,216,221,222,226,232, 234,236,239,240,243,247,251,252,254,264–266,268,270,271,276,280,291 Thirty-one of these 54 studies were retrospective cohort studies,209,212,214–216,221,222,224,226,232,234,236,239,240, 243,247–249,252,254,265–268,271,273,274, 276,280–282 while the other 24 were prospective study designs.48,50,120,128,160,162,180,183,210,213,217,219,223, 242,245,251,255,256,263,264,269,270,275,291 Twenty-six studies were conducted in the United States.50,183,209, 212,214,215,219,221,222,226,232,239,242,245,247–249,256,264,266,267,276,280–282,291 The length of followup to determine harms was not commonly reported, but when reported ranged from 3 days to almost 2 years (most commonly approximately 30 days or 1 month). Despite the clinical heterogeneity, we quantitatively combined rates for commonly reported serious harms (i.e., perforation and bleeding), given the stringency of our inclusion criteria, and focused on estimates of harms in the community practice setting. Other serious harms (e.g., hospitalization, emergency department visits, MI, syncope, infection, other severe gastrointestinal symptoms, other cardiopulmonary events, splenic injury, acute kidney injury) were not consistently defined and/or reported.

Table 25 Key Question 3: Summary Table of Serious Adverse Events From Screening Colonoscopy

Study Design | Study Quality | Recruited Population Country | Number of Endoscopists Completion Rate, % | Mean Age, years Female, % | Followup | Colonoscopies, n | Perforation, n (%) | Bleeding, n (%) | Mortality, n (%) | Other serious events, n (%)
Prospective | Adler, 2013^210^ Fair | Screening Germany | 21 98 | 64 53 | NR | 12,134 | NR | NR | NR | NR^***^
Prospective | Castro, 2013^219^ Fair | Mixed (including symptomatic) US | NR NR | 56 74 | 30 days | 3355 | 3 (0.09) | 1 (0.03) | NR | Other: 4 (severe pain, cardiopulmonary event)
Prospective | Chiu, 2013^162^ Fair | Screening Taiwan | 7 NR | 60 41 | NR | 18296 | 0 (0) | NR | NR | NR
Prospective | Ng, 2013^180^ Fair | Screening Hong Kong | NR NR | 58 55 | NR | 4539 | 0 (0) | 0 (0) | NR | NR
Prospective | Pox, 2012^263^ Fair | Screening Germany | >2100 NR | 65 56 | NR | 2,821,392 | 439 (0.02) | 573 (0.02) | 2 (0.00007) | Other: 128 (cardiopulmonary and “other major”)
Prospective | Quintero, 2012^120^ COLONPREV Fair | Screening Spain | NR NR | NR NR | NR | 4953 | 1 (0.02) | 12 (0.2) | NR | Other: 11 (cardiopulmonary event)
Prospective | Stoop, 2012^128^ COCOS Fair | Screening The Netherlands | 5 98 | 61 49 | 4 weeks | 1276 | 0 (0) | 2 (0.2) | 1 (0.08)^**^ | Other: 3 (infection)
Prospective | Suissa, 2012^275^ Fair | Screening Israel | NR NR | 58 NR | NR | 839 | 0 (0) | 0 (0) | NR | NR
Prospective | Zalis, 2012^183^ Fair | Screening US | NR NR | 60 47 | NR | 618 | 0 (0) | 0 (0) | NR | NR
Prospective | Ferlitsch, 2011^48^ Fair | Screening Austria | NR 96 | NR 51 | NR | 44,350 | 3 (0.007) | 54 (0.1)€ | 0 (0) | Other: 111 (“clinically relevant complication”)
Prospective | Loffeld, 2011^251^ Fair | Mixed (including symptomatic) The Netherlands | NR NR | NR NR | NR | 19,135 | 26 (0.1) | NR | NR | NR
Prospective | Senore, 2011^269^ SCORE III Fair | Screening Italy | NR NR | NR 49 | 30 days | 1198 | 0 (0) | 15 (1.2) € | NR | Hospitalization: 11 ED: 2 Other: 7 (CVD, hernia, severe pain, GI symptom)
Prospective | Ko, 2010^245^ Fair | Mixed (excluding symptomatic) US | NR NR | NR 45 | 30 days | 21,375 | 4 (0.02) | 34 (0.2) | 3 (0.01) | MI: 12 (includes angina) Other: 27 (infection, CVA, severe pain)
Prospective | Bair, 2009^213^ Fair | Screening Canada | 9 99 | 57 52 | NR | 3741 | 1 (0.03) | 2 (0.05) | NR | NR
Prospective | Bokemeyer, 2009^217^ Fair | Screening Germany | 280 NR | NR 56 | NR | 269,144 | 55 (0.02) | 442 (0.16) | NR | Other: 222 (cardiopulmonary event)
Prospective | Quallick, 2009^264^ Fair | Mixed (including symptomatic) US | NR NR | NR NR | NR | 39,054 | 4 (0.01) | NR | NR | NR
Prospective | Johnson, 2008^50^ ACRIN Fair | Screening US | NR NR | 58 52 | NR | 2531 | 0 (0) | 1 (0.04) | NR | Hospitalization: 2 Other: 1 (infection)
Prospective | Kim, 2007^*,242^ Fair | Screening US | 10 NR | 58 56 | NR | 3163 | 7 (0.2) | NR | NR | NR
Prospective | Ko, 2007^291^ Fair | Mixed (including symptomatic) US | 8 99 | NR 51 | 30 days | 502 | 0 (0) | 3 (0.6) | NR | Hospitalization: 2 ED: 2 Other: NR
Prospective | MACS group, 2006^255^ Fair | Screening Australia | NR NR | NR 49 | 4 weeks | 63 | 0 (0) | 0 (0) | NR | 0 (0)
Prospective | Cotterhill, 2005^223^ Fair | Screening Canada | NR 94 | NR 44 | NR | 324 | 0 (0) | 0 (0) | NR | NR
Prospective | Cheng, 2002^160^ Fair | Screening Taiwan | NR 99 | 47 45 | NR | 7411 | 2 (0.03) | 5 (0.07) | 0 (0) | Hospitalization: 0 (0)
Prospective | Nelson, 2002^256^ Fair | Screening US | NR 97 | 63 3 | 30 days | 3196 | 0 (0) | 7 (0.2)^§^ | 3 (0.09) | MI: 4 (includes CVA) Other: 19 (infection, CV event, syncope)
Prospective | Sieg, 2001^270^ Fair | Mixed (including symptomatic) Germany | 94 95 | NR NR | NR | 96,665 | 13 (0.01) | 17 (0.02) | 2 (0.002) | Other: 12 (cardiopulmonary events)
Retrospective | Adeyemo, 2014^209^ Fair | Mixed (including symptomatic) US | NR NR | 61 54 | NR | 118,004 | 48 (0.04) | NR | NR | NR
Retrospective | Bielawska, 2014^215^ Fair | Mixed (including symptomatic) US | NR NR | NR 48 | NR | 1,144,900 | 192 (0.02) | NR | NR | NR
Retrospective | Blotiere, 2014^216^ Fair | Mixed (including symptomatic) France | NR NR | NR 56 | 3 days | 947,061 | 424 (0.04) | 182 (0.02) | NR | NR
Retrospective | Layton, 2014^406^ Fair | Screening US | NR NR | 59 40 | 6 months | 550,696 | NR | NR | NR | AKI^††^: 1595
Retrospective | Zafar, 2014^282^ Fair | Screening US | NR NR | 74 55 | 30 days | 54,039 | 46 (0.08) | 371 (0.7) | NR | Other: 921 (CVD or other GI events)
Retrospective | Chukmaitov, 2013^221^ Fair | Mixed (including symptomatic) US | NR NR | NR 54 | 30 days | 2,315,126 | 773 (0.03) | 3822 (0.2) | NR | NR
Retrospective | Cooper, 2013^222^ Fair | Mixed (including symptomatic) US | NR NR | 76 55 | 30 days | 100,359 | 101 (0.1) | NR | 291 (0.2) | Other: 185 (splenic injury, aspiration)
Retrospective | Dominitz, 2013^226^ Fair | Mixed (including symptomatic) US | 18,578 NR | NR 58 | 30 days | 328,167 | 374 (0.1) | 2299 (0.7)€ | NR | Hospitalization: 10,478 ED: 14,278
Retrospective | Hamdani, 2013^232^ Fair | Mixed (including symptomatic) US | NR NR | NR 51 | 7 days | 80,118 | 50 (0.06) | NR | NR | NR
Retrospective | Kim, 2013^243^ Fair | Mixed (including symptomatic) South Korea | NR NR | NR NR | NR | 94,632 | 26 (0.03) | NR | NR | NR
Retrospective | Stock, 2013^*,273^ Good | Screening Germany | NR 100 | 66 55 | 30 days | 8658 | 7 (0.08) | 4 (0.05) | 5 (0.06) | MI: 2 Other: 8 (CV, splenic injury, syncope)
Retrospective | Tam, 2013^276^ Fair | Mixed (including symptomatic) US | NR NR | NR NR | NR | 86,101 | 25 (0.03) | NR | NR | Other: 4 (“long-term complications”) £
Retrospective | Ho, 2012^234^ Fair | Mixed (including symptomatic) Canada | NR NR | NR 52 | 7 days | 50,660 | NR | NR | ≤13 | Hospitalization: 534 ED: 682 Other: 1218 (not specified)
Retrospective | Rutter, 2012^267^ Fair | Mixed (excluding symptomatic) US | NR NR | NR 51 | 30 days | 43,456 | 21 (0.05) | 122 (0.3) | 15 (0.03) | Hospitalization: 508 ED: 1019
Retrospective | Sagawa, 2012^268^ Fair | Mixed (including symptomatic) Japan | NR NR | 67 38 | NR | 10,826 | 8 (0.07) | NR | NR | NR
Retrospective | Lorenzo-Zuniga, 2010^252^ Fair | Mixed (including symptomatic) Spain | NR NR | 57 NR | NR | 25,214 | 13 (0.05) | 59 (0.2) | NR | NR
Retrospective | Xirasagar, 2010^281^ Fair | Mixed (including symptomatic) US | 51 98 | 58 52 | NR | 10,958 | 2 (0.02) | 1 (0.009) | NR | Other: 3 (severe pain, aspiration, AKI)
Retrospective | Arora, 2009^212^ Fair | Screening US | NR NR | NR NR | 7 days | 58,457 | 39 (0.07) | NR | NR | NR
Retrospective | Berhane, 2009^214^ Fair | Screening US | NR 98 | NR NR | NR | 11,808 | 2 (0.02) | 5 (0.04) | 0 (0) | MI: 1 Other: 8 (CV event other than MI)
Retrospective | Crispin, 2009^224^ Fair | Screening Germany | NR 98 | NR 56 | NR | 55,993 | 22 (0.04) | 10 (0.02) | NR | Other: 39 (cardiopulmonary events)
Retrospective | Hsieh, 2009^236^ Fair | Mixed (including symptomatic) Taiwan | NR NR | 51 42 | NR | 9501 | 3 (0.03) | NR | NR | NR
Retrospective | Kamath, 2009^239^ Fair | Mixed (including symptomatic) US | NR NR | NR NR | 22 months (median) | 296,248 | NR | NR | NR | Splenic injury^‡^: 7
Retrospective | Singh, 2009^271^ Fair | Mixed (including symptomatic) Canada | NR 65 | 59 56 | 30 days | 24,509£ | 29 (0.1) | 22 (0.09)€ | NR | MI: 3 Other: 17 (GI symptoms, infection, AKI)
Retrospective | Warren, 2009^*,280^ Good | Screening US | NR NR | NR NR | 30 days | 5349 | 3 (0.06) | 11 (0.2) | NR | MI: 13 Otherδ: 119 (GI symptoms or events, CV events)
Retrospective | Kang, 2008^240^ Fair | Mixed (including symptomatic) South Korea | NR NR | 60 36 | NR | 44,534£ | 53 (0.1) | NR | NR | NR
Retrospective | Mansmann, 2008^254^ Fair | Mixed (including symptomatic) Germany | NR 97 | 59 57 | NR | 236,087 | 69 (0.03) | 10 (0.004) | NR | Other: 152 (cardiopulmonary events)
Retrospective | Rabeneck, 2008^265^ Fair | Mixed (including symptomatic) Canada | NR NR | 61 54 | 30 days | 97,091 | 54 (0.06) | 137 (0.1) | 51 (0.05) (5 colo related or possibly colo related) | NR
Retrospective | Levin, 2006^249^ Fair | Mixed (excluding symptomatic) US | NR 70 | 62 40 | 30 days | 16,318 | 15 (0.09) | 15 (0.09) | 10 (0.06)θ | MI: 9 Other: 82 (not specified, unclear if bleeding and perf are included)^‡‡^
Retrospective | Rathgaber, 2006^266^ Fair | Mixed (including symptomatic) US | 8 98 | 60 52 | 30 days | 12,407 | 2 (0.02) | 11 (0.09) | 0 (0) | Other: 1 (CV)
Retrospective | Strul, 2006^†,274^ Fair | Screening Israel | NR NR | 60 53 | NR | 1177 | 0 (0) | 0 (0) | 0 (0) | Other: 1 (severe pain)
Retrospective | Korman, 2003^247^ Fair | Mixed (including symptomatic) US | 265 NR | NR NR | NR | 116,000 | 37 (0.03) | NR | NR | NR

*** Study reports “complications,” so they could not be categorized as serious

** Likely not attributable to colonoscopy

€ Unspecified bleeds

* Study has a comparison group

§ Only bleeds requiring hospitalization

†† Study focuses on harms of AKI

£ For colonoscopy and FS combined

‡ Study focuses on harms of splenic injury only

δ Harms from bleeding and perforation are mutually exclusive from other serious events.

θ 1 death directly related to colonoscopy

‡‡ No harms from screening colonoscopies (n=117)

† Prospective from 2002–2003, retrospective from 1996–2001

Abbreviations: ACRIN = American College of Radiology Imaging Network National CT Colonography Trial; AKI = acute kidney injury; COCOS = COlonoscopy or COlonography for Screening; CV = cardiovascular; ED = emergency department; GI = gastrointestinal; MACS = Multicentre Austrailian Colorectal-neoplasia Screening; MI = myocardial infarction; n = number; NR = not reported; SCORE = Screening for COlon Rectum; US = United States.

Based on pooling 26 studies (n=3,414,108) in screening or generally asymptomatic persons,48,50, 120,128,160,162,180,183,213,214,217,219,223,224,242,245,249,256,263,267,269,273–275,281,282 we found that perforations from colonoscopy were relatively uncommon, with a point estimate of 4 per 10,000 procedures (95% CI, 2 to 5; I^2^=86%) (Figure 22). Based on 22 studies (n=3,347,101),50,120,128,160,180,183,213,214, 217,219,223,224,245,249,256,263,267,273–275,281,282 we found that the risk of major bleeding from colonoscopy was 8 per 10,000 procedures (95% CI, 5 to 14; I^2^=97%) (Figure 23). Statistical heterogeneity was very high for all of these pooled analyses. We conducted exploratory meta-regressions to determine if certain a priori identified study level characteristics would affect estimates of harms for colonoscopy. Indication of colonoscopy (i.e., screening or asymptomatic, mixed population [asymptomatic and symptomatic], followup FOBT positive, and followup FS) affected estimates of perforation. As a result, we stratified results by indication. Retrospective study designs with mixed populations appeared to have statistically (but not clinically) significantly lower estimates of major bleeding.

Figure 22 Key Question 3: Forest Plot of Perforations From Colonoscopy, Asymptomatic Population* **

* I^2^ = 88.25%

** One trial has been excluded from the meta-analysis due to very small n (n=63).255 There were no episodes of serious bleeding or perforation in the study.

Abbreviations: CI = confidence interval; n = number; RE = restricted maximum likelihood

Figure 22 displays a forest plot of perforations from colonoscopy. The pooled event rate is 3.62 perforations per 10,000 procedures, with a 95% CI of 2.42 to 5.42 per 10,000.

Figure 23 Key Question 3: Forest Plot of Major Bleeding From Colonoscopy, Asymptomatic Population* **

* I^2^ = 98.34%

** One trial has been excluded from the meta-analysis due to very small n (n=63).255 There were no episodes of serious bleeding or perforation in the study.

Abbreviations: RE = restricted maximum likelihood; CI = confidence interval; n = number

Figure 23 displays a forest plot of major bleeding from colonoscopy. The pooled event rate is 8.21 major bleeds per 10,000 procedures, with a 95% CI of 4.95 to 13.61 per 10,000.

Only eight studies (n=204,614) explicitly reported if perforation or major bleeding was related to polypectomy or biopsy.48,50,128,213,251,266,270,271 Based on this limited subset of studies reporting adequate information, many of the perforations and most of the major bleeding may be from polypectomy—about 36 percent (15/42) of perforations and about 96 percent (49/51) of major bleeding. Only four studies reported risk of perforation or bleeding in a control group (persons without colonoscopy).120,212,273,280 The risk of perforation and bleeding was statistically significantly higher in the colonoscopy group in three of the four studies.120,212,280

Serious harms other than perforation or major bleeding were not routinely reported, including MI, diverticulitis, and mortality. About half of these studies (28 of 55) reported any harm other than bleeding or perforation. Furthermore, the types of additional serious harms (e.g., cardiopulmonary and gastrointestinal events) were not consistent. Most importantly, since the vast majority of studies had no comparator arm (nonscreened group), it is unclear if many of the additional serious harms that were reported can be related to the receipt of colonoscopy. Only two studies compared harms (other than perforation and bleeding) in persons who had a colonoscopy versus those who did not.273,280 Both of these studies did not find a statistically significant higher risk of serious harms due to colonoscopy (including MI, CVA, other cardiovascular events, and mortality). A few studies were designed to examine specific harms— splenic injury (k=1)239 and comparative harms of different bowel preparations (k=2).234,248 Splenic injury (rupture) is a rare but serious event previously described as case reports following colonoscopy. A large retrospective study found splenic injury in 0.002 percent (7/296,248) of colonoscopies, only one of which happened during a screening colonoscopy.239 Two studies that assessed harms compared PEG versus sodium phosphate bowel preparation and found greater risk of serious harm, including acute kidney injury, with PEG than with sodium phosphate, especially in older adults (age ≥65 years).234,248

Nineteen studies provided differential harms of colonoscopy by age (groups) (Appendix E).48,209, 212,215,216,221,222,224,232,245,247,249,252,254,263,265,267,280,282 Only two studies provided differential harms limited to screening populations, one in Australia (n=44,350)48 and another in the United States (n=55,423).282 The Australian study found that cardiopulmonary adverse events increased with age, from 0.05 percent in ages 50–60 years to 0.25 percent in ages 70–80 years (p<0.001), whereas bleeding events were similar (p=0.23).48 The U.S. study in a Medicare population found that increasing age was associated with higher odds of serious bleeding, perforation, other gastrointestinal events, and cardiovascular events from either colonoscopy (n=54,039) or CTC (n=1,384), although only cardiovascular events were statistically significant.282 The remaining 17 studies were large studies of colonoscopy harms in mixed populations (n>10,000), including but not limited to screening colonoscopy. Serious adverse events were not reported by age for the screening subgroups in these studies. In general, studies of colonoscopy performed for mixed indications found increasing risk of serious adverse events with increasing age, including bleeding, perforation, and serious 30-day serious adverse events,. Seven studies reported increasing age as a risk factor for serious adverse events after adjusting for potential confounders.215,216,221,222,245,267,280 Only two studies explicitly included indication for colonoscopy as a confounder in their multivariate analyses; both found increased harms with increasing age after adjusting for confounders, including indication for colonoscopy.215,267 We also used study-level age in our exploratory meta-regressions for our meta-analyses, and it did not appear to affect estimates of perforation or major bleeding. However, average age was not always reported, and only six studies were exclusively conducted in older adults (age ≥65 years) or had a mean age of 65 years or older.222,226,234,263, 273,280

#### CTC

##### Serious Adverse Events

We found 15 fair- to good-quality studies that addressed serious adverse effects of screening CTC (Table 26).49–51,128,165,170,183,211,228,237,242,255,262,272 Eleven of these were prospective studies that were restricted to screening populations, three were large retrospective studies conducted in mixed populations (including but not limited to screening examinations),237,262,272 and one was a retrospective study conducted in a mixed population that presented screening results separately.282 The most commonly reported serious adverse event was perforation, which can happen due to insufflation. Other nonserious adverse events included gastrointestinal symptoms such as abdominal pain, due to either the bowel preparation or the CTC examination, and vasovagal syncope or presyncope. The mean age ranged from 51 to 77 years, although age was not routinely reported.

Table 26 Key Question 3: Summary Table of Serious Adverse Events From Screening CTC

Study Design | Study Quality | Recruited population Country | Followup | Readers | Mean Age Female, % | CTC exams | Perforations, n (%) | Other Serious Adverse Events
Prospective | Fletcher, 2013^165^ Fair | Screening US | NR | 2 | 56 (median) 58 | 568 | 0 (0) | No serious adverse events
Prospective | Lefere, 2013^51^ Fair | Screening Portugal | NR | 1 | 60 60 | 510 | 0 (0) | No serious adverse events
Prospective | Stoop, 2012^128^ Fair | Screening The Netherlands | 4 weeks | 3 | 61 48 | 982 | 0 (0) | Collapse: 1/982 (0.1) Myocardial infarction: 1/982 (0.1) Cerebrovascular accident: 1/982 (0.1)
Prospective | Zalis, 2012^183^ Fair | Screening US | NR | 3 | 60 47 | 618 | 0 (0) | No serious adverse events
Prospective | Graser, 2009^49^ Fair | Screening Germany | NR | 3 | 60 45 | 309 | 0 (0) | No serious adverse events
Prospective | An, 2008^211^ Fair | Screening South Korea | NR | 2 | 51 40 | 1015 | 0 (0) | No serious adverse events
Prospective | Johnson, 2008^50,193^ (ACRIN) Fair | Screening US | NR | 15 | 58 52 | 2531 | 0 (0) | Hospitalizations (total): 2/2531 (0.08)^*^ Severe nausea and vomiting: 1/2531 (0.04)
Prospective | Kim, 2008^170^ Fair | Screening South Korea | NR | 2 | 58 49 | 241 | 0 (0) | No serious adverse events
Prospective | Kim, 2007^242^ Fair | Screening US | NR | 5 | 57 56 | 3120 | 0 (0) | NR
Prospective | MACS group, 2006^255^ Fair | Screening Australia | 4 weeks | NR | NR 49 | 38 | 0 (0) | No serious adverse events
Prospective | Edwards, 2004^228^ Fair | Screening Australia | NR | 2 | NR 46 | 340 | 0 (0) | No serious adverse events
Retrospective | Zafar, 2014^282^ Fair | Screening US | 30 days | NR | 77 64 | 1384 | 1 (0.07) | Major bleeding events: 4 (0.3%) Other GI events: 5 (0.4) CVD events: 26 (1.9)
Retrospective | Iafrate, 2013^237^ Fair | Mixed (including symptomatic) Italy | NR | NR | NR NR | 40,121 | 7 (0.02) | Mortality: 0 Self-limiting vasovagal episodes: 63 (0.16; 95% CI, 0.09–0.3)
Retrospective | Sosna, 2006^272^ Fair | Mixed (including symptomatic) Israel | NR | 16 | 60 42 | 11,870 | 7 (0.06) (only 1 was in a screening patient) | Mortality: 0 (0)
Retrospective | Pickhardt, 2006^262^ Fair | Screening US, Belgium, Ireland, Italy, The Netherlands | NR | NR | NR NR | 11,707 | 0 (0) | NR

* after CTC and colonoscopy

Abbreviations: ACRIN = American College of Radiology Imaging Network National CT Colonography Trial; CI = confidence interval; CTC = computed tomographic colonography; MACS = Multicentre Austrailian Colorectal-neoplasia Screening; n = number; NR = not reported; US = United States.

Overall, the risk of perforation for screening CTC was less than 0.02 percent (2 per 10,000 CTC procedures). There were no perforations reported in 11 prospective studies (n=10,272) limited to screening populations.49–51,128,165,170,183,211,228,237,242,255,262,272 Evidence of any clinically significant adverse effects primarily came from four retrospective studies (n=65,082), which included both asymptomatic and symptomatic populations.237,262,272 These four studies suggested an increased risk of perforation in symptomatic compared to asymptomatic persons. Three of these studies specified perforation rates in the screening CTC subgroup.262,272,282 No perforations were reported in one study’s screening subgroup of 11,707 procedures.262 In the study by Sosna and colleagues, there was 1 screening-related perforation in 11,870 procedures (number of CTC screening procedures not reported).272 In one small study using Medicare claims data, 1 perforation was found among 1,384 screening CTC examinations.282 While there were 7 perforations in 40,121 procedures in a fourth study, the author states that none were due to mechanical insufflation, and five of the seven perforations occurred in persons who also had colonoscopy within 2 weeks.237 Results were not reported for screening-only examinations in this study. Limited data suggest that not all CTC-detected perforations are symptomatic or require any clinical management. In the study by Sosna and colleagues, for example, six of the seven perforations were detected only on CTC (number of symptomatic perforations not reported), and only four of the seven perforations required surgical intervention.272 In the study by Pickhardt and colleagues, only one of the two perforations was clinically symptomatic and required treatment.262

We found no studies that reported on the differential risk for serious harms of CTC by age. However, one study, ACRIN, noted that hospitalizations following both CTC and colonoscopy were greater in persons older than age 65 years.50

Radiation exposure per examination. Many of the CTC diagnostic accuracy studies in this review did not report actual radiation exposure or provide sufficient information to calculate it (Table 27). Based on four included diagnostic accuracy studies of CTC (published between 2008 and 2013), however, the estimated radiation dose for one full-screening CTC examination (dual positioning supine and prone) was about 4.5 to 7 mSv.49,50,165,183 Based on three additional recent CTC screening studies (2004–2008), the estimated radiation dose has decreased to a range of 1 to less than 5 mSv.211,228,255 A recent survey of academic and nonacademic institutions (62 of 109 responding) found that the median radiation dose per screening CTC examination was 4.4 mSv.292 In contrast, two older reviews provided estimates of radiation exposure and found a dose range per CTC examination (not limited to screening examinations) of 1.6 to 24.4 mSv, with a median dose estimate of 8.8 or 10.2 mSv.293,294 Overall, the body of evidence reflects a decrease in radiation exposure for CTC examinations over time due to newer multidetector scanners and protocols. Based on survey data and included studies, however, radiation exposure has not decreased significantly from 2007 to 2011.^292^

Table 27 Key Question 3: Radiation Exposure From Screening CTC

Author, Year | Total radiation exposure | Supine radiation exposure | Prone radiation exposure
Fletcher, 2013^165^ | 6–7 mGy | NR | NR
Lefere, 2013^51^ | NR | 50 mAs^*^ | 30 mAs^*^
Zalis, 2012^183^ | 5.3mSv | NR | NR
Graser, 2009^49^ | 4.5 mSv | 3.2 mSv | 1.3 mSv
An, 2008^211^ | 0.8–1.0 mSv | NR | NR
Johnson, 2008^50^ | 50 mAs^*^ | NR | NR
Kim, 2008^170^ | NR | 120 mAs^*^ | 50 mAs^*^
Johnson, 2007^169^ | 70 mAs^*^ | NR | NR
MACS group, 2006^255^ | <5 mSv | NR | NR
Edwards, 2004^228^ | 5 mSv | NR | NR
Macari, 2004^176^ | 50 mAs^*^ | NR | NR
Pickahrdt, 2003^52^ | 100 mAs^*^ | NR | NR

* mSv NR

Abbreviations: MACS = Multicentre Austrailian Colorectal-neoplasia Screening; mAs = milliamperage second; mGy = milligray; mSv = millisievert; NR = not reported.

We did not identify any study that directly measured the risk for stochastic effects (e.g., cancer) caused by radiation exposure from CTC. For context, we briefly consider the indirect evidence for the potential adverse effects of low-dose ionizing radiation in the Discussion section.

Extracolonic findings. Incidental extracolonic findings detected on CTC can be a benefit or a harm, depending on the finding. The CT Colonography Reporting and Data System (C-RADS) is a well-recognized standard for reporting CTC findings. Under C-RADS, extracolonic findings are categorized into five categories: E0=limited examination, E1=normal examination or normal variant, E2=clinically unimportant finding in which no workup is required, E3=likely unimportant or incompletely characterized finding in which workup may be required, and E4=potentially important finding requiring followup.295 Some studies examining extracolonic findings do not use the C-RADS classification system but instead a classification of “high,” “moderate,” or “low” clinical significance. “High” generally includes findings that require surgical treatment, medical intervention, or further investigation (e.g., indeterminate solid organ masses or chest nodules, abdominal aortic aneurysms ≥3 cm, aneurysms of the splenic or renal arteries, adenopathy >1 cm). Findings of “moderate” clinical significance do not require immediate medical attention but would likely require recognition, investigation, or treatment sometime in the future (e.g., calculi, small adrenal masses). Findings of “low” clinical significance do not require further investigation or treatment.

We found 21 studies (n=38,293)50,52,128,183,218,220,227,229–231,233,242,244,253,257,259–261,277,285,288 (seven studies with overlapping populations reported different extracolonic findings) in 22 articles50,52, 128,183,193,218,220,227,229–231,233,242,244,253,257,259–261,277,285,288 reporting on extracolonic findings in asymptomatic persons, 16 studies (n=35,409) in screening populations,50,52,128,183,220,227,229,242,244, 257,259–261,277,285,288 and five studies (n=2,884) in mixed asymptomatic populations (including those undergoing surveillance, those with positive stool testing or iron deficiency anemia, and those with family history) (Table 28).218,230,231,233,253 The number of examinations in these studies ranged from 75 to 10,286. The largest study (n=10,286) represented persons included in other studies but focused on different extracolonic malignancies only.260 In general, studies that reported extracolonic findings varied greatly in their ability to accurately assess followup and the duration of followup. The longest duration of followup was 5 years, but was often not reported. Thus, none of these studies are able to articulate the true net health benefit or harm due to extracolonic findings for persons undergoing CTC.

Table 28 Extracolonic Findings in Asymptomatic Persons Undergoing CT Colonography

Population | Author, Year Study design Quality | Population Followup | Categorization of extracolonic findings | Prevalence of extracolonic findings | Workup of extracolonic findings
Screening | Durbin, 2012^227^ Prospective Fair | N= 490 Asymptomatic, mean 60 years Followup: NR | Major: high clinical importance, required definitive management Moderate: Potential moderate clinical significance Minor: no or little clinical importance Only evaluated genitourinary findings | 10 (2%) persons with major genitourinary findings 86 (17.6%) persons with moderate genitourinary findings 100 (20.4%) with minor genitourinary findings | 25 (5.1%) had additional diagnostic evaluation 2 (0.4%) required surgical resection (clear cell renal carcinoma)
Screening | Stoop, 2012^128^ Prospective Fair | N= 982 Asymptomatic, mean 61 years Followup: NR | C-RADS | E3/E4: 107 (11%) | 94 (10%) had additional diagnostic evaluation [underlined: Findings of diagnostic evaluations:] 5 (0.5%) extracolonic cancer (4 renal-cell carcinoma, 1 duodenal carcinoma). 7 (0.7%) abdominal aortic aneurysms (3 underwent surgical treatment) 3 (0.3%) aneurysms of smaller vessel 1 (0.1%) low-risk myelofibrosis 1 (0.1%) Paget’s disease 1 (0.1%) glandular papilloma 76 (7.7%) benign lesions (19 kidney, 12 gynecological, 7 liver, 7 lung, 5 adrenal, 26 in other organs)
Screening | Zalis, 2012^183^ Prospective Fair | N= 605 Asymptomatic, mean 60 years Followup: chart review, timing NR | C-RADS | E3: 97 (16%) E4: 16 (3%) | 33 (5.5%) had additional diagnostic evaluation Diagnostic outcome NR
Screening | Pickhardt, 2010^*,260^ Prospective Fair | N= 10286 Asymptomatic, mean 60 years Followup: Chart review, 13–56 months | C-RADS | NR | 36 (0.35%) extracolonic malignancy after diagnostic workup (3 adrenal, 1 appendix, 1 stomach, 1 hepatocellular, 8 lung, 1 breast, 1 endometrial, 1 skin, 6 non-Hodgkin lymphoma, 2 prostate, 11 renal cell) 32 (0.31%) received treatment for malignancy 3 (0.03%) deceased upon followup
Screening | O’Connor, 2011^*,257^ Retrospective Fair | N= 3001 Asymptomatic, mean 57 years Followup: chart review, 3 years | Benign renal mass (masses containing fat or with attenuation <20 HU or >70 HU without thickened walls or septations, ≥3 septations, mural nodules, or thick clacifications. Indeterminate renal mass (attenuation 20 to 70 HU or any without thickened walls or septations, ≥3 septations, mural nodules, or thick calcifications) Evaluated renal masses only | 376 (12.5%) benign renal masses 57 (1.9%) indeterminate renal masses | 41 (1.4%) underwent additional diagnostic evaluation [underlined: Findings from diagnostic evaluation:] 4 (0.13%) identified with renal cell carcinoma 2 additional patients who had benign index masses were found to have renal cell carcinoma 3 years later, but did not originate from the index mass or any other identifiable mass on CTC.
Screening | Pickhardt, 2011^*,259^ Retrospective Fair | N= 3126 Asymptomatic, mean 57 years Followup: NR | Small hiatal hernia Moderate hiatal hernia Large hiatal hernia Evaluated hiatal hernias only | 1281 (41%) small hiatal hernia 194 (6.2%) moderate hiatal hernia 20 (0.64%) large hiatal hernia | Subsequent evaluation NR
Screening | Kim, 2007^*,242^ Prospective Fair | N=3120 98% asymptomatic, mean 57 years Followup: NR | C-RADS | E2: 1490 (47.8%) E3: 265 (8.5%) E4: 70 (2.2%) | 241 (7.7%) recommended to have additional diagnostic evaluation 8 (0.3%) patients with extracolonic cancer (treatment NR) (3 renal, 2 bronchogenic, 1 non-Hodgkin’s lymphoma, 1 endometrial, 1 GI stromal tumor)
Screening | Kim, 2010^*,285^ Retrospective Fair | N= 577 Assumed asymptomatic, mean 69 years Followup: Chart review, 17–62 months | C-RADS | E3/E4: 89 (15.4%) | 45 (7.8%) had subsequent evaluation. 21 (3.6%) had substantial but unsuspected diagnoses 18 (3.1%) vascular aneurysms 1 (0.2%) lung cancer 1 (0.2%) malrotation 1 (0.2%) femoral hernia
Screening | Pickhardt, 2008^*,288^ Prospective Fair | N=2195 Asymptomatic, mean 58 years Followup: chart review, up to 18 months | C-RADS | E4: 204 (9.3%) | 157 (7.2%) recommended to have additional diagnostic evaluation 133 (6.1%) had additional diagnostic evaluation (includes 18 patients with findings of less than moderate importance (not recommended)) 55 (2.5%) with confirmed diagnosis of an unsuspected condition of at least ‘moderate’ importance 9 (0.4%) had a malignant tumor (3 non-Hodgkin lymphoma, 3 renal cell carcinoma, 2 abdominal metastatic disease, 1 bronchogenic carcinoma) 22 (1.0%) required surgical procedures as followup [underlined: Findings of diagnostic evaluations:] 13 (0.6%) benign ovarian tumor 9 (0.4%) malignant tumor 12 (0.5%) aortoilaic aneurysm 4 (0.2%) congenital renal anomaly 3 (0.1%) obstructing urolithiasis 2 (0.1%) mucinous adenoma of appendix 2 (0.1%) endometriosis 2 (0.1%) porcelain gallbladder 1 (0.04%) polycystic disease 1 (0.04%) polysplenia 1 (0.04%) malrotation 1 (0.04%) hydrosalpinx
Screening | Pickhardt, 2007^*,261^ Prospective Fair | N=2014 Presumed asymptomatic, mean 57 years Followup: chart review, unclear duration | NR Only evaluated extracolonic GI tumors | 10 (0.5%) focal extracolonic GI tumors | 0.5% (10/2014) had further diagnostic evaluation (cancer locations: 3 stomach, 2 jejunum, 3 ileum, 2 appendix) 0.3% (7/2014) required surgical resection; 0.05% (1/2014) required endoscopic resection All GI tumors found to be benign
Screening | Veerappan, 2010^277^ Retrospective Fair | N= 2277 Assumed asymptomatic, mean 59 years Followup: Database, 6 months–4 years | C-RADS | E2–E4: 1037 (45.5%) E2: 787 (34.6) E3: 211 (9.3%) E4: 39 (1.7%) | 8.7% (199/2277) received additional diagnostic evaluation 0.83% (19/2277) required surgical treatment 0.26% (6/2277) found to have cancer (1 lung adenocarcinoma, 2 renal cell carcinomas, 1 bronchoalveolar carcinoma of the lung, 1 nodular lymphoma) 0.04% (1/2277) large abdominal aortic aneurysm (8 cm)
Screening | Johnson, 2008^50,193^ (ACRIN) Prospective Fair | N=2531 Asymptomatic, mean 58 years 50–64 years: N=2054 ≥65 years: N=477 Followup: NR | NR^†^ | E2–E4: 1665 (66%) 50–64 years: 1278 (62%) ≥65 years: 387 (81%) (E3)/E4^‡^ (requiring additional evaluation): 428 (17%) 50–64 years: 104 (5.1%) ≥65 years: 324 (68%) E4 (requiring urgent care): 50–64 years: 26 (1.3%) ≥65 years: 4 (0.8%) | Subsequent evaluation NR
Screening | Flicker, 2008^229^ Retrospective Fair | N= 210 Asymptomatic, mean 61 years Followup: Medical records, 1–76 months | C-RADS | E3: 30 (14.3%) E4: 6 (2.9%) | 6 (2.8%) received additional diagnostic imaging [underlined: Findings of diagnostic imaging:] 2 (1.0%) abdominal aortic aneurysms ≥3 cm 2 (1.0%) renal solid masses 1 (0.5%) liver solid mass 1 (0.5%) pneumoperitoneum
Screening | Kim, 2008^244^ Prospective Fair | N= 2230 Asymptomatic, mean 58 years Followup: Medical records, 1–3 years | C-RADS | E2–E4: 1484 (66.5%) E2: 1707 (76.5%) E3: 358 (16.1%) E4: 115 (5.2%) | 100 (4.5%) received additional diagnostic evaluation (15 patients did not need further imaging for treatment decisions) 45 (2.0%) required surgical or medical treatment [underlined: Findings of diagnostic evaluations:] 0.5% (12/2230) extracolonic cancer (5 renal cell, 3 hepatocellular, 1 pancreatic, 1 lung, 1 cervical, 1 stomach)
Screening | Chin, 2005^220^ Prospective Fair | N=432 Asymptomatic, mean 59 years Followup: through GP, 2 years | Clinically relevant: required medical or surgical attention, or further hematological, biochemical, and/or radiological investigation after reviewing patient’s medical history^†^ | E2–E4: 118 (27.3%) (E3)/E4^‡^: 32 (7.4%) | 32 (7.4%) required further diagnostic evaluation: [underlined: Findings of diagnostic evaluations:] 1 (0.2%) renal cell carcinoma 6 (1.4%) abdominal aortic aneurisms 1 (0.2%) splenic artery aneurysm 24 (5.5%) benign lesions
Screening | Pickhardt, 2003^**^ 52 Prospective Fair | N= 1233 Asymptomatic, mean 58 years Followup: NR | High, moderate, low importance^§^ | E4: 56 (4.5%) | Persons requiring diagnostic imaging: NR [underlined: Findings of diagnostic evaluations]: 5 (0.4%) extracolonic malignancy (1 lymphoma, 2 bronchogenic carcinoma, 1 ovarian cancer, 1 renal cancer) 2 (0.2%) underwent successful repair of unsuspected abdominal aortic aneurysms
Mixed (includes surveillance, individuals with family history, iron deficiency anemia) | Cash, 2012^218^ Prospective Fair | N= 1410 Asymptomatic, mean 75 years Followup: None | C-RADS | E3: 196 (13.9%) E4: 41 (2.9%) | Subsequent evaluation NR
Mixed (includes surveillance, individuals with family history, iron deficiency anemia) | Macari, 2011^253^ Retrospective Fair | N= 454 Assumed asymptomatic (16.5% positive guaiac test) (57.3% referred from incomplete colonoscopy), mean 62 years N=204 <65 N=250 ≥65 Followup: NR | C-RADS | E2–E4: 298 (66%) <65 years: 113 (55.4%) ≥65 years: 185 (74.0%) E3/E4: 24 (5.3%) <65 years: 9 (4.4%) ≥65 years: 15 (6.0%) | 10 (2.2%) additional diagnostic evaluation <65 years: 4 (2.0%) ≥65 years: 6 (2.4%)
Mixed (includes surveillance, individuals with family history, iron deficiency anemia) | Ginnerup, 2003^230^ Prospective Fair | N=75 Asymptomatic undergoing surveillance, median 61 years Followup: chart review, 6 months | NR^†^ | E2–E4: 49 (65%) (E3)/E4^‡^: 9 (12%) | 8 (11%) had further diagnostic evaluation 2 (3%) had surgery due to findings or adverse events of workup [underlined: Findings of diagnostic evaluations:] 1 (1.3%) Lung cancer (lung resection, died 1 year later) 1 (1.3%) Fatty sparing hepatic mass 1 (1.3%) Renal cyst 2 (2.7%) Adrenal incidentaloma 1 (1.3%) Endometrioma (surgical draining of infection after exam) 1 (1.3%) Ovarian cyst >4 cm 1 (1.3%) Fibromatous uterus
Mixed (includes surveillance, individuals with family history, iron deficiency anemia) | Gluecker, 2003^231^ Prospective Fair | N=681 Asymptomatic, median 64 years Followup: chart review, at least 12 months | High, moderate, low importance^§^ | E2–E4: 469 (69%) E2: 341 (50%) E3: 183 (27%) E4: 71 (10%) | 94 followup diagnostic procedures in patients with ‘high’ clinical importance findings 15 followup diagnostic procedures in 183 persons with ‘moderate’ clinical importance findings 9 (1%) needed treatment (1 AAA, 1 squamous cell carcinoma of the lung, 1 thyroid metastases to the lung, 1 renal adenocarcinoma, 1 renal oncocytoma, 3 serous cystadenoma of the ovary, 1 ileal ascariasis)
Mixed (includes surveillance, individuals with family history, iron deficiency anemia) | Hara, 2000^233^ Prospective Fair | N=264 Asymptomatic (high risk), 162 undergoing surveillance, age NR Followup: chart review, 7–22 months | High, moderate, low importance^§^ | E2–E4: 109 (41%) E2: 55 (21%) E3: 46 (17%) E4: 30 (11%) | 18 (6.8%) had further diagnostic evaluation 6 (2.3%) had surgery due to malignant or nonmalignant findings 4 (1.5%) required ongoing followup [underlined: Finding of diagnostic evaluations:] 2 (0.8%) Renal cancer (required surgery) 2 (0.8%) Abdominal aortic aneurysm 1 (0.4%) Pneumothorax (required surgery) 4 (1.6%) Indeterminate lesions (2 pulmonary nodules, 2 probable adrenal adenomas) 9 (3.4%) Benign lesions (Renal cysts 4, pulmonary granuloma 1, liver with focal fat 1, 4.2 cm AAA 1, hepatic cyst 1, splenic cyst 1)

* Overlapping populations from the University of Wisconsin screening program.

** From the University of Wisconsin screening program but in a non-overlapping time frame.

† Definitions for extracolonic findings in the publication are similar to C-RADS E1–E4 definitions and have been labeled as such

‡ Likely includes a portion of extracolonic findings corresponding to C-RADS E3

§ High importance: findings requiring surgical treatment, medical intervention, and/or further investigation during that patient care visit [similar to C-RADS E4], Moderate importance: benign findings that may eventually require medical or surgical intervention [similar to C-RADS E3], Low importance: unlikely to require any future treatment [similar to C-RADS E2]

Abbreviations: AAA = abdominal aortic aneurysm; cm = centimeter; C-RADS = Computed Tomographic Colonography Reporting and Data System; CTC = computed tomographic colonography; E1 = normal examination or anatomic variant; E2 = clinically unimportant finding; E3 = findings unlikely to be clinically significant; E4 = potentially clinically important findings; GI = gastrointestinal; GP = general practitioner; N = number; NR = not reported.

Overall, extracolonic findings were common among screening or surveillance CTC examinations and ranged from 27 to 69 percent for any extracolonic findings. Similarly, available studies suggested a very wide range of findings needing additional workup; 5 to 37 percent had E3 or E4 category findings and 1.7 to 12 percent had E4 category findings. Because E3 or E4 findings, as well as those of “moderate” or “high” clinical significance, generally require medical followup, the potential for significant additional morbidity and cost, as well as benefit, remains. Among the studies that also reported medical followup of extracolonic findings, between 1.4 and 11 percent went on to diagnostic evaluation, which closely mirrors the prevalence of E4 category findings. Among studies adequately reporting subsequent treatment, only a minority of findings (≤3%) required definitive medical or surgical treatment. Extracolonic cancers were not common and occurred in only 0.5 percent of persons undergoing CTC examinations. In the largest series of examinations (n=10,286), with about 4 years of followup, 36 (0.35%) examinations found an extracolonic malignancy, 32 of which received definitive treatment.260 Abdominal aortic aneurysm occurred in up to 1.4 percent of persons.

Based mostly on indirect comparisons, we did not find large differences in the prevalence of extracolonic findings (any or clinically significant) between studies limited to screening populations and those in asymptomatic persons. Extracolonic findings, however, may be more common with increasing age. The mean age in these studies ranged from 57 to 75 years. In the two studies with a mean age of 65 years or older, the percent with E3/E4 extracolonic findings was on average higher than in studies with younger mean ages.218,285 Two studies compared extracolonic findings in persons younger than age 65 years to those age 65 years and older.50,253 Both studies found a higher prevalence of both any extracolonic finding and extracolonic findings that warranted further workup (E3/E4).50,253