# Methods

## Scope and Purpose

The USPSTF will use this evidence review to update its 2008 recommendation statement on screening for CRC in conjunction with microsimulation decision models from the Cancer Intervention and Surveillance Modeling Network (CISNET).89 This review addresses the benefit and harms associated with CRC screening and the diagnostic accuracy of the individual screening tests currently available, and most commonly used, in U.S. clinical practice. While this review primarily updates our previous work to support the prior USPSTF recommendation,90 it also addresses evidence on new considerations, including:

1. Observational evidence on the benefits of screening tests or screening programs on cancer incidence and/or mortality for screening technologies without trial evidence (i.e., colonoscopy, CTC, high-sensitivity stool testing)
2. Comparative effectiveness of screening tests on cancer incidence and/or mortality
3. Diagnostic accuracy of newly available screening technologies (i.e., FDA-approved mtsDNA test, blood test)

## Key Questions and Analytic Framework

The analytic framework is presented in Figure 2.

Figure 2 Analytic Framework

Abbreviations: CTC = computed tomographic colonography; DNA = deoxyribonucleic acid; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; mSEPT9 = circulating methylated septin 9 gene deoxyribonucleic acid

Figure 2 is an analytic framework for the key questions of this report that depicts the events that adults age 40 years or older could experience while undergoing screening for colorectal cancer. In general, the figure illustrates how screening for colorectal cancer with colonoscopy, flexible sigmoidoscopy, CT colonography, fecal tests (gFOBT, FIT, fecal DNA), or a blood test (mSEPT9) could lead to detection of polyps or cancer and decrease colorectal cancer incidence and mortality and all-cause mortality.

### Key Questions

1 What is the effectiveness (or comparative effectiveness) of screening programs based on any of the following screening tests (alone or in combination) in reducing a) incidence of and b) mortality from CRC?
  i. Colonoscopy
  ii. FS
  iii. CTC
  iv. Stool screening tests:
    a. Any gFOBT
    b. FIT
    c. Stool DNA or multitarget stool test
  v. Blood screening test: mSEPT9
2 What are the test performance characteristics (e.g., sensitivity and specificity) of the following screening tests (alone or in combination) for detecting a) CRC, b) advanced adenomas, and/or c) adenomatous polyps based on size?
  i. Colonoscopy
  ii. FS
  iii. CTC
  iv. Stool screening tests:
    a. high-sensitivity gFOBT
    b. FIT
    c. Stool DNA or multitarget stool test
  v. Blood screening test: mSEPT9
3a What are the adverse effects (i.e., serious harms) of the different screening tests (either as single application or in a screening program)?
3b Do adverse effects vary by important subpopulations (e.g., age)?

## Data Sources and Searches

We searched MEDLINE, PubMed, and the Cochrane Central Register of Controlled Trials to locate relevant studies for all key questions. We searched for articles published from the end of our prior review (January 1, 2008) to December 31, 2014. We supplemented our database searches with expert suggestions and through reviewing reference lists from all other recent relevant existing systematic reviews. We also searched selected grey literature sources, including ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform, for ongoing trials.

## Study Selection

Two investigators independently reviewed 8,492 titles and abstracts using an online platform (abstrackr91) and 696 articles (Appendix B Figure 1) with specified inclusion criteria (Appendix B Table 1). We resolved discrepancies through consensus and consultation with a third investigator. We carried forward 33 studies (40 articles) from our prior review. Twenty-eight articles from the previous review were not included in this review due to differences in inclusion criteria. We excluded articles that did not meet inclusion criteria or those we rated as poor quality. Appendix C contains a list of all excluded trials.

Eligible studies included asymptomatic screening populations of individuals age 40 years and older at average risk for CRC or who were not selected for inclusion based on CRC risk factors. We excluded symptomatic populations or populations selected for personal or family history of CRC, known genetic susceptibility syndromes (e.g., Lynch syndrome, familial adenomatous polyposis), personal history of inflammatory bowel disease, previous screening test positive (e.g., gFOBT or FIT), iron deficiency anemia, or surveillance for previous colorectal lesion. In studies with mixed populations, we limited our inclusion to those with less than 50 percent surveillance populations and/or less than 10 percent with symptoms, positive gFOBT or FIT, or anemia. For studies of harms of screening, we allowed mixed populations (e.g., indications for colonoscopy or CTC not reported or detailed) if the sample was larger than 10,000 participants. This allowed us to include studies that may detect rare or uncommon harms. We arrived at the number 10,000 based on estimates derived from our previous systematic review.90 Because many studies reporting extracolonic findings on CTC limited population descriptions to asymptomatic or symptomatic, we included any studies in asymptomatic persons that could include persons at high risk for CRC (e.g., anemia, FOBT positive, personal history of CRC or colorectal lesions).

For the greatest applicability to U.S. practice, we focused on studies conducted in developed countries, as defined by “very high” development according to the United Nations Human Development Index. We included only studies that published their results in English because of resource constraints.

We included studies that evaluated the following screening tests: colonoscopy, FS, CTC, gFOBT, FIT, mtsDNA tests, and the blood test for mSEPT9. Although we did review the evidence for benefit of older-generation gFOBT (i.e., Hemoccult II) on cancer incidence and mortality (Key Question 1), we did not update the evidence of its test accuracy (Key Question 2) because it has been replaced with high-sensitivity gFOBT and FIT testing in U.S. practice. We excluded stool testing based on in-office digital rectal examination, DCBE, capsule endoscopy (i.e., PillCam), and MRC. We also excluded studies that primarily focused on evaluating technological improvements to colonoscopy or CTC. We excluded endoscopy studies conducted in primarily single-center research settings or those with a limited number of endoscopists (e.g., <5 to 10) in order to approximate test performance and harms of screening tests in community practice.

### Key Question 1

We included randomized or controlled trials of CRC screening versus no screening or another screening test. For screening tests without trial-level evidence (i.e., colonoscopy, FIT), we examined well-conducted prospective cohort or population-based nested case-control studies. We included trials and observational studies that shared outcomes of cancer incidence and/or CRC-specific or all-cause mortality. We excluded decision analyses because this review is paired with CISNET microsimulation models designed to compare the effectiveness and harms of different screening strategies.

### Key Question 2

We included diagnostic accuracy studies that used colonoscopy as a reference standard. We generally excluded studies whose design was subject to a high risk of bias, including studies that did not apply colonoscopy to at least a random subset of screen-negative persons (verification bias),92 although we made an exception for otherwise well-conducted diagnostic accuracy studies of FITs in which the screen-negative persons received registry followup (instead of colonoscopy) to determine cancer outcomes. We excluded studies without an adequate representation of a full spectrum of patients (spectrum bias) (e.g., case-control studies).92–96 Diagnostic accuracy studies had to include outcomes of test performance (i.e., sensitivity, specificity, positive and negative predictive value) for the detection of CRC, advanced adenoma, and/or adenomatous polyp by size (≤5, 6–9, or ≥10 mm). We also captured test performance by location in the colon (i.e., proximal vs. distal), when reported.

### Key Question 3

We included all trials or observational studies that reported serious adverse events requiring unexpected or unwanted medical attention and/or resulting in death. These events included, but were not limited to, perforation, major bleeding, severe abdominal symptoms, and cardiovascular events. We excluded studies whose reported harms were limited to minor adverse events that did not necessarily result in medical attention (e.g., patient dissatisfaction, worry, minor gastrointestinal complaints), physiologic outcomes only (e.g., hypoxia, renal or electrolyte disturbances), or harms of health certificate effect (i.e., persons with negative screening results engaging in risky health behaviors or not pursuing future screening). Studies of harms did not have to include a comparator (i.e., persons who did not receive any screening test). We also included studies designed to assess for extracolonic findings (incidental findings on CTC) and resultant diagnostic workup and harms of workup. We extracted extracolonic findings and radiation exposure per CTC examination from relevant diagnostic accuracy (Key Question 2) studies, when reported.

## Quality Assessment and Data Abstraction

At least two reviewers critically appraised all articles that met inclusion criteria using the USPSTF’s design-specific quality criteria (Appendix B Table 2).97 We supplemented this criteria with the National Institute for Health and Care Excellence methodology checklists,98 AMSTAR for systematic reviews,99 Newcastle Ottawa Scales for cohort and case-control studies,100 and QUADAS I and II for studies of diagnostic accuracy101,102 (Appendix B Table 2). We rated articles as good, fair, or poor quality. In general, a good-quality study met all criteria. A fair-quality study did not meet, or it was unclear if it met, at least one criterion, but also had no known important limitations that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations. The most common fatal flaw for diagnostic studies included application of the reference standard to only those who screened positive (because when missing data are not random or selective, analysis will generate biased estimates of diagnostic accuracy,92,93,96,103 and verification of only screen-positive patients will generally lead to an overestimation of both sensitivity and specificity). We also excluded diagnostic studies that did not provide a description of followup of screen-negative persons for poor quality because of limitations in reporting. We excluded poor-quality studies from this review. Disagreements about critical appraisal were resolved by consensus and, if needed, consultation with a third independent reviewer.

One reviewer extracted key elements of included studies into standardized evidence tables in Excel or Microsoft Access (FIT diagnostic accuracy studies). A second reviewer checked the data for accuracy. Evidence tables were tailored for each key question and to specific study designs and/or specific screening tests. Tables generally included details on: study design/quality, setting and population (e.g., country, inclusion criteria, age, sex, race/ethnicity, family history), screening test/protocol (e.g., who administered, how it was administered, definition of test positive/diagnostic threshold[s], frequency/interval), reference standard or comparator (if applicable), adherence to testing, length of followup, outcomes (e.g., CRC incidence, mortality, sensitivity/specificity, harms) and outcomes for a priori specified subgroups.

## Data Synthesis and Analysis

We synthesized results by key question and type of screening test, incorporating those studies from our previous review that met our updated inclusion criteria. We used a standardized summary of evidence table to summarize the overall strength of evidence for each key question. This table included: number and design of included studies, summary of results, consistency/precision of results, reporting bias, summary of study quality, limitations of the body of evidence, and applicability of findings.

### Key Question 1

We organized the syntheses primarily by study design and separated them into three main categories: 1) trials designed to test the effectiveness of screening tests (either as a one-time application or in a screening program) compared to no screening on CRC-specific and/or all-cause mortality; 2) well-conducted observational studies designed to test the effectiveness of a one-time application of a screening test or a screening program of screening tests without trial evidence (i.e., colonoscopy) compared to no screening on CRC incidence and mortality; and 3) comparative effectiveness trials of one screening test (e.g., FIT) versus another screening test (e.g., colonoscopy). These latter trials, however, were primarily designed to determine the differential uptake of different tests and/or to determine the comparative yield between different tests (i.e., not powered to detect differences in CRC outcomes or mortality). Primary outcomes of interest were: CRC incidence, CRC mortality, and all-cause mortality, as well as CRC incidence and mortality by location of CRC (distal vs. proximal).

Because of the limited number of studies and/or clinical heterogeneity of studies, we primarily synthesized results qualitatively using summary tables to allow for comparisons across different studies. We did conduct quantitative analyses for four large FS trials for the above stated outcomes. We conducted random-effects meta-analyses using the profile likelihood method to estimate the incidence rate ratio (IRR) (events per person-year) in R version 3.0.2 (The R Project for Statistical Computing; Vienna, Austria).104,105 We assessed the presence and magnitude of statistical heterogeneity among the studies using the I^2^ statistic.

### Key Question 2

This question focused explicitly on the one-time test performance of currently available CRC screening tests. We organized our synthesis by type of screening test (i.e., CTC, high-sensitivity stool-based testing, and mSEPT9). Our analyses primarily focus on per-person test sensitivity to detect adenomas (by size, where reported, of <6, ≥6, or ≥10 mm), advanced adenomas (as defined by the study), CRC, and advanced neoplasia (a composite outcome of advanced adenoma plus CRC). In one instance, the per-person sensitivity was not reported and could not be calculated, so we substituted per-lesion test performance. If per-person test accuracy was not reported for adenomas by size, we allowed for any lesion (i.e., polyp) regardless of histology. We calculated sensitivity and specificity for adenomas by size and advanced adenomas excluding CRC lesions (persons who had CRC were removed from the 2×2 table). We calculated sensitivity and specificity in Stata using Jeffrey’s CIs. We used 2×2 tables constructed from data reported in the primary studies. If the observed sensitivity or specificity was 100%, only the lower 95% CI was calculated. In many cases the data presented in our report differ slightly from the published paper because of these calculations.

For test performance of CTC, we synthesized results for examinations with bowel preparation separately from those without bowel preparation. For each study that reported both sensitivity and specificity, we plotted results in receiver operating characteristic (ROC) space (sensitivity vs. 1-specificity) to determine whether summary ROC curve analysis was necessary. Summary ROC curves are used when sensitivity and specificity are related through the test positivity threshold.106 We observed relatively constant specificity with variability in sensitivity across studies, however, and therefore these joint modeling approaches were not needed. We conducted random-effects meta-analyses using the empirical Bayes method to (separately) estimate sensitivity and specificity in R.107 We assessed the presence and magnitude of statistical heterogeneity among the studies using the I^2^ statistic. We did not quantitatively pool results if data were limited to three or fewer studies.

For studies of FITs, we focused on study designs in which all patients received colonoscopy (the reference standard) regardless of the screening FIT result. In this way we avoided potential test referral bias, which increases apparent test sensitivity and decreases apparent test specificity in the study population. We separately evaluated studies that employed differential followup. Studies in our evidence base utilized several different FITs, which we grouped into qualitative and quantitative tests; similarities and differences are shown in Table 3. We further characterized FITs by name and alias if applicable (with name variations resulting from changes in company ownership, distribution in different countries, or other reasons). We grouped similar FITs into “families” for results display and discussion. For example, tests produced by the same manufacturer, utilizing the same components and method, and compatible with different automated analyzers (and often reported by analyzer name) were placed in the same FIT family.

Table 3 FIT Characteristics, Including Those Unique to Qualitative and Quantitative Assays

FIT Characteristic | Qualitative FIT | Quantitative FIT
Cutoff value reported in ng Hb/mL buffer | Not comparable across studies/tests | Not comparable across studies/tests
Cutoff value reported in μg hemoglobin/g feces | Comparable across studies/tests | Comparable across studies/tests
Best interval for screening | Unknown | Unknown
Hb calibrator | May not be traceable to international reference preparation | May not be traceable to international reference preparation
Method | Immuno-chromatographic | Various; e.g. immuno-turbidometric
Cutoff value | Fixed | Adjustable by user
Results determination | Subjective | Objective; may be automated; results may be qualitatively reported^*^
Sample stabilization and transport | N/A | Various approaches to control sample size and stability
Suitable for large screening programs | No | Yes
Suitable for point of care testing | Yes | Dependent on volume

* Quantitative results may be transformed into qualitative results using the manufacturer’s or a user-defined cutoff value. Performance characteristics of a quantitative assay used qualitatively may be adjusted by varying the cutoff value. In the US, the FDA has approved quantitative FITs only for dichotomous use.

FIT sensitivity is likely to depend on the chosen cutoff value (i.e., the value that is used to determine a positive or negative result), which in turn depends on the detection limit of the test. Many manufacturers express the test cutoff value in ng hemoglobin (Hb)/mL buffer, units that are unique to the device or test system and cannot be compared across different tests.108 Cutoff values expressed in μg Hb/g feces are more comparable across tests, although there is variability due to differences in sampling probes and stool mass. In lieu of a better method, however, we attempted to compare tests according to cutoff values expressed in μg Hb/g feces. In some cases there was insufficient information to convert values expressed in ng Hb/mL to μg Hb/g feces.

Despite efforts to consolidate study information, the heterogeneity of tests, test cutoffs, and study design remained high and we did not quantitatively pool sensitivity and specificity for FITs. In these instances, we used summary tables and forest plots, prepared using Stata, to provide a graphical summary of results.

### Key Question 3

We organized our synthesis by type of screening test, study design, and type of harm. Our synthesis is organized into three main categories: 1) harms of programs of screening, which include downstream harms of subsequent diagnostic/therapeutic endoscopy; 2) harms of individual screening tests focusing on CTC and endoscopy, as we did not hypothesize any serious harms for stool- or blood/serum-based screening tests; and 3) extracolonic findings on CTC. Although we included our discussion of results for extracolonic findings with harms, we recognize that detection of extracolonic findings can represent either a benefit or harm.

For harms of programs of screening as well as radiation exposure from and extracolonic findings on CTC, we primarily synthesized results qualitatively using summary tables to allow for comparisons across different studies. When possible, we conducted quantitative analyses for serious harms, including perforation and major bleeding, for colonoscopy or FS. We defined major bleeding as any bleeding that required medical attention or intervention (e.g., emergency visit, hospitalization, transfusion, endoscopic management, surgery), or defined/reported as “major” or “serious” by the individual study author. Quantitative analyses were not performed for other serious adverse events, as they were not routinely or consistently reported or defined. We used random-effects models to estimate rates of serious adverse events for colonoscopy and FS separately. We applied the restricted maximum likelihood estimation method when the number of studies to be synthesized was 10 or greater and the profile likelihood estimation method otherwise. Exploratory meta-regression analysis was conducted by fitting random-effects logistic models to examine the association of the risk of serious adverse events with the following study-level characteristics: study design, year of study, sample size, study setting by country, and indication for endoscopy. The analyses were performed using R version 3.0.2.

## Expert Review and Public Comment

A draft research plan that included the analytic framework, key questions, and inclusion criteria was available for public comment in January 2014. We made no substantive changes to our review methods based on comments received. A draft version of this report was reviewed by seven invited content experts as well as federal partners from the Centers for Disease Control and Prevention, National Institutes of Health, Department of Veterans Affairs (VA), and Indian Health Service. Comments received during this process were presented to the USPSTF during its deliberation of the evidence and subsequently addressed, as appropriate, in the final version of the report. Additionally, a draft of the full report was posted on the USPSTF Web site from October 6 through November 2, 2015. Comments from 21 individuals were received during this public comment period; there were no changes made to the report based on these comments.

## USPSTF Involvement

The authors worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis.

This research was funded by the Agency for Healthcare Research and Quality (AHRQ) under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project, coordinated systematic review work with decision models, reviewed the draft report, and assisted in external review of the draft evidence synthesis.