# Ongoing Studies

Appendix F Table 1 Ongoing Studies

Study Reference Trial Identifier | Study Name | Location | Estimated N | Description | Relevant Outcomes | 2015 Status
Regge D, Iussich G, Senore C, et al. Population screening for colorectal cancer by flexible sigmoidoscopy or CT colonography: study protocol for a multicenter randomized trial. Trials 2014;15:97. PMID: 24678896 NCT01739608 | NR | Italy | 20,000 | Randomized trial comparing CTC with FS | Advanced neoplasia incidence; adverse events | Recruiting
Pilot study of a national screening programme for bowel cancer in Norway. https://clinicaltrials.gov/ct2/show/NCT01538550. Accessed February 9, 2015. NCT01538550 | NR | Norway | 140,000 | Randomized trial comparing FOBT and FS | CRC mortality and incidence; adverse events | Recruiting
Colonoscopy and FIT as colorectal cancer screening test in the average risk population. https://clinicaltrials.gov/ct2/show/NCT02078804. Accessed February 9, 2015. NCT02078804 | SCREESCO | Sweden | 200,000 | Randomized trial comparing FIT and colonoscopy | CRC mortality and incidence | Recruiting
Maximizing yield of the fecal immunochemical test for colorectal cancer screening (MY-FIT). https://clinicaltrials.gov/ct2/show/NCT01634126. Accessed February 9, 2015. NCT01634126 | NR | US | 3000 | Single-sample versus two-sample FIT, using various cut-points | Sensitivity and specificity for CRC and AA | Ongoing
Colonoscopy or fecal occult blood test in screening healthy participants for colorectal cancer. https://clinicaltrials.gov/ct2/show/NCT00102011. Accessed February 9, 2015. NCT00102011 | NR | US | 4952^*^ | Randomized trial comparing colonoscopy to FOBT | CRC incidence; adverse events | Final data collection completed
Kaminski MF, Bretthauer M, Zauber AG, et al. The NordICC Study: rationale and design of a randomized trial on colonoscopy screening for colorectal cancer. Eur J Radiol 2012 Jul;44(7):695–702. NCT00883792 | NordICC | Nordic countries; The Netherlands; Poland | 66,000 | Randomized trial comparing colonoscopy to usual care | CRC mortality and incidence; all-cause mortality | Recruiting
Comparative effectiveness of FIT, colonoscopy, and usual care screening strategies. https://clinicaltrials.gov/ct2/show/NCT01710215. Accessed February 9, 2015. NCT01710215 | NR | US | 6000 | Randomized trial comparing FIT, colonoscopy, and usual care | CRC and AA incidence | Recruiting
Sali L, Grazzini G, Carozzi F, et al. Screening for colorectal cancer with FOBT, virtual colonoscopy and optical colonoscopy: study protocol for a randomized controlled trial in the Florence district (SAVE study). Trials [Electronic Resource] 2013;14:74. NCT01651624 | SAVE | Italy | 14,000 | Randomized trial comparing CTC, FOBT, and colonoscopy | CRC and AA incidence; adverse events | Recruiting
Study of in-home tests for colorectal cancer (SIT). https://clinicaltrials.gov/ct2/show/NCT01998009. Accessed February 9, 2015. NCT01998009 | SIT | US | 2000 | Two FIT and one gFOBT screening with a colonoscopy reference standard | Sensitivity and specificity for advanced neoplasia | Recruiting
Colonoscopy versus fecal immunochemical test in reducing mortality from colorectal cancer (CONFIRM). https://clinicaltrials.gov/ct2/show/NCT01239082. Accessed December 15, 2014. NCT01239082 | CONFIRM | US | 50,000 | Randomized trial comparing FIT with colonoscopy | CRC mortality | Recruiting
Implementation of colorectal cancer screening with FOBT in the Netherlands. http://www.trialregister.nl/trialreg/admin/rctview.asp?TC=1006. Accessed February 9, 2015. NTR1006 | FOCUS | The Netherlands | 20,000 | Randomized trial comparing gFOBT with FIT | CRC incidence | Recruiting
Screening for colorectal cancer in the Netherlands: A study comparing attendance and feasibility of two different forms of faecal occult blood testing and sigmoidoscopy. http://www.trialregister.nl/trialreg/admin/rctview.asp?TC=1096. Accessed February 9, 2015. NTR1096 | CORERO | The Netherlands | 15,000 | Randomized trial comparing gFOBT, FIT, and FS | CRC incidence | Recruiting
Randomized Controlled trial to evaluate the effectiveness of total colonoscopy in colorectal cancer screening. http://apps.who.int/trialsearch/Trial2.aspx?TrialID=JPRN-UMIN000001980. Accessed February 9, 2015. | NR | Japan | 10,000 | Randomized trial comparing FOBT with FOBT and colonoscopy | CRC incidence | Recruiting
Implementation of population screening for colorectal cancer by repeated Fecal Immunochemical Test (FIT): 3 round. http://www.trialregister.nl/trialreg/admin/rctview.asp?TC=2755. Accessed February 9, 2015. NTR2755 | FITTeR | The Netherlands | 10,000 | FIT screening | Sensitivity and specificity for CRC

* Actual enrollment

Abbreviations: AA = advanced adenoma; CONFIRM = Colonoscopy versus Fecal Immunochemical Test in Reducing Mortality from Colorectal Cancer; CRC = colorectal cancer; CTC = computed tomographic colonography; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; FOBT = fecal occult blood test; n = number; NordICC = The Northern European Initiative on Colorectal Cancer; SCREESCO = Screening of Swedish Colons; SIT = Study of In-home Tests for Colorectal Cancer; US = United States.