# Colonoscopy Harms by Age

Appendix E Table 1 Colonoscopy Harms by Age

Author, Year Quality | n | Recruited Population | Type of Outcome | Effect size difference by age
Adeyemo, 2014^209^ Fair | 118,004 | Mixed (including symptomatic) | Perforation | OR per decade (95% CI), unadjusted^*^ Propofol sedation: 1.41 (1.05, 1.89) p=0.02 No propofol: 1.30 (0.93, 1.81) p=0.12 Diagnostic colonoscopy: 1.46 (1.01, 2.13) p=0.04 Therapeutic colonoscopy: 1.32 (1.01, 1.74) p=0.04
Bielawska, 2014^215^ Fair | 1,144,900 | Mixed (including symptomatic) | Perforation | OR (95% CI), unadjusted Age <60: 1.0 60–74: 2.83 (1.94, 4.14) p<0.0001 ≥75: 6.73 (4.55, 9.96) p<0.0001
Blotiere, 2014^216^ Fair | 947,061 | Mixed (including symptomatic) | Perforation | OR (95% CI), unadjusted^*^ Age 0–39: 1.0 (reference) 40–49: 0.78 (0.38, 1.58) 50–59: 1.56 (0.87, 2.79) 60–69: 2.89 (1.66, 5.05) 70–79: 5.75 (3.32, 9.97) ≥80: 10.83 (6.16, 19.05)
Blotiere, 2014^216^ Fair | 947,061 | Mixed (including symptomatic) | Hemorrhage | OR (95% CI), unadjusted^*^ Age 0–39: 1.0 (reference) 40–49: 1.06 (0.70, 1.62) 50–59: 1.75 (1.22, 2.52) 60–69: 2.51 (1.76, 3.58) 70–79: 4.54 (3.19, 6.45) ≥80: 8.23 (5.71, 11.85)
Zafar, 2014 Fair | 54,039 (1384 CTC) | Screening | Serious bleeding | OR (95% CI), adjustedα Age 66–74: 1.0 (reference) 75–84: 1.14 (0.87, 1.48) ≥85: 1.49 (0.81, 2.75)
Zafar, 2014 Fair | 54,039 (1384 CTC) | Screening | Perforation | OR (95% CI), adjustedα Age 66–74: 1.0 (reference) 75–84: 1.02 (0.49, 2.14) ≥85: 1.99 (0.45, 8.69)
Zafar, 2014 Fair | 54,039 (1384 CTC) | Screening | Other GI events | OR (95% CI), adjustedα Age 66–74: 1.0 (reference) 75–84: 0.92 (0.70, 1.22) ≥85: 1.22 (0.68, 2.20)
Zafar, 2014 Fair | 54,039 (1384 CTC) | Screening | Cardiovascular events | OR (95% CI), adjustedα Age 66–74: 1.0 (reference) 75–84: 1.35 (1.10, 1.64) ≥85: 1.56 (1.05, 2.32)
Chukmaitov, 2013^221^ Fair | 2,315,126 | Mixed (including symptomatic) | Serious bleeding | OR (95% CI), multivariate Age 50–65: 1.08 (0.94, 1.25) 65–74: 1.22 (1.03, 1.45) 75–84: 1.71 (1.43, 2.05) ≥85: 2.34 (1.90, 2.88)
Chukmaitov, 2013^221^ Fair | 2,315,126 | Mixed (including symptomatic) | Perforation | OR (95% CI), multivariate Age 50–65: 1.38 (1.01, 1.87) 65–74: 1.80 (1.24, 2.62) 75–84: 2.36 (1.61, 3.48) ≥85: 2.88 (1.75, 4.72)
Cooper, 2013^222^ Fair | 100,359 | Mixed (including symptomatic) | Perforation, splenic injury/rupture, or aspiration pneumonia | OR (95% CI), multivariate Age 66–69: 1 (reference) 70–74: 3.36 (2.03, 5.56) 75–79: 3.63 (2.18, 6.05) 80–84: 5.97 (3.58, 9.97) ≥85: 10.41 (6.18, 17.54) p<0.001
Hamdani, 2013^232^ Fair | 80,118 | Mixed (including symptomatic) | Perforation | For every year increase in age, the risk of a perforation increased by 7% (95% CI, 5 to 9%) Incidence per 10,000: Age 18–49: 3.6^†^ 50–64: 2.6^†^ 65–79: 8.7^†^ ≥80: 31.7 p<0.0001
Pox, 2012^263^ Fair | 2,821,392 | Screening | Major and minor complications | OR (95% CI) Males 55–59: 1.0 (reference) 60–64: 1.2 (1.0, 1.3) 65–69: 1.3 (1.2, 1.5) 70–74: 1.5 (1.3, 1.7) 75–79: 1.7 (1.5, 2.0) 79+: 1.6 (1.3, 2.0) Females 55–59: 1.0 (reference) 60–64: 1.5 (1.3, 1.7) 65–69: 1.8 (1.6, 2.0) 70–74: 2.1 (1.8, 2.4) 75–79: 2.8 (2.4, 3.2) 79+: 3.4 (2.8, 4.1)
Rutter, 2012^‡,267^ Fair | 43,456 | Mixed (excluding symptomatic) | Perforation | Age 40–49: 0.00% 50–64: 0.03 65–74: 0.10 75–85: 0.17
Rutter, 2012^‡,267^ Fair | 43,456 | Mixed (excluding symptomatic) | Hemorrhage | Age 40–49: 0.23% 50–64: 0.21 65–74: 0.43 75–85: 0.81
Rutter, 2012^‡,267^ Fair | 43,456 | Mixed (excluding symptomatic) | Hospitalization | Age 40–49: 1.1% 50–64: 0.89 65–74: 2.0 75–85: 2.7
Rutter, 2012^‡,267^ Fair | 43,456 | Mixed (excluding symptomatic) | ED/urgent care visit | Age 40–49: 2.9% 50–64: 2.2 65–74: 2.5 75–85: 3.5
Ferlitsch, 2011^48^ Fair | 44,350 | Screening | Cardiopulmonary adverse events | Cardiopulmonary adverse events increased with age- from 0.05% in 50- to 60-year-old patients to 0.25% in 70- to 80-year-old patients (p<0.001)
Ferlitsch, 2011^48^ Fair | 44,350 | Screening | Bleeding | Bleeding events were unchanged by age (p=0.23)
Ko, 2010^245^ Fair | 21,375 | Mixed (excluding symptomatic) | Serious bleeding, diverticulitis, perforation, post-polypectomy syndrome | Incidence per 1000 exams (95% CI): Age 40–59: 1.19 (0.59, 2.13) 60–69: 1.80 (0.93, 3.14) 70–79: 3.48 (1.94, 5.72) ≥80: 4.36 (1.41, 10.14)
Ko, 2010^245^ Fair | 21,375 | Mixed (excluding symptomatic) | Serious bleeding, diverticulitis, perforation, post-polypectomy syndrome, cardiovascular events, neurologic events, abdominal pain, biliary colic, perirectal abscess, pneumonia, splenic hematoma, prolonged recovery from sedation, nausea and vomiting from bowel prep, and ileus | Incidence per 1000 exams: Age 40–59: 1.95 (1.16, 3.08) 60–69: 3.14 (1.95, 4.80) 70–79: 5.32 (3.38, 7.98) ≥80: 5.23 (1.92, 11.35)
Lorenzo-Zuniga, 2010^252^ Fair | 25,214 | Mixed (including symptomatic) | Perforation | Mean age of patients with perforation: 71.15 (range 36–89) Mean age of patients without perforation: 57.42 (range 5–97) p<0.001
Arora, 2009^212^ Fair | 277,434 | Mixed (including symptomatic) | Perforation | Incidence per 100,000 Age 18–50: 66 50–65: 71 65–80: 85 ≥80: 119
Crispin, 2009^224^ Fair | 236,087 | Mixed (including symptomatic) | Bleeding | OR (95% CI) for age squared, per year: 1.0001 (1.0001, 1.0002) p<0.0001
Crispin, 2009^224^ Fair | 236,087 | Mixed (including symptomatic) | Perforation | OR (95% CI) for age squared, per year: 1.0003 (1.0002, 1.0005) p<0.0001
Crispin, 2009^224^ Fair | 236,087 | Mixed (including symptomatic) | Cardiorespiratory complication | OR (95% CI) for age squared, per year: 1.0003 (1.0002, 1.0004) p<0.0001
Warren, 2009^**,280^ Good | 53,220 | Mixed (including symptomatic) | Serious GI events (perforation, GI bleeding, transfusion) | Adjusted risk per 1000 (95% CI) Age 66–69: 5.0 (3.8, 6.2) 70–74: 5.8 (4.6, 6.9) 75–79: 7.2 (5.9, 8.6) 80–84: 8.8 (6.9, 10.7) ≥85:12.1 (8.7, 15.5)
Warren, 2009^**,280^ Good | 53,220 | Mixed (including symptomatic) | Cardiovascular events | Adjusted risk per 1000 (95% CI) Age 66–69: 12.6 (11.0, 14.3) 70–74: 16.0 (14.4, 17.6) 75–79: 20.6 (18.6, 22.5) 80–84: 25.7 (23.0, 28.4) ≥85: 31.8 (27.4, 36.1)
Mansmann, 2008^254^ Fair | 236,087 | Mixed (including symptomatic) | Serious adverse events (including bleeding, perforation, and cardiorespiratory events) | All serious adverse events were more frequent in older age groups
Rabeneck, 2008^265^ Fair | 97,091 | Mixed (including symptomatic) | Bleeding | OR (95% CI), multivariate Age 50–59: 1.00 60–75: 1.61 (1.20, 2.16) p= 0.001
Rabeneck, 2008^265^ Fair | 97,091 | Mixed (including symptomatic) | Perforation | Age 50–59: 1.00 60–75: 2.06 (1.79, 2.37) p<0.0001
Levin, 2006^249^ Fair | 16,318 | Mixed (excluding symptomatic) | Perforation | RR (95% CI) Age 40–59: 1.0 60+: 5.2 (1.4, 19.2)
Levin, 2006^249^ Fair | 16,318 | Mixed (excluding symptomatic) | Serious bleeding or diverticulitis requiring surgery | RR (95% CI) Age 40–59: 1.0 60+: 1.8 (0.81, 3.9)
Levin, 2006^249^ Fair | 16,318 | Mixed (excluding symptomatic) | Any serious complication | RR (95% CI) Age 40–59: 1.0 60+: 1.2 (0.9, 1.7)
Korman, 2003^247^ Fair | 116,000 | Mixed (including symptomatic) | Perforation | Most perforations occurred in patients over 60 years of age.

* Similar findings for adjusted odds ratios

† Calculated

‡ Also reports deaths, diverticulitis, abdominal pain, and any serious adverse event

** Also reports paralytic ileus, nausea, vomiting and dehydration, abdominal pain

α Adjusted for sex, age, race, comorbidities associated with adverse events, and adverse events in preceding 90 day

Abbreviations: CI = confidence interval; ED = emergency department; GI = gastrointestinal; n = number; OR = odds ratio; p = p-value; RR = rate ratio.