# Comparative Effectiveness Studies

We found 12 fair-quality trials 110,111,116,120,121,125,126,128–132 in 16 articles110,111,116,120,121,125,126,128–132, 137,138,148,152 examining the comparative effectiveness of different screening tests in average-risk screening populations. We also found three fair-quality large prospective cohort studies112,114,115 (in six articles112,114,115,139–141) examining the comparative effectiveness of gFOBT versus FIT in average risk screening populations (Table 9).

Trials and cohort studies included asymptomatic adults between ages 50–74 years. Mean age, when reported, was approximately 59 to 62 years, with approximately equal numbers of men and women (when reported). Studies generally excluded persons at high risk for CRC due to symptoms, personal history of CRC, and/or strong family history. All studies were conducted in Western European countries.

Trials were primarily designed to assess the differential uptake (adherence) of testing and relative detection of colorectal lesions and were limited to a single round of screening. Although these trials did include CRC outcomes, the trials were not powered to detect differences in yield of CRC. For example, approximately 6000 participants per arm would be needed to detect a 0.3% difference in CRC incidence with 80% power, assuming 100% adherence. The trials that have been conducted generally had less than 6000 participants per arm with less than 60% adherence to testing.

## Comparative uptake and cancer yield of stool tests (versus stool tests)

[underlined: gFOBT versus FIT]. Two trials included the comparative uptake and detection of CRC of Hemoccult II versus FIT (OC-Sensor);116,130 in addition, three cohort studies112,114,115 included the comparative detection of CRC as part national screening programs of Hemoccult II versus FITs (Immudia (discontinued), FOB Gold, Magstream, OC-Sensor) (Appendix D Table 1). From the two trials reporting comparative uptake, it appears that there was greater adherence to OC-Sensor (~59%) than to Hemoccult II (~47%). Across all the studies reporting test positivity, it appears that there was a greater proportion of FIT test positive as compared to Hemoccult II. Although the test positivity was higher for OC-Sensor, and a greater number of cancers was detected in the FIT versus gFOBT arm, the difference in number of cancers detected in the two comparative trials after one round of testing was not statistically significant.116,130 The national screening program cohort studies had much larger numbers of cancers being detected. Again, all of these cohort studies showed a higher test positivity for FIT than Hemoccult II and two showed statistically significant higher detection of CRC for FIT (FOB Gold, Magstream, OC-Sensor) than Hemoccult II.112,115 One cohort study did not show statistically significant difference in cancer detection between Immudia and Hemoccult II despite the higher test positivity of Immudia.114 None of these studies, however, have reported number of interval cancers or mortality outcomes.

Appendix D Table 1 Key Question 1: gFOBT vs. FIT or FIT vs. FIT Comparative Effectiveness Studies

Design | Author, Year | Round | Test | Adherence, % | Test Positivity | n CRC/n Analyzed | (%) | Interval CRC | (%)
Trials | Zubero, 2014^132^ | 1 | FIT (OC-Sensor) | 61.8 | 6.6 | 35/11,153 | (0.3) | NR
Trials | Zubero, 2014^132^ | 1 | FIT (FOB Gold) | 59.1 | 8.5 | 44/11,725 | (0.4) | NR
Trials | van Roon, 2013^*,129^ (intervals) | 1 | FIT (OC-Sensor Micro), 1 year interval | 64.7 | 8.4 | 4/1541 | (0.3) | NR
Trials | van Roon, 2013^*,129^ (intervals) | 1 | FIT (OC-Sensor Micro), 2 year interval | 61.0 | 8.4 | 10/1474 | (0.7) | NR
Trials | van Roon, 2013^*,129^ (intervals) | 1 | FIT (OC-Sensor Micro), 3 year interval | 62.0 | 8.4 | 8/1492 | (0.5) | NR
Trials | van Roon, 2013^*,129^ (intervals) | 2 | FIT (OC-Sensor Micro), 1 year interval | 63.2 | 6.0 | 1/1286 | (0.08) | 0/1285^†^ | (0)
Trials | van Roon, 2013^*,129^ (intervals) | 2 | FIT (OC-Sensor Micro), 2 year interval | 62.5 | 6.0 | 4/1280 | (0.3) | 1/1276^††^ | (0.08)
Trials | van Roon, 2013^*,129^ (intervals) | 2 | FIT (OC-Sensor Micro), 3 year interval | 64.0 | 6.0 | 2/1298 | (0.2) | 2/1296^**^ | (0.2)
Trials | van Roon, 2011^*,152^ (1, 2 sample FIT) | 1 | FIT (OC-Sensor Micro), 1 sample | 61.5 | 8.1 | 16/2975 | (0.5) | NR
Trials | van Roon, 2011^*,152^ (1, 2 sample FIT) | 1 | FIT (OC-Sensor Micro), 2 samples | 61.3 | 12.8 | 12/1874 | (0.6) | NR
Trials | Hol, 2010^*,116^ | 1 | gFOBT (Hemoccult II) | 47.0 | 2.8 | 6/2351 | (0.3) | NR
Trials | Hol, 2010^*,116^ | 1 | FIT (OC-Sensor Micro) | 59.4 | 4.8 | 14/2975 | (0.5) | NR
Trials | van Rossum, 2008^**,116,137,138^ | 1 | gFOBT (Hemoccult II) | 46.9 | 2.4 | 11/4836 | (0.2) | NR
Trials | van Rossum, 2008^**,116,137,138^ | 1 | FIT (OC-Sensor) | 59.6 | 5.5 | 24/6157 | (0.4) | NR
Cohort studies | Hamza, 2013^115^ | 2–4 | gFOBT (Hemoccult II) | NR | 2.1 | 29/23,231 | (0.1) | NR
Cohort studies | Hamza, 2013^115^ | 2–4 | FIT (FOB Gold) | NR | 4.6 | 63/23,231 | (0.3)^‡^ | NR
Cohort studies | Faivre, 2012^112,139^ | 1 | gFOBT (Hemoccult II) | NR | 2.0 | 117/85,026 | (0.1) | NR
Cohort studies | Faivre, 2012^112,139^ | 1 | FIT (FOB Gold), 1 sample | NR | 3.3 | 74/32,077 | (0.2)^‡^ | NR
Cohort studies | Faivre, 2012^112,139^ | 1 | FIT (FOB Gold), 2 samples | NR | 5.2 | 91/32,077 | (0.3)^‡^ | NR
Cohort studies | Faivre, 2012^112,139^ | 1 | FIT (Magstream) | NR | 4.6 | 65/19,180 | (0.3)^‡^ | NR
Cohort studies | Faivre, 2012^112,139^ | 1 | FIT (OC-Sensor), 1 sample | NR | 2.5 | 76/33,611 | (0.2)^‡^ | NR
Cohort studies | Faivre, 2012^112,139^ | 1 | FIT (OC-Sensor), 2 samples | NR | 3.7 | 92/33,611 | (0.3)^‡^ | NR
Cohort studies | Guittet, 2012^140^ | 1 | gFOBT (Hemoccult II) | NR | 2.5 | 46/32225 | (0.1) | NR
Cohort studies | Guittet, 2012^140^ | 1 | FIT (Immudia) | NR | 6.4 | 60/32225 | (0.2) | NR

* Overlapping study populations

† Followup 1 year

†† Followup 2 years

** Followup 3 years

‡ p<0.01 versus gFOBT

Abbreviations: CRC = colorectal cancer; FIT = fecal immunochemical test; gFOBT = guaiac fecal occult blood test; n = number; NR = not reported.

[underlined: FIT versus FIT]. Two trials included the comparative uptake and yield of detection of CRC of different FIT tests or test intervals (Appendix D Table 1).129,132 The first trial was conducted by van Roon and colleagues in the Netherlands and it evaluated comparative uptake and yield of OC-Sensor at 1-year (n=1541 analyzed per arm), 2-year (n=1474 analyzed per arm), and 3-year (n=1492 analyzed per arm) intervals of testing over two rounds.129 The adherence to testing was similar (61–65%) over rounds one and two regardless of interval length. The test positivity was expectedly slightly lower the second round of testing, 6.0% compared with 8.4% in the first round. Overall, the number of cancers detected was low and there were no statistically significant differences in the number of cancers or interval cancers between the different intervals of testing. The second trial, conducted by Zubero and colleagues in Spain, evaluated the comparative uptake and yield of OC-Sensor (n=11,153 analyzed per arm) versus FOB Gold (n=11,725 analyzed per arm) over one round.132 The adherence to testing was similar between the two FITs. FOB-Gold had a higher test positivity rated (8.5%) compared to OC-Sensor (6.6%), both of which used similar cut-off values. Although test positivity and the number of cancers detected were higher in the FOB Gold arm compared to the OC-Sensor arm, the difference in cancers was not statistically significant. This trial has not yet reported on interval cancers or mortality.

## Comparative uptake and cancer yield stool tests versus direct visualization

[underlined: gFOBT versus FS]. Five comparative trials110,111,116,121,131 published from 1997 to 2010 included the comparative uptake and yield of CRC cases detected after one round of Hemoccult II versus FS with (three trials110,121,131) or without Hemoccult II (Appendix D Table 2). These trials were relatively small, again with very low number of cancers in each trial, such that differences in cancer detection were not statistically significant except for in one trial by Rasmussen and colleagues.121 In this trial (n=3055 analyzed per gFOBT arm, n=2222 analyzed per FS plus gFOBT arm), although the adherence was lower in the FS plus Hemoccult II arm compared to the Hemoccult II only arm, the test positivity and CRC yield was statistically significantly higher in the combined arm. In addition, the interval number of cancers (up to about 5 years of followup) amongst the screen negative persons was 8/3051 in the combined arm versus 18/2210 in the Hemoccult II only arm. The CRC mortality, however, was not statistically significantly different, 2.00/1000 persons in the combined arm versus 2.55/1000 persons in the Hemoccult II only arm.

Appendix D Table 2 Key Question 1: Stool Test vs. FS (With or Without Stool Test) Comparative Effectiveness Studies

Design | Author, Year | Round | Test | Adherence, % | Test Positivity | n CRC/n Analyzed | (%) | Interval CRC | (%)
Trials | Hol, 2010^*,116^ | 1 | gFOBT (Hemoccult II) | 47.0 | 2.8 | 6/2351 | (0.3) | NR
Trials | Hol, 2010^*,116^ | 1 | FIT (OC-Sensor Micro) | 59.4 | 4.8 | 14/2975 | (0.5) | NR
Trials | Hol, 2010^*,116^ | 1 | FS | 27.7 | 10.2 | 8/1386 | (0.6) | NR
Trials | Segnan, 2007^125^ SCORE III | 1 | FIT (Immudia-HemSp) | 32.3 | 4.7 | 2/1965 | (0.1) | NR
Trials | Segnan, 2007^125^ SCORE III | 1 | FS | 32.3 | 7.2 | 12/1922 | (0.6)^‡^ | NR
Trials | Segnan, 2005^126^ SCORE II | 1 | FIT (Immudia-HemSp) | 28.1 | 4.6 | 8/2336 | (0.3) | NR
Trials | Segnan, 2005^126^ SCORE II | 1 | FS +/− FIT (Immudia-HemSp) | 28.1 | 7.6^*^ | 14/4075 | (0.3) | NR
Trials | Rasmussen, 1999^121^ | 1 | gFOBT (Hemoccult II) | 55.7 | 2.4 | 4/3055 | (0.1) | 18/2210^†^ | (0.8)
Trials | Rasmussen, 1999^121^ | 1 | gFOBT (Hemoccult II) + FS | 38.9 | 19.4 | 12/2222 | (0.5)^‡^ | 8/3051^†,‡^ | (0.3)
Trials | Verne, 1998^131^ | 1 | gFOBT (Hemoccult II) | 31.6 | 8.2 | 1/854 | (0.1) | NR
Trials | Verne, 1998^131^ | 1 | FS | 46.6 | 9.9 | 4/1116 | (0.4) | NR
Trials | Verne, 1998^131^ | 1 | gFOBT (Hemoccult II) + FS | 30.1 | NR | 1/401 | (0.2) | NR
Trials | Berry, 1997^110^ | 1 | gFOBT (Hemoccult II) | 50 | NR | 2/1564 | (0.1) | NR
Trials | Berry, 1997^110^ | 1 | gFOBT (Hemoccult II) + FS | 20.2 | NR | 3/656 | (0.5) | NR
Trials | Brevinge, 1997^111^ | 1 | gFOBT (Hemoccult II) | 59 | 4.4 | 2/1893 | (0.1) | NR
Trials | Brevinge, 1997^111^ | 1 | FS | 42.5 | NR | 5/1371 | (0.4) | NR

* Test positivity includes flexible sigmoidoscopy by patient choice.

† Followup for 24–62 months

‡ p<0.01

Abbreviations: CRC = colorectal cancer; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; n = number; NR = not reported; SCORE = Screening for COlon Rectum.

[underlined: FIT versus FS]. Three trials116,125,126 included comparative uptake and yield of detection of CRC with one round of FIT (Immudia, OC-Sensor) versus FS (Appendix D Table 2). In these trials, both conducted by Segnan and colleagues in Italy, the adherence to both FIT and FS was similarly low, around 30%;125 as compared to the other trial by Hol and colleagues in the Netherlands, the adherence to FIT (59%) was higher than to FS (28%).116 In all three trials the test positivity was higher for FS (with or without FIT) than FIT alone. Only one trial, conducted by Segnan and colleagues, found a statistically significant higher yield of CRC in the FS screened group versus Immudia alone screened group.125 These trials, however, were not necessarily powered to detect a difference in CRC detection. Interval cancers and mortality was not reported in either trial.

[underlined: FIT versus colonoscopy or CTC]. Two trials120,125 included the comparative uptake and yield of detection of CRC with one round of FIT (Immudia, OC-Sensor) and colonoscopy (Appendix D Table 3). No trials compared FIT to CTC. In both these two trials, the adherence to FIT was higher than to colonoscopy. One trial by Segnan and colleagues (n=1596 analyzed per colonoscopy arm, n=1965 analyzed per FIT arm) conducted in Italy found statistically significant higher number of cancers in the colonoscopy screened group compared to the Immudia screened group. In the other trial by Quintero and colleagues, powered to detect a difference in cancers (n=5059 analyzed per colonscopy arm, n=10,507 analyzed per FIT arm) conducted in Spain found statistically significantly more cancers in the colonoscopy arm versus the FIT arm. Neither of these trials reported interval cancers or mortality.

Appendix D Table 3 Key Question 1: FIT vs. CTC or Colonoscopy Comparative Effectiveness Studies

Design | Author, Year | Round | Test | Adherence, % | Test Positivity | n CRC/n Analyzed | (%) | Interval CRC | (%)
Trials | Quintero, 2012^120,148^ COLONPREV | 1 | Colonoscopy | 17.3 | 10.3 | 30/5059 | (0.6)^*^ | NR
Trials | Quintero, 2012^120,148^ COLONPREV | 1 | FIT (OC-Sensor) | 31.3 | 7.2 | 33/10507 | (0.3) | NR
Trials | Segnan, 2007^125^ SCORE III | 1 | Colonoscopy | 26.5 | 5.1 | 13/1596 | (0.8)^‡^ | NR
Trials | Segnan, 2007^125^ SCORE III | 1 | FIT (Immudia-HemSp) | 32.3 | 4.7 | 2/1965 | (0.1) | NR

* p<0.05

‡ p<0.01

Abbreviations: CRC = colorectal cancer; FIT = fecal immunochemical test; n = number; NR = not reported; SCORE = Screening for COlon Rectum.

## Comparative uptake and cancer yield of direct visualization tests (endoscopy, CT)

[underlined: FS versus colonoscopy]. Only one trial125 included the comparative uptake and yield of detection of CRC with FS versus colonoscopy (Appendix D Table 4). In this trial, conducted by Segnan and colleagues, (n=1596 per colonoscopy arm, n=1922 per FS arm) in Italy, adherence to FS was higher than to colonoscopy (32.3% versus 26.5% respectively). However, there was no statistically significant difference in the number of cancers detected in each arm. This trial was not powered to detect a difference in CRC yield, furthermore, interval cancers and mortality were not reported.

Appendix D Table 4 Key Question 1: Direct Visualization Comparative Effectiveness Studies

Design | Author, Year | Round | Test | Adherence, % | Test Positivity | n CRC/n Analyzed | (%) | Interval CRC | (%)
Trials | Stoop, 2012^128^ COCOS | 1 | Colonoscopy | 21.5 | 8.7 | 7/5924 | (0.1) | NR
Trials | Stoop, 2012^128^ COCOS | 1 | CTC | 33.6 | 8.6 | 5/2920 | (0.2) | NR
Trials | Segnan, 2007^125^ SCORE III | 1 | Colonoscopy | 26.5 | 5.1 | 13/1596 | (0.8) | NR
Trials | Segnan, 2007^125^ SCORE III | 1 | FS | 32.3 | 7.2 | 12/1922 | (0.6) | NR

Abbreviations: COCOS = COlonoscopy or COlonography for Screening; CRC = colorectal cancer; CTC = computed tomographic colonography; FS = flexible sigmoidoscopy; n = number; NR = not reported; SCORE = Screening for COlon Rectum

[underlined: Colonoscopy versus CTC]. Only one trial128 included the comparative uptake and yield of detection of CRC with colonoscopy versus CTC (Appendix D Table 4). This trial by Stoop and colleagues, (n=5924 per colonoscopy arm, n=2920 per CTC arm) conducted in the Netherlands found adherence to CTC was higher than to colonoscopy (33.6% versus 21.5%, respectively); however there was no statistically significant difference in the number of cancers detected in each arm. This trial was not powered to detect a difference in cancers; furthermore, interval cancers and mortality were not reported.