# Excluded Studies

Reason for Exclusion
E1. | Study relevance
E1a. | Primary aim technology improvements
E2. | Study design
E2a. | Case-control study design
E2b. | No use of reference standard (reference standard not applied to all/subset of screen negative)
E2c. | Case report
E3. | Setting
E3a. | Not a very high Human Development Index country
E4. | Population
E4a. | High-risk or symptomatic
E5. | No relevant outcomes or incomplete outcomes
E5a. | No additional relevant data (primary article included)
E6. | Intervention (including outdated technology)
E7. | Poor Study Quality
E8. | Simulated flexible sigmoidoscopy
E9. | Key existing SER with out of date meta-analysis

1 Senore C, Armaroli P, Silvani M, et al. Comparing different strategies for colorectal cancer screening in Italy: predictors of patients’ participation. Am J Gastroenterol. Jan. 2010;105(1):188-98. KQ1E1. [pmid: 19826409].
2 Stegeman I, de Wijkerslooth TR, Stoop EM, et al. Combining risk factors with faecal immunochemical test outcome for selecting CRC screenees for colonoscopy. Gut. Mar. 2014;63(3):466-71. KQ1E1. [pmid: 23964098].
3 Alford SH, Rattan R, Buekers TE, et al. Protective effect of bisphosphonates on endometrial cancer incidence in data from the Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening trial. Cancer. 2014. Dec. 22. KQ1E1. [pmid: 25533883].
4 Benson M, Lucey M, Pfau P. Caecal intubation rates and colonoscopy competency. Gut. 2014. Apr. 9. KQ1E1. [pmid: 24717933].
5 Jones RM, Mongin SJ, Lazovich D, et al. Validity of four self-reported colorectal cancer screening modalities in a general population: differences over time and by intervention assignment. Cancer Epidemiology, Biomarkers & Prevention. Apr. 2008;17(4):777-84. KQ1E1, KQ2E1, KQ3E1. [pmid: 18381476].
6 Mittal S, Lin YL, Tan A, et al. Limited Life Expectancy Among a Subgroup of Medicare Beneficiaries Receiving Screening Colonoscopies. Clin Gastroenterol Hepatol. 2013. Aug. 22. KQ1E1, KQ2E1, KQ3E1. [pmid: 23973925].
7 John A, Al KS, Dweik N, et al. Emerging role for colorectal cancer screening in Asian countries. Tropical Gastroenterology. Jan. 2014;35(1):21-4. KQ1E1, KQ2E5. [pmid: 25276902].
8 Newcomb PA, Norfleet RG, Storer BE, et al. Screening sigmoidoscopy and colorectal cancer mortality. J Natl Cancer Inst. Oct. 21. 1992;84(20):1572-5. KQ1E2. [pmid: 1404450].
9 Scheitel SM, Ahlquist DA, Wollan PC, et al. Colorectal cancer screening: a community case-control study of proctosigmoidoscopy, barium enema radiography, and fecal occult blood test efficacy. Mayo Clin Proc. Dec. 1999;74(12):1207-13. KQ1E2. [pmid: 10593348].
10 Faivre J, Tazi MA, El MT, et al. Faecal occult blood screening and reduction of colorectal cancer mortality: a case-control study. Br J Cancer. Feb. 1999;79(3–4):680-3. KQ1E2. [pmid: 10027349].
11 Slattery ML, Edwards SL, Ma KN, et al. Colon cancer screening, lifestyle, and risk of colon cancer. Cancer Causes Control. Jul. 2000;11(6):555-63. KQ1E2. [pmid: 10880038].
12 Brenner H, Arndt V, Sturmer T, et al. Long-lasting reduction of risk of colorectal cancer following screening endoscopy. Br J Cancer. Sep. 28. 2001;85(7):972-6. KQ1E2. [pmid: 11592768].
13 Newcomb PA, Storer BE, Morimoto LM, et al. Long-term efficacy of sigmoidoscopy in the reduction of colorectal cancer incidence. J Natl Cancer Inst. Apr. 16. 2003;95(8):622-5. KQ1E2. [pmid: 12697855].
14 Costantini AS, Martini A, Puliti D, et al. Colorectal cancer mortality in two areas of Tuscany with different screening exposures. J Natl Cancer Inst. Dec. 17. 2008;100(24):1818-21. KQ1E2. [pmid: 19066268].
15 Blom J, Yin L, Liden A, et al. A 9-year follow-up study of participants and nonparticipants in sigmoidoscopy screening: importance of self-selection. Cancer Epidemiology, Biomarkers & Prevention. May. 2008;17(5):1163-8. KQ1E2. [pmid: 18483338].
16 Goulard H, Boussac-Zarebska M, Ancelle-Park R, et al. French colorectal cancer screening pilot programme: results of the first round. [Erratum appears in J Med Screen. 2008;15(4):214]. Journal of Medical Screening. 2008;15(3):143-8. KQ1E2. [pmid: 18927097].
17 Manfredi S, Piette C, Durand G, et al. Colonoscopy results of a French regional FOBT-based colorectal cancer screening program with high compliance. Eur J Radiol. May. 2008;40(5):422-7. KQ1E2. [pmid: 18231963].
18 Jones AM, Morris E, Thomas J, et al. Evaluation of bowel cancer registration data in England, 1996–2004. British Journal of Cancer. Oct. 20. 2009;101(8):1269-73. KQ1E2. [pmid: 19773758].
19 Ananda SS, McLaughlin SJ, Chen F, et al. Initial impact of Australia’s National Bowel Cancer Screening Program. Med J Aust. Oct. 5. 2009;191(7):378-81. KQ1E2. [pmid: 19807627].
20 Kahi CJ, Imperiale TF, Juliar BE, et al. Effect of screening colonoscopy on colorectal cancer incidence and mortality. Clinical Gastroenterology & Hepatology. 2009;7(7):770-5. KQ1E2. [pmid: 19268269].
21 Steele RJ, McClements PL, Libby G, et al. Results from the first three rounds of the Scottish demonstration pilot of FOBT screening for colorectal cancer. Gut. Apr. 2009;58(4):530-5. KQ1E2. [pmid: 19036949].
22 Baxter NN, Goldwasser MA, Paszat LF, et al. Association of colonoscopy and death from colorectal cancer. Ann Intern Med. Jan. 6. 2009;150(1):1-8. KQ1E2. [pmid: 19075198].
23 Denis B, Gendre I, Aman F, et al. Colorectal cancer screening with the addition of flexible sigmoidoscopy to guaiac-based faecal occult blood testing: a French population-based controlled study (Wintzenheim trial). European Journal of Cancer. Dec. 2009;45(18):3282-90. KQ1E2. [pmid: 19665368].
24 Singh H, Nugent Z, Demers AA, et al. The Reduction in Colorectal Cancer Mortality After Colonoscopy Varies by Site of the Cancer. Gastroenterology. Oct. 2010;139(4):1128-37. KQ1E2. [pmid: 20600026].
25 Brenner H, Altenhofen L, Hoffmeister M. Eight years of colonoscopic bowel cancer screening in Germany: initial findings and projections. Deutsches Arzteblatt International. Oct. 2010;107(43):753-9. KQ1E2. [pmid: 21085544].
26 Majek O, Danes J, Zavoral M, et al. Czech National Cancer Screening Programmes in 2010. Klinicka Onkologie. 2010;23(5):343-53. KQ1E2. [pmid: 21058528].
27 Ellul P, Fogden E, Simpson CL, et al. Downstaging of colorectal cancer by the National Bowel Cancer Screening programme in England: first round data from the first centre. Colorectal Disease. May. 2010;12(5):420-2. KQ1E2. [pmid: 19843116].
28 Brenner H, Hoffmeister M, Arndt V, et al. Protection from right- and left-sided colorectal neoplasms after colonoscopy: population-based study. J Natl Cancer Inst. Jan. 20. 2010;102(2):89-95. KQ1E2. [pmid: 20042716].
29 Steele RJ, Kostourou I, McClements P, et al. Effect of repeated invitations on uptake of colorectal cancer screening using faecal occult blood testing: analysis of prevalence and incidence screening. BMJ. 2010;341:c5531. KQ1E2. [pmid: 20980376].
30 Brenner H, Chang-Claude J, Seiler CM, et al. Protection From Colorectal Cancer After Colonoscopy A Population-Based, Case-Control Study. Ann Intern Med. Jan. 4. 2011;154(1):22-30. KQ1E2. [pmid: 21200035].
31 Gross CP, Soulos PR, Ross JS, et al. Assessing the impact of screening colonoscopy on mortality in the medicare population. Journal of General Internal Medicine. Dec. 2011;26(12):1441-9. KQ1E2. [pmid: 21842323].
32 Strock P, Mossong J, Scheiden R, et al. Colorectal cancer incidence is low in patients following a colonoscopy. Digestive & Liver Disease. Nov. 2011;43(11):899-904. KQ1E2. [pmid: 21831735].
33 Kistler CE, Kirby KA, Lee D, et al. Long-term outcomes following positive fecal occult blood test results in older adults: benefits and burdens. Archives of Internal Medicine. Aug. 8. 2011;171(15):1344-51. KQ1E2. [pmid: 21555655].
34 Stock C, Knudsen AB, Lansdorp-Vogelaar I, et al. Colorectal cancer mortality prevented by use and attributable to nonuse of colonoscopy. Gastrointest Endosc. Mar. 2011;73(3):435-43. KQ1E2. [pmid: 21353840].
35 Manfredi S, Philip J, Campillo B, et al. The positive predictive value of guaiac faecal occult blood test in relation to the number of positive squares in two consecutive rounds of colorectal cancer screening. Eur J Cancer Prev. Jul. 2011;20(4):277-82. KQ1E2. [pmid: 21633201].
36 Katicic M, Antoljak N, Kujundzic M, et al. Results of National Colorectal Cancer Screening Program in Croatia (2007–2011). World Journal of Gastroenterology. Aug. 28. 2012;18(32):4300-7. KQ1E2. [pmid: 22969192].
37 Logan RF, Patnick J, Nickerson C, et al. Outcomes of the Bowel Cancer Screening Programme (BCSP) in England after the first 1 million tests. Gut. Oct. 2012;61(10):1439-46. KQ1E2. [pmid: 22156981].
38 Van RS, Hoeck S, Van HG. Population-based screening for colorectal cancer using an immunochemical faecal occult blood test: a comparison of two invitation strategies. Cancer Epidemiology. Oct. 2012;36(5):e317-e324. KQ1E2. [pmid: 22560885].
39 Morris EJ, Whitehouse LE, Farrell T, et al. A retrospective observational study examining the characteristics and outcomes of tumours diagnosed within and without of the English NHS Bowel Cancer Screening Programme. British Journal of Cancer. Aug. 21. 2012;107(5):757-64. KQ1E2. [pmid: 22850549].
40 Gill MD, Bramble MG, Rees CJ, et al. Comparison of screen-detected and interval colorectal cancers in the Bowel Cancer Screening Programme. British Journal of Cancer. Jul. 24. 2012;107(3):417-21. KQ1E2. [pmid: 22782347].
41 Jacob BJ, Moineddin R, Sutradhar R, et al. Effect of colonoscopy on colorectal cancer incidence and mortality: an instrumental variable analysis. Gastrointest Endosc. Aug. 2012;76(2):355-64. KQ1E2. [pmid: 22658386].
42 Baxter NN, Warren JL, Barrett MJ, et al. Association between colonoscopy and colorectal cancer mortality in a US cohort according to site of cancer and colonoscopist specialty. Journal of Clinical Oncology. Jul. 20. 2012;30(21):2664-9. KQ1E2. [pmid: 22689809].
43 Ferrari BM, De CV, Devoto GL, et al. Colorectal cancer screening in LHU4 Chiavarese, Italy: ethical, methodological and outcome evaluations at the end of the first round. Journal of Preventive Medicine & Hygiene. Mar. 2012;53(1):37-43. KQ1E2. [pmid: 22803318].
44 Libby G, Brewster DH, McClements PL, et al. The impact of population-based faecal occult blood test screening on colorectal cancer mortality: a matched cohort study. British Journal of Cancer. Jul. 10. 2012;107(2):255-9. KQ1E2. [pmid: 22735907].
45 McClements PL, Madurasinghe V, Thomson CS, et al. Impact of the UK colorectal cancer screening pilot studies on incidence, stage distribution and mortality trends. Cancer Epidemiology. Aug. 2012;36(4):e232-e242. KQ1E2. [pmid: 22425027].
46 Manser CN, Bachmann LM, Brunner J, et al. Colonoscopy screening markedly reduces the occurrence of colon carcinomas and carcinoma-related death: a closed cohort study. Gastrointest Endosc. Jul. 2012;76(1):110-7. KQ1E2. [pmid: 22498179].
47 Steele RJ, McClements P, Watling C, et al. Interval cancers in a FOBT-based colorectal cancer population screening programme: implications for stage, gender and tumour site. Gut. Apr. 2012;61(4):576-81. KQ1E2. [pmid: 21930729].
48 Gupta S, Saunders BP, Fraser C, et al. The first 3 years of national bowel cancer screening at a single UK tertiary centre. Colorectal Disease. Feb. 2012;14(2):166-73. KQ1E2. [pmid: 21689280].
49 Brenner H, Chang-Claude J, Seiler CM, et al. Interval cancers after negative colonoscopy: population-based case-control study. Gut. Nov. 2012;61(11):1576-82. KQ1E2. [pmid: 22200840].
50 Fraser CG, Digby J, McDonald PJ, et al. Experience with a two-tier reflex gFOBT/FIT strategy in a national bowel screening programme. Journal of Medical Screening. Mar. 2012;19(1):8-13. KQ1E2. [pmid: 22156144].
51 Park MJ, Choi KS, Lee YK, et al. A comparison of qualitative and quantitative fecal immunochemical tests in the Korean national colorectal cancer screening program. Scand J Gastroenterol. Apr. 2012;47(4):461-6. KQ1E2. [pmid: 22428929].
52 Moss SM, Campbell C, Melia J, et al. Performance measures in three rounds of the English bowel cancer screening pilot. Gut. Jan. 2012;61(1):101-7. KQ1E2. [pmid: 21561880].
53 Doubeni CA, Weinmann S, Adams K, et al. Screening colonoscopy and risk for incident late-stage colorectal cancer diagnosis in average-risk adults: a nested case-control study. Ann Intern Med. Mar. 5. 2013;158(5 Pt 1):312-20. KQ1E2. [pmid: 23460054].
54 Tan WS, Tang CL, Koo WH. Opportunistic screening for colorectal neoplasia in Singapore using faecal immunochemical occult blood test. Singapore Medical Journal. Apr. 2013;54(4):220-3. KQ1E2. [pmid: 23624450].
55 Ferrante JM, Lee JH, McCarthy EP, et al. Primary care utilization and colorectal cancer incidence and mortality among Medicare beneficiaries: a population-based, case-control study. [Summary for patients in Ann Intern Med. 2013 Oct 1;159(7):I-24; PMID: 24081298]. Ann Intern Med. Oct. 1. 2013;159(7):437-46. KQ1E2. [pmid: 24081284].
56 Amri R, Bordeianou LG, Sylla P, et al. Impact of screening colonoscopy on outcomes in colon cancer surgery. JAMA Surgery. Aug. 2013;148(8):747-54. KQ1E2. [pmid: 23784448].
57 Wang YR, Cangemi JR, Loftus EV Jr, et al. Risk of colorectal cancer after colonoscopy compared with flexible sigmoidoscopy or no lower endoscopy among older patients in the United States, 1998–2005. Mayo Clinic Proceedings. May. 2013;88(5):464-70. KQ1E2. [pmid: 23522751].
58 Cole SR, Tucker GR, Osborne JM, et al. Shift to earlier stage at diagnosis as a consequence of the National Bowel Cancer Screening Program. Med J Aust. Apr. 1. 2013;198(6):327-30. KQ1E2. [pmid: 23545032].
59 Riboe DG, Dogan TS, Brodersen J. Safety of cold polypectomy for <10mm polyps at colonoscopy: a prospective multicenter study. Journal of Evaluation in Clinical Practice. Apr. 2013;19(2):311-6. KQ1E2. [pmid: 22332801].
60 Roxburgh CS, McTaggart F, Balsitis M, et al. Impact of the bowel-screening programme on the diagnosis of colorectal cancer in Ayrshire and Arran. Colorectal Disease. Jan. 2013;15(1):34-41. KQ1E2. [pmid: 22632378].
61 Rees CJ, Bevan R. The National Health Service Bowel Cancer Screening Program: the early years. Expert review of gastroenterology & hepatology. Jul. 2013;7(5):421-37. KQ1E2. [pmid: 23899282].
62 Cha JM, Lee JI, Joo KR, et al. Use of a low cut-off value for the fecal immunochemical test enables better detection of proximal neoplasia. Digestive Diseases & Sciences. Nov. 2013;58(11):3256-62. KQ1E2. [pmid: 23912251].
63 Kershenbaum A, Flugelman A, Lejbkowicz F, et al. Excellent performance of Hemoccult Sensa in organised colorectal cancer screening. European Journal of Cancer. Mar. 2013;49(4):923-30. KQ1E2. [pmid: 23099005].
64 Shin A, Choi KS, Jun JK, et al. Validity of fecal occult blood test in the national cancer screening program, Korea. PLoS ONE [Electronic Resource]. 2013;8(11):e79292. KQ1E2. [pmid: 24260189].
65 Leuraud K, Jezewski-Serra D, Viguier J, et al. Colorectal cancer screening by guaiac faecal occult blood test in France: Evaluation of the programme two years after launching. Cancer Epidemiology. Dec. 2013;37(6):959-67. KQ1E2. [pmid: 24035240].
66 Kelley L, Swan N, Hughes DJ. An analysis of the duplicate testing strategy of an Irish immunochemical faecal occult blood test colorectal cancer screening programme. Colorectal Disease. Sep. 2013;15(9):e512-e521. KQ1E2. [pmid: 23746062].
67 Major D, Bryant H, Delaney M, et al. Colorectal cancer screening in Canada: results from the first round of screening for five provincial programs. Current Oncology. Oct. 2013;20(5):252-7. KQ1E2. [pmid: 24155629].
68 Bretthauer M, Holme O, Garborg K. Computed tomography colonography vs. colonoscopy for colorectal cancer screening: close call, but not closed case. Eur J Radiol. 2013;45(3):159-60. KQ1E2. [pmid: 23446666].
69 Ladabaum U, Allen J, Wandell M, et al. Colorectal cancer screening with blood-based biomarkers: cost-effectiveness of methylated septin 9 DNA versus current strategies. Cancer Epidemiology, Biomarkers & Prevention. Sep. 2013;22(9):1567-76. KQ1E2. [pmid: 23796793].
70 Suchanek S, Majek O, Vojtechova G, et al. Colorectal cancer prevention in the Czech Republic: time trends in performance indicators and current situation after 10 years of screening. Eur J Cancer Prev. Jan. 2014;23(1):18-26. KQ1E2. [pmid: 24129196].
71 Rabeneck L, Tinmouth JM, Paszat LF, et al. Ontario’s Colon Cancer Check: Results from Canada’s first province-wide colorectal cancer screening program. Cancer Epidemiol Biomarkers Prev. Jan. 17. 2014;23(3):508-15. KQ1E2. [pmid: 24443406].
72 Brenner H, Chang-Claude J, Jansen L, et al. Reduced Risk of Colorectal Cancer Up to 10 Years After Screening, Surveillance, or Diagnostic Colonoscopy. Gastroenterology. 2014. KQ1E2. [pmid: 24012982].
73 Hermann B, Christian S, Michael H. Effect of screening sigmoidoscopy and screening colonoscopy on colorectal cancer incidence and mortality: systematic review and meta-analysis of randomised controlled trials and observational studies. BMJ. Apr. 2014;9:348. KQ1E2. [pmid: 24922745].
74 Wu BU, Longstreth GF, Ngor EW. Screening colonoscopy versus sigmoidoscopy: implications of a negative examination for cancer prevention and racial disparities in average-risk patients. Gastrointest Endosc. Nov. 2014;80(5):852-61. KQ1E2. [pmid: 24814774].
75 Wolf HJ, Dwyer A, Ahnen DJ, et al. Colon Cancer Screening for Colorado’s Underserved: A Community Clinic/Academic Partnership. Am J Prev Med. 2014. Dec. 26. KQ1E2. [pmid: 25547926].
76 Xirasagar S, Li YJ, Hurley TG, et al. Colorectal cancer prevention by an optimized colonoscopy protocol in routine practice. Int J Cancer. 2014. Sep. 20. KQ1E2. [pmid: 25242510].
77 Zorzi M, Fedeli U, Schievano E, et al. Impact on colorectal cancer mortality of screening programmes based on the faecal immunochemical test. Gut. 2014. Sep. 1. KQ1E2. [pmid: 25179811].
78 Kahi CJ, Rex DK, Imperiale TF. Screening, surveillance, and primary prevention for colorectal cancer: a review of the recent literature. Gastroenterology. Aug. 2008;135(2):380-99. KQ1E2, KQ2E2. [pmid: 18582467].
79 Faivre J, Dancourt V, Lejeune C. Screening for colorectal cancer with immunochemical faecal occult blood tests. [Review]. Digestive & Liver Disease. Dec. 2012;44(12):967-73. KQ1E2, KQ2E2. [pmid: 22898146].
80 Kim DH, Pooler BD, Weiss JM, et al. Five year colorectal cancer outcomes in a large negative CT colonography screening cohort. European Radiology. Jul. 2012;22(7):1488-94. KQ1E2, KQ2E2. [pmid: 22210409].
81 Crotta S, Segnan N, Paganin S, et al. High rate of advanced adenoma detection in 4 rounds of colorectal cancer screening with the fecal immunochemical test. Clin Gastroenterol Hepatol. Jun. 2012;10(6):633-8. KQ1E2, KQ2E2. [pmid: 22426085].
82 Seeff LC, Royalty J, Helsel WE, et al. Clinical outcomes from the CDC’s Colorectal Cancer Screening Demonstration Program. Cancer. Aug. 1. 2013;119:Suppl-33. KQ1E2, KQ2E2. [pmid: 23868476].
83 McNamara D, Leen R, Seng-Lee C, et al. Sustained participation, colonoscopy uptake and adenoma detection rates over two rounds of the Tallaght-Trinity College colorectal cancer screening programme with the faecal immunological test. European Journal of Gastroenterology & Hepatology. Dec. 2014;26(12):1415-21. KQ1E2, KQ2E2b. [pmid: 25244415].
84 Parente F, Vailati C, Boemo C, et al. Improved 5-year survival of patients with immunochemical faecal blood test-screen-detected colorectal cancer versus non-screening cancers in northern Italy. Digestive & Liver Disease. Jan. 2015;47(1):68-72. KQ1E2, KQ2E5. [pmid: 25306524].
85 Dancourt V, Lejeune C, Lepage C, et al. Immunochemical faecal occult blood tests are superior to guaiac-based tests for the detection of colorectal neoplasms. European Journal of Cancer. Oct. 2008;44(15):2254-8. KQ1E2, KQ2E7. [pmid: 18760592].
86 Elwood JM, Ali G, Schlup MM, et al. Flexible sigmoidoscopy or colonoscopy for colorectal screening: a randomized trial of performance and acceptability. Cancer Detect Prev. 1995;19(4):337-47. KQ1E2, KQ3E5. [pmid: 7553676].
87 Jin P, Wu ZT, Li SR, et al. Colorectal cancer screening with fecal occult blood test: A 22-year cohort study. Oncol Lett. Aug. 2013;6(2):576-82. KQ1E3a. [pmid: 24137374].
88 Huang Y, Li Q, Ge W, et al. Predictive power of quantitative and qualitative fecal immunochemical tests for hemoglobin in population screening for colorectal neoplasm. Eur J Cancer Prev. Jan. 2014;23(1):27-34. KQ1E3a. [pmid: 23942476].
89 Alatise OI, Arigbabu AO, Agbakwuru AE, et al. Polyp prevalence at colonoscopy among Nigerians: A prospective observational study. Nigerian Journal of Clinical Practice. Nov. 2014;17(6):756-62. KQ1E3a. [pmid: 25385915].
90 Sudoyo AW, Lesmana CR, Krisnuhoni E, et al. Detection rate of colorectal adenoma or cancer in unselected colonoscopy patients: indonesian experience in a private hospital. Asian Pacific Journal of Cancer Prevention: Apjcp. 2014;15(22):9801-4. KQ1E3a. [pmid: 25520108].
91 Cotterchio M, Manno M, Klar N, et al. Colorectal screening is associated with reduced colorectal cancer risk: a case-control study within the population-based Ontario Familial Colorectal Cancer Registry. Cancer Causes Control. Sep. 2005;16(7):865-75. KQ1E4. [pmid: 16132797].
92 Samadder NJ, Curtin K, Tuohy TM, et al. Characteristics of missed or interval colorectal cancer and patient survival: a population-based study. Gastroenterology. Apr. 2014;146(4):950-60. KQ1E4. [pmid: 24417818].
93 Zauber AG, Winawer SJ, O’Brien MJ, et al. Colonoscopic polypectomy and long-term prevention of colorectal-cancer deaths. N Engl J Med. Feb. 23. 2012;366(8):687-96. KQ1E4a. [pmid: 22356322].
94 Khalid-de Bakker CA, Jonkers DM, Sanduleanu S, et al. Test performance of immunologic fecal occult blood testing and sigmoidoscopy compared with primary colonoscopy screening for colorectal advanced adenomas. Cancer Prevention Research. Oct. 2011;4(10):1563-71. KQ1E5. [pmid: 21750209].
95 Multicentre Austrailian Colorectal-neoplasia Screening (MACS) Group. A comparison of colorectal neoplasia screening tests: a multicentre community-based study of the impact of consumer choice. Med J Aust. Jun. 5. 2006;184(11):546-50. KQ1E5. [pmid: 16768659].
96 Kewenter J, Brevinge H, Engaras B, et al. Follow-up after screening for colorectal neoplasms with fecal occult blood testing in a controlled trial. Dis Colon Rectum. Feb. 1994;37(2):115-9. KQ1E5a. [pmid: 8306829].
97 Kronborg O, Fenger C, Olsen J, et al. Randomised study of screening for colorectal cancer with faecal-occult-blood test. Lancet. Nov. 30. 1996;348(9040):1467-71. KQ1E5a. [pmid: 8942774].
98 Mandel JS, Church TR, Ederer F, et al. Colorectal cancer mortality: effectiveness of biennial screening for fecal occult blood. J Natl Cancer Inst. Mar. 3. 1999;91(5):434-7. KQ1E5a. [pmid: 10070942].
99 Atkin WS, Edwards R, Wardle J, et al. Design of a multicentre randomised trial to evaluate flexible sigmoidoscopy in colorectal cancer screening. J Med Screen. 2001;8(3):137-44. KQ1E5a. [pmid: 11678553].
100 Jorgensen OD, Kronborg O, Fenger C. A randomised study of screening for colorectal cancer using faecal occult blood testing: results after 13 years and seven biennial screening rounds. Gut. Jan. 2002;50(1):29-32. KQ1E5a. [pmid: 11772963].
101 Scholefield JH, Moss S, Sufi F, et al. Effect of faecal occult blood screening on mortality from colorectal cancer: results from a randomised controlled trial. Gut. Jun. 2002;50(6):840-4. KQ1E5a. [pmid: 12010887].
102 Bonelli L, Sciallero S, Senore C, et al. History of negative colorectal endoscopy and risk of rectosigmoid neoplasms at screening flexible sigmoidoscopy. Int J Colorectal Dis. Mar. 2006;21(2):105-13. KQ1E5a. [pmid: 15864604].
103 Malila N, Oivanen T, Hakama M. Implementation of colorectal cancer screening in Finland: experiences from the first three years of a public health programme. Zeitschrift fur Gastroenterologie. Apr. 2008;46:Suppl-8. KQ1E5a. [pmid: 18368636].
104 Guittet L, Launoy G. Diagnostic accuracy of immunochemical faecal occult blood tests according to number of samples and positivity threshold. Journal of Medical Screening. 2008;15(1):48-9. KQ1E5a. [pmid: 18416958].
105 Hol L, Wilschut JA, van BM, et al. Screening for colorectal cancer: random comparison of guaiac and immunochemical faecal occult blood testing at different cut-off levels. British Journal of Cancer. Apr. 7. 2009;100(7):1103-10. KQ1E5a. [pmid: 19337257].
106 Paimela H, Malila N, Palva T, et al. Early detection of colorectal cancer with faecal occult blood test screening. British Journal of Surgery. Oct. 2010;97(10):1567-71. KQ1E5a. [pmid: 20603855].
107 Whynes DK, Mangham CM, Balfour TW, et al. Analysis of deaths occurring within the Nottingham trial of faecal occult blood screening for colorectal cancer. Gut. Aug. 2010;59(8):1088-93. KQ1E5a. [pmid: 20639252].
108 Weissfeld JL, Schoen RE, Pinsky PF, et al. Flexible sigmoidoscopy in the randomized prostate, lung, colorectal, and ovarian (PLCO) cancer screening trial: added yield from a second screening examination. J Natl Cancer Inst. Feb. 22. 2012;104(4):280-9. KQ1E5a. [pmid: 22298838].
109 Castells A, Bessa X, Quintero E, et al. Risk of advanced proximal neoplasms according to distal colorectal findings: comparison of sigmoidoscopy-based strategies. J Natl Cancer Inst. Jun. 19. 2013;105(12):878-86. KQ1E5a. [pmid: 23708054].
110 Shaukat A, Mongin S, Geisser M, et al. Long-term mortality following screening for colorectal cancer: Results from the minnesota fecal occult blood trial. Am J Gastroenterol. 2013;108:S646-S647. KQ1E5a.
111 Salas D, Vanaclocha M, Ibanez J, et al. Participation and detection rates by age and sex for colonoscopy versus fecal immunochemical testing in colorectal cancer screening. Cancer Causes & Control. Aug. 2014;25(8):985-97. KQ1E5a. [pmid: 24859111].
112 Schoen RE, Pinsky PF, Weissfeld JL, et al. Results of repeat sigmoidoscopy 3 years after a negative examination. JAMA. Jul. 2. 2003;290(1):41-8. KQ1E5a, KQ2E2. [pmid: 12837710].
113 Kewenter J, Brevinge H. Endoscopic and surgical complications of work-up in screening for colorectal cancer. Dis Colon Rectum. Jun. 1996;39(6):676-80. KQ1E5a, KQ3E4a. [pmid: 8646956].
114 Robinson MH, Hardcastle JD, Moss SM, et al. The risks of screening: data from the Nottingham randomised controlled trial of faecal occult blood screening for colorectal cancer. Gut. Oct. 1999;45(4):588-92. KQ1E5a, KQ3E4a. [pmid: 10486370].
115 Lindholm E, Berglund B, Kewenter J, et al. Worry associated with screening for colorectal carcinomas. Scand J Gastroenterol. Mar. 1997;32(3):238-45. KQ1E5a, KQ3E5. [pmid: 9085461].
116 Schoen RE, Weissfeld JL, Bowen NJ, et al. Patient satisfaction with screening flexible sigmoidoscopy. Arch Intern Med. Jun. 26. 2000;160(12):1790-6. KQ1E5a, KQ3E5. [pmid: 10871972].
117 Parker MA, Robinson MH, Scholefield JH, et al. Psychiatric morbidity and screening for colorectal cancer. J Med Screen. 2002;9(1):7-10. KQ1E5a, KQ3E5. [pmid: 11943790].
118 Larsen IK, Grotmol T, Bretthauer M, et al. Continuous evaluation of patient satisfaction in endoscopy centres. Scand J Gastroenterol. Jul. 2002;37(7):850-5. KQ1E5a, KQ3E5. [pmid: 12190102].
119 Wardle J, Williamson S, Sutton S, et al. Psychological impact of colorectal cancer screening. Health Psychol. Jan. 2003;22(1):54-9. KQ1E5a, KQ3E5. [pmid: 12558202].
120 Larsen IK, Grotmol T, Almendingen K, et al. Impact of colorectal cancer screening on future lifestyle choices: a three-year randomized controlled trial. Clin Gastroenterol Hepatol. Apr. 2007;5(4):477-83. KQ1E5a, KQ3E5. [pmid: 17363335].
121 Hol L, de JV, van Leerdam ME, et al. Screening for colorectal cancer: comparison of perceived test burden of guaiac-based faecal occult blood test, faecal immunochemical test and flexible sigmoidoscopy. European Journal of Cancer. Jul. 2010;46(11):2059-66. KQ1E5a, KQ3E5. [pmid: 20621736].
122 Fracchia M, Senore C, Armaroli P, et al. Assessment of the multiple components of the variability in the adenoma detection rate in sigmoidoscopy screening, and lessons for training. Eur J Radiol. Jun. 2010;42(6):448-55. KQ1E5a, KQ3E5. [pmid: 20414864].
123 Denters MJ, Deutekom M, Essink-Bot ML, et al. FIT false-positives in colorectal cancer screening experience psychological distress up to 6 weeks after colonoscopy. Support Care Cancer. Oct. 2013;21(10):2809-15. KQ1E5a, KQ3E5. [pmid: 23729229].
124 Atkin WS, Hart A, Edwards R, et al. Uptake, yield of neoplasia, and adverse effects of flexible sigmoidoscopy screening. Gut. Apr. 1998;42(4):560-5. KQ1E5a. [pmid: 9616321].
125 Gondal G, Grotmol T, Hofstad B, et al. The Norwegian Colorectal Cancer Prevention (NORCCAP) screening study: baseline findings and implementations for clinical work-up in age groups 50–64 years. Scandinavian Journal of Gastroenterology. 2003;38(6):635-42. Jun. KQ1E5a. [pmid: 12825872].
126 Hoff G, Grotmol T, Skovlund E, et al. Risk of colorectal cancer seven years after flexible sigmoidoscopy screening: randomised controlled trial. BMJ. 2009;338:b1846. KQ1E5a. [pmid: 19483252].
127 Thiis-Evensen E, Kalager M, Bretthauer M, et al. Long-term effectiveness of endoscopic screening on incidence and mortality of colorectal cancer: A randomized trial. United European Gastroenterology Journal. Jun. 2013;1(3):162-8. KQ1E7. [pmid: 24917955].
128 Hillyer GC, Schmitt KM, Freedberg DE, et al. Fecal-based colorectal cancer screening among the uninsured in northern Manhattan. American Journal of Preventive Medicine. Aug. 2014;47(2):182-7. KQ1E7. [pmid: 24951037].
129 Shuhaibar M, Walsh C, Lindsay F, et al. A comparative study of faecal occult blood kits in a colorectal cancer screening program in a cohort of healthy construction workers. Irish Journal of Medical Science. Mar. 2011;180(1):103-8. KQ1E7, KQ2E2b. [pmid: 20953981].
130 Thiis-Evensen E, Hoff GS, Sauar J, et al. The effect of attending a flexible sigmoidoscopic screening program on the prevalence of colorectal adenomas at 13-year follow-up. Am J Gastroenterol. Jun. 2001;96(6):1901-7. KQ1E7, KQ3E5a. [pmid: 11419846].
131 Kim DH, Pickhardt PJ, Taylor AJ, et al. CT colonography versus colonoscopy for the detection of advanced neoplasia. N Engl J Med. Oct. 4. 2007;357(14):1403-12. KQ1E7. [pmid: 17914041].
132 Hoff G, Sauar J, Vatn MH, et al. Polypectomy of adenomas in the prevention of colorectal cancer: 10 years’ follow-up of the Telemark Polyp Study I. A prospective, controlled population study. Scand J Gastroenterol. Oct. 1996;31(10):1006-10. KQ1E7. [pmid: 8898422].
133 Thiis-Evensen E, Hoff GS, Sauar J, et al. Population-based surveillance by colonoscopy: effect on the incidence of colorectal cancer. Telemark Polyp Study I. Scand J Gastroenterol. Apr. 1999;34(4):414-20. KQ1E7. [pmid: 10365903].
134 Towler B, Irwig L, Glasziou P, et al. A systematic review of the effects of screening for colorectal cancer using the faecal occult blood test, hemoccult. BMJ. 1998;317:559-65. KQ1E9. [pmid: 9721111].
135 Hewitson P, Glasziou P, Irwig L, et al. Screening for colorectal cancer using the faecal occult blood test. Hemoccult Cochrane Database of Systematic Reviews. 2007;(1):CD001216. KQ1E9. [pmid: 17253456].
136 Hewitson P, Glasziou P, Watson E, et al. Cochrane systematic review of colorectal cancer screening using the fecal occult blood test (hemoccult): an update. Am J Gastroenterol. Jun. 2008;103(6):1541-9. KQ1E9. [pmid: 18479499].
137 Elmunzer BJ, Hayward RA, Schoenfeld PS, et al. Effect of flexible sigmoidoscopy-based screening on incidence and mortality of colorectal cancer: a systematic review and meta-analysis of randomized controlled trials. PLoS Medicine/Public Library of Science. 2012;9(12):e1001352. KQ1E9. [pmid: 23226108].
138 Littlejohn C, Hilton S, Macfarlane GJ, et al. Systematic review and meta-analysis of the evidence for flexible sigmoidoscopy as a screening method for the prevention of colorectal cancer. British Journal of Surgery. Nov. 2012;99(11):1488-500. KQ1E9. [pmid: 23001715].
139 Holme O, Bretthauer M, Fretheim A, et al. Flexible sigmoidoscopy versus faecal occult blood testing for colorectal cancer screening in asymptomatic individuals. Cochrane Database of Systematic Reviews. 2013;9:CD009259. KQ1E9. [pmid: 24085634].
140 Whitlock EP, Lin J, Liles E, et al. Screening for Colorectal Cancer: An Updated Systematic Review. 2008. KQ1E9, KQ2E9, KQ3E9. [pmid: 20722162].
141 Atkin WS, Edwards R, Kralj-Hans I, et al. Once-only flexible sigmoidoscopy screening in prevention of colorectal cancer: a multicentre randomised controlled trial. Lancet. May. 8. 2010;375(9726):1624-33. KQ3E5. [pmid: 20430429].
142 Ferrandez A, Navarro M, Diez M, et al. Risk factors for advanced lesions undetected at prior colonoscopy: not always poor preparation. Eur J Radiol. Dec. 2010;42(12):1071-6. KQ2E1. [pmid: 20960390].
143 Cash BD, Stamps K, McFarland EG, et al. Clinical use of CT colonography for colorectal cancer screening in military training facilities and potential impact on HEDIS measures. Journal of the American College of Radiology. Jan. 2013;10(1):30-6. KQ2E1. [pmid: 23290671].
144 Brenner H, Altenhofen L, Tao S. Matching of controls may lead to biased estimates of specificity in the evaluation of cancer screening tests. Journal of Clinical Epidemiology. Feb. 2013;66(2):202-8. KQ2E1. [pmid: 23257151].
145 Sikka S, Ringold DA, Jonnalagadda S, et al. Comparison of white light and narrow band high definition images in predicting colon polyp histology, using standard colonoscopes without optical magnification. Eur J Radiol. Oct. 2008;40(10):818-22. KQ2E1a. [pmid: 18668472].
146 Matsuda T, Saito Y, Fu KI, et al. Does autofluorescence imaging videoendoscopy system improve the colonoscopic polyp detection rate?--a pilot study. The American journal of gastroenterology. 2008;103:1926-32. KQ2E1a. [pmid: 18647285].
147 Van den Broek FJ, Reitsma JB, Curvers WL, et al. Systematic review of narrow-band imaging for the detection and differentiation of neoplastic and nonneoplastic lesions in the colon. Gastrointest Endosc. 2009;69(1):124-35. KQ2E1a. [pmid: 19111693].
148 Rastogi A, Keighley J, Singh V, et al. High accuracy of narrow band imaging without magnification for the real-time characterization of polyp histology and its comparison with high-definition white light colonoscopy: a prospective study. Am J Gastroenterol. Oct. 2009;104(10):2422-30. KQ2E1a. [pmid: 19584829].
149 Hewett DG, Rex DK. Cap-fitted colonoscopy: a randomized, tandem colonoscopy study of adenoma miss rates. Gastrointest Endosc. Oct. 2010;72(4):775-81. KQ2E1a. [pmid: 20579648].
150 Chung SJ, Kim D, Song JH, et al. Efficacy of computed virtual chromoendoscopy on colorectal cancer screening: a prospective, randomized, back-to-back trial of Fuji Intelligent Color Enhancement versus conventional colonoscopy to compare adenoma miss rates. Gastrointest Endosc. Jul. 2010;72(1):136-42. KQ2E1a. [pmid: 20493487].
151 Kahi CJ, Anderson JC, Waxman I, et al. High-definition chromocolonoscopy vs. high-definition white light colonoscopy for average-risk colorectal cancer screening. Am J Gastroenterol. Jun. 2010;105(6):1301-7. KQ2E1a. [pmid: 20179689].
152 Gross SA, Buchner AM, Crook JE, et al. A comparison of high definition-image enhanced colonoscopy and standard white-light colonoscopy for colorectal polyp detection. Eur J Radiol. Dec. 2011;43(12):1045-51. KQ2E1a. [pmid: 21971929].
153 Lee CK, Lee SH, Hwangbo Y. Narrow-band imaging versus I-Scan for the real-time histological prediction of diminutive colonic polyps: a prospective comparative study by using the simple unified endoscopic classification. Gastrointest Endosc. Sep. 2011;74(3):603-9. KQ2E1a. [pmid: 21762907].
154 Leufkens AM, DeMarco DC, Rastogi A, et al. Effect of a retrograde-viewing device on adenoma detection rate during colonoscopy: the TERRACE study. Gastrointest Endosc. Mar. 2011;73(3):480-9. KQ2E1a. [pmid: 21067735].
155 Ikematsu H, Saito Y, Tanaka S, et al. The impact of narrow band imaging for colon polyp detection: a multicenter randomized controlled trial by tandem colonoscopy. Journal of Gastroenterology. Oct. 2012;47(10):1099-107. KQ2E1a. [pmid: 22441532].
156 Siersema PD, Rastogi A, Leufkens AM, et al. Retrograde-viewing device improves adenoma detection rate in colonoscopies for surveillance and diagnostic workup. World Journal of Gastroenterology. Jul. 14. 2012;18(26):3400-8. KQ2E1a. [pmid: 22807609].
157 Leufkens AM, van Oijen MG, Vleggaar FP, et al. Factors influencing the miss rate of polyps in a back-to-back colonoscopy study. Eur J Radiol. May. 2012;44(5):470-5. KQ2E1a. [pmid: 22441756].
158 Hong SN, Choe WH, Lee JH, et al. Prospective, randomized, back-to-back trial evaluating the usefulness of i-SCAN in screening colonoscopy. Gastrointest Endosc. May. 2012;75(5):1011-21. KQ2E1a. [pmid: 22381530].
159 Chan JL, Lin L, Feiler M, et al. Comparative effectiveness of i-SCAN and high-definition white light characterizing small colonic polyps. World Journal of Gastroenterology. Nov. 7. 2012;18(41):5905-11. KQ2E1a. [pmid: 23139606].
160 Kakol D, Fraczek M, Banaszkiewicz A, et al. Narrow-band imaging and white-light endoscopy for detection of colorectal polyps: a randomized study. Polskie Archiwum Medycyny Wewnetrznej. 2013;123(10):519-25. KQ2E1a. [pmid: 23928892].
161 Chung SJ, Kim D, Song JH, et al. Comparison of detection and miss rates of narrow band imaging, flexible spectral imaging chromoendoscopy and white light at screening colonoscopy: a randomised controlled back-to-back study. Gut. 2013. Jul. 12. KQ2E1a. [pmid: 23853211].
162 Foutch PG, Mai H, Pardy K, et al. Flexible sigmoidoscopy may be ineffective for secondary prevention of colorectal cancer in asymptomatic, average-risk men. Dig Dis Sci. Jul. 1991;36(7):924-8. KQ2E2. [pmid: 2070706].
163 Schoenfeld P, Lipscomb S, Crook J, et al. Accuracy of polyp detection by gastroenterologists and nurse endoscopists during flexible sigmoidoscopy: a randomized trial. Gastroenterology. Aug. 1999;117(2):312-8. KQ2E2. [pmid: 10419911].
164 Burke CA, Elder K, Lopez R. Screening for colorectal cancer with flexible sigmoidoscopy: is a 5-yr interval appropriate? A comparison of the detection of neoplasia 3 yr versus 5 yr after a normal examination. Am J Gastroenterol. Jun. 2006;101(6):1329-32. KQ2E2. [pmid: 16771957].
165 Yang KC, Liao CS, Chiu YH, et al. Colorectal cancer screening with faecal occult blood test within a multiple disease screening programme: an experience from Keelung, Taiwan. J Med Screen. 2006;13(Suppl 1):S8-13. KQ2E2. [pmid: 17227635].
166 Summers RM, Handwerker LR, Pickhardt PJ, et al. Performance of a previously validated CT colonography computer-aided detection system in a new patient population. AJR. Jul. American. 2008;(1):168-74. KQ2E2. [pmid: 18562741].
167 Taylor SA, Charman SC, Lefere P, et al. CT colonography: investigation of the optimum reader paradigm by using computer-aided detection software. Radiology. Feb. 2008;246(2):463-71. KQ2E2. [pmid: 18094263].
168 Taylor SA, Greenhalgh R, Ilangovan R, et al. CT colonography and computer-aided detection: effect of false-positive results on reader specificity and reading efficiency in a low-prevalence screening population. Radiology. Apr. 2008;247(1):133-40. KQ2E2. [pmid: 18292478].
169 Taylor SA, Burling D, Roddie M, et al. Computer-aided detection for CT colonography: incremental benefit of observer training. British Journal of Radiology. Mar. 2008;81(963):180-6. KQ2E2. [pmid: 18180260].
170 Pohl J, Lotterer E, Balzer C, et al. Computed virtual chromoendoscopy versus standard colonoscopy with targeted indigocarmine chromoscopy: a randomised multicentre trial. Gut. Jan. 2009;58(1):73-8. KQ2E2. [pmid: 18838485].
171 ECRI Institute. Computed tomographic (CT) colonography for colorectal cancer screening and diagnosis. Or Manager. Jun. 2009;25(6):15-8. KQ2E2. [pmid: 19558018].
172 Park SH, Kim SY, Lee SS, et al. Sensitivity of CT colonography for nonpolypoid colorectal lesions interpreted by human readers and with computer-aided detection. AJR. Jul. American. 2009;(1):70-8. KQ2E2. [pmid: 19542397].
173 Pickhardt PJ, Kim DH, Hassan C. Advanced neoplasia detection rates at colonoscopy screening: implications for CT colonography. Gastroenterology. 2009;136(3):1121-2. KQ2E2. [pmid: 19167389].
174 Rosenberg JA, Rubin DT. Performance of CT colonography in clinical trials. Gastrointestinal Endoscopy Clinics of North America. Apr. 2010;20(2):193-207. KQ2E2. [pmid: 20451810].
175 Suzuki K, Rockey DC, Dachman AH. CT colonography: advanced computer-aided detection scheme utilizing MTANNs for detection of “missed” polyps in a multicenter clinical trial. Medical Physics. Jan. 2010;37(1):12-21. KQ2E2. [pmid: 20175461].
176 Leung K, Pinsky P, Laiyemo AO, et al. Ongoing colorectal cancer risk despite surveillance colonoscopy: the Polyp Prevention Trial Continued Follow-up Study. Gastrointest Endosc. Jan. 2010;71(1):111-7. KQ2E2. [pmid: 19647250].
177 Hewett DG, Rex DK. Miss rate of right-sided colon examination during colonoscopy defined by retroflexion: an observational study. Gastrointest Endosc. Aug. 2011;74(2):246-52. KQ2E2. [pmid: 21679946].
178 Kahi CJ, Hewett DG, Norton DL, et al. Prevalence and variable detection of proximal colon serrated polyps during screening colonoscopy. Clinical Gastroenterology & Hepatology. Jan. 2011;9(1):42-6. KQ2E2. [pmid: 20888435].
179 Lathroum L, Ramos-Mercado F, Hernandez-Marrero J, et al. Ethnic and sex disparities in colorectal neoplasia among Hispanic patients undergoing screening colonoscopy. Clinical Gastroenterology & Hepatology. Sep. 2012;10(9):997-1001. KQ2E2. [pmid: 22542749].
180 Westwood DA, Alexakis N, Connor SJ. Transparent cap-assisted colonoscopy versus standard adult colonoscopy: a systematic review and meta-analysis. Diseases of the Colon & Rectum. Feb. 2012;55(2):218-25. KQ2E2. [pmid: 22228167].
181 Fraser CG, Allison JE, Young GP, et al. Quantitation of hemoglobin improves fecal immunochemical tests for noninvasive screening. Clinical Gastroenterology & Hepatology. Jul. 2013;11(7):839-40. KQ2E2. [pmid: 23591278].
182 Kearns B, Whyte S, Chilcott J, et al. Guaiac faecal occult blood test performance at initial and repeat screens in the English Bowel Cancer Screening Programme. British Journal of Cancer. Oct. 28. 2014;111(9):1734-41. KQ2E2. [pmid: 25180767].
183 Zhang H, Qi J, Wu YQ, et al. Accuracy of early detection of colorectal tumours by stool methylation markers: a meta-analysis. World Journal of Gastroenterology. Oct. 14. 2014;20(38):14040-50. KQ2E2. [pmid: 25320544].
184 Raginel T, Puvinel J, Ferrand O, et al. A population-based comparison of immunochemical fecal occult blood tests for colorectal cancer screening. Gastroenterology. May. 2013;144(5):918-25. KQ2E2, KQ1E2. [pmid: 23376426].
185 Pox CP, Schmiegel W. Role of CT colonography in colorectal cancer screening: risks and benefits. Gut. May. 2010;59(5):692-700. KQ2E2, KQ3E2. [pmid: 20427403].
186 Tao S, Hundt S, Haug U, et al. Sensitivity estimates of blood-based tests for colorectal cancer detection: impact of overrepresentation of advanced stage disease. [Review]. Am J Gastroenterol. Feb. 2011;106(2):242-53. KQ2E2a. [pmid: 20959816].
187 Warren JD, Xiong W, Bunker AM, et al. Septin 9 methylated DNA is a sensitive and specific blood test for colorectal cancer. BMC Medicine. 2011;9:133. KQ2E2a. [pmid: 22168215].
188 Septin 9 (SEPT9) methylation analysis for colorectal cancer. 2012. KQ2E2a.
189 Ahlquist DA, Zou H, Domanico M, et al. Next-generation stool DNA test accurately detects colorectal cancer and large adenomas. Gastroenterology. 2012;142(2):248-56. KQ2E2a. [pmid: 22062357].
190 Toth K, Sipos F, Kalmar A, et al. Detection of methylated SEPT9 in plasma is a reliable screening method for both left- and right-sided colon cancers. PLoS ONE [Electronic Resource]. 2012;7(9):e46000. KQ2E2a. [pmid: 23049919].
191 Ahlquist DA, Taylor WR, Mahoney DW, et al. The stool DNA test is more accurate than the plasma septin 9 test in detecting colorectal neoplasia. Clinical Gastroenterology & Hepatology. Mar. 2012;10(3):272-7. KQ2E2a. [pmid: 22019796].
192 Heigh RI, Yab TC, Taylor WR, et al. Detection of Colorectal Serrated Polyps by Stool DNA Testing: Comparison with Fecal Immunochemical Testing for Occult Blood (FIT). PLoS ONE. [Electronic Resource]. Jan. 20. 2014;9(1):e85659. KQ2E2a. [pmid: 24465639].
193 Teoh ML, Puvan R, Cheah PY, et al. Colorectal cancer screening: yield of faecal occult blood testing. Asian Pacific Journal of Cancer Prevention: Apjcp. 2010;11(1):153-6. KQ2E2b. [pmid: 20593948].
194 Pickhardt PJ, Wise SM, Kim DH. Positive predictive value for polyps detected at screening CT colonography. European Radiology. Jul. 2010;20(7):1651-6. KQ2E2b. [pmid: 20069423].
195 Pickhardt PJ, Durick NA, Pooler BD, et al. Left-sided polyps detected at screening CT colonography: do we need complete optical colonoscopy for further evaluation?. [Erratum appears in Radiology. 2011 Jul;260(1):308]. Radiology. May. 2011;259(2):429-34. KQ2E2b. [pmid: 21357518].
196 Van Turenhout ST, van Rossum LG, Oort FA, et al. Similar fecal immunochemical test results in screening and referral colorectal cancer. World Journal of Gastroenterology. Oct. 14. 2012;18(38):5397-403. KQ2E2b. [pmid: 23082056].
197 Pooler BD, Kim DH, Hassan C, et al. Variation in diagnostic performance among radiologists at screening CT colonography. Radiology. Jul. 2013;268(1):127-34. KQ2E2b. [pmid: 23449954].
198 Liao CS, Lin YM, Chang HC, et al. Application of quantitative estimates of fecal hemoglobin concentration for risk prediction of colorectal neoplasia. World Journal of Gastroenterology. Dec. 7. 2013;19(45):8366-72. KQ2E2b. [pmid: 24363529].
199 Senore C, Armaroli P, Arrigoni A, et al. Neoplasia yield of repeated immunochemical fobt following a negative screening sigmoidoscopy. Gastroenterology. 2013;144:S96-S97. KQ2E2b.
200 Poskus T, Strupas K, Mikalauskas S, et al. Initial results of the National Colorectal Cancer Screening Program in Lithuania. Eur J Cancer Prev. 2014. Nov. 3. KQ2E2b. [pmid: 25370682].
201 Li S, Wang H, Hu J, et al. New immunochemical fecal occult blood test with two-consecutive stool sample testing is a cost-effective approach for colon cancer screening: results of a prospective multicenter study in Chinese patients. Int J Cancer. Jun. 15. 2006;118(12):3078-83. KQ2E3a. [pmid: 16425283].
202 Miutescu B, Sporea I, Popescu A, et al. Effectiveness of the immunochemical fecal test (FIT) for detection of advanced adenomas in colorectal carcinoma screening in an asymptomatic population. Revista Medico-Chirurgicala a Societatii de Medici Si Naturalisti Din Iasi. Apr. 2013;117(2):302-7. KQ2E3a. [pmid: 24340508].
203 Rozen P, Knaani J, Samuel Z. Performance characteristics and comparison of two immunochemical and two guaiac fecal occult blood screening tests for colorectal neoplasia. Dig Dis Sci. Oct. 1997;42(10):2064-71. KQ2E4. [pmid: 9365136].
204 Wessling J, Fischbach R, Domagk D, et al. Colorectal polyps: Detection with multi-slice CT colonography. Rofo. Dec. 2001;173(12):1069-71. KQ2E4. [pmid: 11740665].
205 Yoshida H, Nappi J, MacEneaney P, et al. Computer-aided diagnosis scheme for detection of polyps at CT colonography. Radiographics. Jul. 2002;22(4):963-79. KQ2E4. [pmid: 12110726].
206 Yoshida H, Masutani Y, MacEneaney P, et al. Computerized detection of colonic polyps at CT colonography on the basis of volumetric features: pilot study. Radiology. Feb. 2002;222(2):327-36. KQ2E4. [pmid: 11818596].
207 Lefere PA, Gryspeerdt SS, Dewyspelaere J, et al. Dietary fecal tagging as a cleansing method before CT colonography: initial results polyp detection and patient acceptance. Radiology. Aug. 2002;224(2):393-403. KQ2E4. [pmid: 12147834].
208 George ML, Tutton MG, Jadhav VV, et al. Colonoscopy in older patients: a safe and sound practice. Age Ageing. Jan. 2002;31(1):80-1. KQ2E4. [pmid: 11850317].
209 Wong BC, Wong WM, Cheung KL, et al. A sensitive guaiac faecal occult blood test is less useful than an immunochemical test for colorectal cancer screening in a Chinese population. Aliment Pharmacol Ther. Nov. 1. 2003;18(9):941-6. KQ2E4. [pmid: 14616158].
210 Vvan Rijn JC, Reitsma JB, Stoker J, et al. Polyp miss rate determined by tandem colonoscopy: a systematic review. [Review] [26 refs]. Am J Gastroenterol. Feb. 2006;101(2):343-50. KQ2E4. [pmid: 16454841].
211 Kaltenbach T, Friedland S, Soetikno R. A randomised tandem colonoscopy trial of narrow band imaging versus white light examination to compare neoplasia miss rates. Gut. Oct. 2008;57(10):1406-12. KQ2E4. [pmid: 18523025].
212 Heresbach D, Barrioz T, Lapalus MG, et al. Miss rate for colorectal neoplastic polyps: a prospective multicenter study of back-to-back video colonoscopies. Eur J Radiol. Apr. 2008;40(4):284-90. KQ2E4. [pmid: 18389446].
213 Hock D, Ouhadi R, Materne R, et al. Virtual dissection CT colonography: evaluation of learning curves and reading times with and without computer-aided detection. Radiology. Sep. 2008;248(3):860-8. KQ2E4. [pmid: 18710980].
214 Chaparro M, Gisbert JP, Del CL, et al. Accuracy of computed tomographic colonography for the detection of polyps and colorectal tumors: a systematic review and meta-analysis. [Review] [80 refs]. Digestion. 2009;80(1):1-17. KQ2E4. [pmid: 19407448].
215 Young PE, Ray QP, Hwang I, et al. Gastroenterologists’ interpretation of CTC: a pilot study demonstrating feasibility and similar accuracy compared with radiologists’ interpretation. Am J Gastroenterol. Dec. 2009;104(12):2926-31. KQ2E4. [pmid: 19672252].
216 Taylor SA, Brittenden J, Lenton J, et al. Influence of computer-aided detection false-positives on reader performance and diagnostic confidence for CT colonography. AJR. Jun. American. 2009;(6):1682-9. KQ2E4. [pmid: 19457835].
217 Zhu H, Liang Z, Pickhardt PJ, et al. Increasing computer-aided detection specificity by projection features for CT colonography. Medical Physics. Apr. 2010;37(4):1468-81. KQ2E4. [pmid: 20443468].
218 Oort FA, Terhaar sive Droste JS, van der Hulst RW, et al. Colonoscopy-controlled intra-individual comparisons to screen relevant neoplasia: faecal immunochemical test vs. guaiac-based faecal occult blood test. Alimentary Pharmacology & Therapeutics. Feb. 1. 2010;31(3):432-9. KQ2E4. [pmid: 19878150].
219 Pickhardt PJ, Hassan C, Halligan S, et al. Colorectal cancer: CT colonography and colonoscopy for detection--systematic review and meta-analysis. Radiology. May. 2011;259(2):393-405. KQ2E4. [pmid: 21415247].
220 Oort FA, van Turenhout ST, Coupe VM, et al. Double sampling of a faecal immunochemical test is not superior to single sampling for detection of colorectal neoplasia: a colonoscopy controlled prospective cohort study. BMC Cancer. 2011;11:434. KQ2E4. [pmid: 21985604].
221 Omata F, Shintani A, Isozaki M, et al. Diagnostic performance of quantitative fecal immunochemical test and multivariate prediction model for colorectal neoplasms in asymptomatic individuals. European Journal of Gastroenterology & Hepatology. Nov. 2011;23(11):1036-41. KQ2E4. [pmid: 21897207].
222 Chiang TH, Lee YC, Tu CH, et al. Performance of the immunochemical fecal occult blood test in predicting lesions in the lower gastrointestinal tract. CMAJ Canadian Medical Association Journal. Sep. 20. 2011;183(13):1474-81. KQ2E4. [pmid: 21810951].
223 Kalimutho M, Del Vecchio BG, Cretella M, et al. A simplified, non-invasive fecal-based DNA integrity assay and iFOBT for colorectal cancer detection. International Journal of Colorectal Disease. May. 2011;26(5):583-92. KQ2E4. [pmid: 21225430].
224 Chen JG, Cai J, Wu HL, et al. Colorectal cancer screening: comparison of transferrin and immuno fecal occult blood test. World Journal of Gastroenterology. Jun. 7. 2012;18(21):2682-8. KQ2E4. [pmid: 22690078].
225 Hong SN, Sung IK, Kim JH, et al. The Effect of the Bowel Preparation Status on the Risk of Missing Polyp and Adenoma during Screening Colonoscopy: A Tandem Colonoscopic Study. Clinical Endoscopy. Nov. 2012;45(4):404-11. KQ2E4. [pmid: 23251889].
226 Martin Lopez JE, Calvo CB, Lopez RR, et al. Comparison of the accuracy of CT Colonography and colonoscopy in the diagnosis of colorectal cancer. Colorectal Dis. 2013. Dec. 3. KQ2E4. [pmid: 24299052].
227 Castro I, Cubiella J, Rivera C, et al. Fecal immunochemical test accuracy in familial risk colorectal cancer screening. Int J Cancer. 2013. Jul. 1. KQ2E4. [pmid: 23818169].
228 Johnson DA, Barclay RL, Mergener K, et al. Plasma Septin9 versus fecal immunochemical testing for colorectal cancer screening: a prospective multicenter study. PLoS ONE [Electronic Resource]. 2014;9(6):e98238. KQ2E4. [pmid: 24901436].
229 Taylor SA, Halligan S, Saunders BP, et al. Use of multidetector-row CT colonography for detection of colorectal neoplasia in patients referred via the Department of Health “2-Week-wait” initiative. Clin Radiol. Nov. 2003;58(11):855-61. KQ2E4a. [pmid: 14581009].
230 Cotton PB, Durkalski VL, Pineau BC, et al. Computed tomographic colonography (virtual colonoscopy): a multicenter comparison with standard colonoscopy for detection of colorectal neoplasia. JAMA. Apr. 14. 2004;291(14):1713-9. KQ2E4a. [pmid: 15082698].
231 Vogt C, Cohnen M, Beck A, et al. Detection of colorectal polyps by multislice CT colonography with ultra-low-dose technique: comparison with high-resolution videocolonoscopy. Gastrointest Endosc. Aug. 2004;60(2):201-9. KQ2E4a. [pmid: 15278045].
232 Levi Z, Rozen P, Hazazi R, et al. A quantitative immunochemical fecal occult blood test for colorectal neoplasia. Ann Intern Med. Feb. 20. 2007;146(4):244-55. KQ2E4a. [pmid: 17310048].
233 Bose M, Bell J, Jackson L, et al. Virtual vs. optical colonoscopy in symptomatic gastroenterology out-patients: the case for virtual imaging followed by targeted diagnostic or therapeutic colonoscopy. Aliment Pharmacol Ther. Sep. 1. 2007;26(5):727-36. KQ2E4a. [pmid: 17697206].
234 Chaparro SM, del CV, Mate JJ, et al. Computed tomography colonography compared with conventional colonoscopy for the detection of colorectal polyps. Gastroenterol Hepatol. Aug. 2007;30(7):375-80. KQ2E4a. [pmid: 17692193].
235 Florie J, van Gelder RE, Schutter MP, et al. Feasibility study of computed tomography colonography using limited bowel preparation at normal and low-dose levels study. Eur Radiol. Dec. 2007;17(12):3112-22. KQ2E4a. [pmid: 17549490].
236 Taylor SA, Slater A, Burling DN, et al. CT colonography: optimisation, diagnostic performance and patient acceptability of reduced-laxative regimens using barium-based faecal tagging. European Radiology. Jan. 2008;18(1):32-42. KQ2E4a. [pmid: 17404739].
237 Roberts-Thomson IC, Tucker GR, Hewett PJ, et al. Single-center study comparing computed tomography colonography with conventional colonoscopy. World Journal of Gastroenterology. Jan. 21. 2008;14(3):469-73. KQ2E4a. [pmid: 18200672].
238 Jensch S, de Vries AH, Peringa J, et al. CT colonography with limited bowel preparation: performance characteristics in an increased-risk population. Radiology. Apr. 2008;247(1):122-32. KQ2E4a. [pmid: 18292475].
239 Nagata K, Okawa T, Honma A, et al. Full-laxative versus minimum-laxative fecal-tagging CT colonography using 64-detector row CT: prospective blinded comparison of diagnostic performance, tagging quality, and patient acceptance. Academic Radiology. Jul. 2009;16(7):780-9. KQ2E4a. [pmid: 19375954].
240 van den Broek FJ, Fockens P, van ES, et al. Clinical evaluation of endoscopic trimodal imaging for the detection and differentiation of colonic polyps. Clinical Gastroenterology & Hepatology. Mar. 2009;7(3):288-95. KQ2E4a. [pmid: 19168154].
241 White TJ, Avery GR, Kennan N, et al. Virtual colonoscopy vs conventional colonoscopy in patients at high risk of colorectal cancer--a prospective trial of 150 patients. Colorectal Disease. Feb. 2009;11(2):138-45. KQ2E4a. [pmid: 18462241].
242 Gimeno-Garcia AZ, Quintero E, Nicolas-Perez D, et al. Screening for familial colorectal cancer with a sensitive immunochemical fecal occult blood test: a pilot study. European Journal of Gastroenterology & Hepatology. Sep. 2009;21(9):1062-7. KQ2E4a. [pmid: 19307978].
243 Regge D, Laudi C, Galatola G, et al. Diagnostic accuracy of computed tomographic colonography for the detection of advanced neoplasia in individuals at increased risk of colorectal cancer. JAMA. Jun. 17. 2009;301(23):2453-61. KQ2E4a. [pmid: 19531785].
244 Rozen P, Levi Z, Hazazi R, et al. Identification of colorectal adenomas by a quantitative immunochemical faecal occult blood screening test depends on adenoma characteristics, development threshold used and number of tests performed. Alimentary Pharmacology & Therapeutics. Apr. 15. 2009;29(8):906-17. KQ2E4a. [pmid: 19183147].
245 de Vries AH, Jensch S, Liedenbaum MH, et al. Does a computer-aided detection algorithm in a second read paradigm enhance the performance of experienced computed tomography colonography readers in a population of increased risk?. European Radiology. Apr. 2009;19(4):941-50. KQ2E4a. [pmid: 18982331].
246 Rozen P, Levi Z, Hazazi R, et al. Quantitative colonoscopic evaluation of relative efficiencies of an immunochemical faecal occult blood test and a sensitive guaiac test for detecting significant colorectal neoplasms. Alimentary Pharmacology & Therapeutics. Feb. 15. 2009;29(4):450-7. KQ2E4a. [pmid: 19035980].
247 Schonfeld V, Hinzmann S. Missed colonic adenomas in routine primary care endoscopy: a prospective tandem colonoscopy study. Zeitschrift fur Gastroenterologie. Oct. 2010;48(10):1207-10. KQ2E4a. [pmid: 20886425].
248 Horiuchi A, Nakayama Y, Kato N, et al. Hood-assisted colonoscopy is more effective in detection of colorectal adenomas than narrow-band imaging. Clinical Gastroenterology & Hepatology. Apr. 2010;8(4):379-83. KQ2E4a. [pmid: 19716434].
249 Wi JY, Kim SH, Lee JY, et al. Electronic cleansing for CT colonography: does it help CAD software performance in a high-risk population for colorectal cancer?. European Radiology. Aug. 2010;20(8):1905-16. KQ2E4a. [pmid: 20309555].
250 Rozen P, Comaneshter D, Levi Z, et al. Cumulative evaluation of a quantitative immunochemical fecal occult blood test to determine its optimal clinical use. Cancer. May. 1. 2010;116(9):2115-25. KQ2E4a. [pmid: 20186820].
251 Liedenbaum MH, de Vries AH, Gouw CI, et al. CT colonography with minimal bowel preparation: evaluation of tagging quality, patient acceptance and diagnostic accuracy in two iodine-based preparation schemes. European Radiology. Feb. 2010;20(2):367-76. KQ2E4a. [pmid: 19707769].
252 Sofic A, Beslic S, Kocijancic I, et al. CT colonography in detection of colorectal carcinoma. Radiology & Oncology. Mar. 2010;44(1):19-23. KQ2E4a. [pmid: 22933886].
253 Keedy AW, Yee J, Aslam R, et al. Reduced cathartic bowel preparation for CT colonography: prospective comparison of 2-L polyethylene glycol and magnesium citrate. Radiology. Oct. 2011;261(1):156-64. KQ2E4a. [pmid: 21873253].
254 Rozen P, Shabtai EI, Liphshitz I, et al. Risk for colorectal cancer in elderly persons and possible methodologies for their screening. European Journal of Gastroenterology & Hepatology. May. 2011;23(5):431-7. KQ2E4a. [pmid: 21448071].
255 Heresbach D, Djabbari M, Riou F, et al. Accuracy of computed tomographic colonography in a nationwide multicentre trial, and its relation to radiologist expertise. Gut. May. 2011;60(5):658-65. KQ2E4a. [pmid: 21266723].
256 Terhaar sive Droste JS, Oort FA, van der Hulst RW, et al. Higher fecal immunochemical test cutoff levels: lower positivity rates but still acceptable detection rates for early-stage colorectal cancers. Cancer Epidemiology, Biomarkers & Prevention. Feb. 2011;20(2):272-80. KQ2E4a. [pmid: 21135261].
257 Kim JH, Kim YS, Cheon JH, et al. Influence of the insertion time and number of polyps on miss rate in colonoscopy. Scand J Gastroenterol. May. 2011;46(5):634-9. KQ2E4a. [pmid: 21370993].
258 Zhang HM, Guo W, Liu GF, et al. Colonic polyps: application value of computer-aided detection in computed tomographic colonography. Chinese Medical Journal. Feb. 2011;124(3):380-4. KQ2E4a. [pmid: 21362337].
259 Rozen P, Liphshitz I, Barchana M. Follow-up of patients undergoing both semiquantitated immunochemical fecal occult blood and colonoscopy examinations. Eur J Cancer Prev. May. 2012;21(3):247-53. KQ2E4a. [pmid: 21955798].
260 Wong CK, Fedorak RN, Prosser CI, et al. The sensitivity and specificity of guaiac and immunochemical fecal occult blood tests for the detection of advanced colonic adenomas and cancer. International Journal of Colorectal Disease. Dec. 2012;27(12):1657-64. KQ2E4a. [pmid: 22696204].
261 Parente F, Marino B, Ilardo A, et al. A combination of faecal tests for the detection of colon cancer: a new strategy for an appropriate selection of referrals to colonoscopy? A prospective multicentre Italian study. European Journal of Gastroenterology & Hepatology. Oct. 2012;24(10):1145-52. KQ2E4a. [pmid: 22735608].
262 Horiuchi A, Nakayama Y, Kajiyama M, et al. Invasive colorectal cancer within 5 years of negative colonoscopy in a Japanese population. Colorectal Disease. Sep. 2012;14(9):1090-4. KQ2E4a. [pmid: 22107065].
263 Kovarova JT, Zavoral M, Zima T, et al. Improvements in colorectal cancer screening programmes - quantitative immunochemical faecal occult blood testing - how to set the cut-off for a particular population. Biomedical Papers of the Medical Faculty of Palacky University in Olomouc, Czech Republic. Jun. 2012;156(2):143-50. KQ2E4a. [pmid: 22837135].
264 Munroe CA, Lee P, Copland A, et al. A tandem colonoscopy study of adenoma miss rates during endoscopic training: a venture into uncharted territory. Gastrointest Endosc. Mar. 2012;75(3):561-7. KQ2E4a. [pmid: 22341103].
265 Mang T, Bogoni L, Salganicoff M, et al. Computer-aided detection of colorectal polyps in CT colonography with and without fecal tagging: a stand-alone evaluation. Investigative Radiology. Feb. 2012;47(2):99-108. KQ2E4a. [pmid: 21934519].
266 Moore H, Dodd N. Computed tomographic colonography (CTC); colorectal cancer diagnosis with CTC in an Auckland population. Journal of Medical Imaging & Radiation Oncology. Oct. 2013;57(5):572-5. KQ2E4a. [pmid: 24119271].
267 Colvin H, Lukram A, Sohail I, et al. The performance of routine computed tomography for the detection of colorectal cancer. Annals of the Royal College of Surgeons of England. Oct. 2013;95(7):473-6. KQ2E4a. [pmid: 24112491].
268 Randell E, Kennell M, Taher A, et al. Evaluation of Hemo Techt NS-Plus system for use in a province-wide colorectal cancer screening program. Clinical Biochemistry. Mar. 2013;46(4–5):365-8. KQ2E4a. [pmid: 23262404].
269 Ou CH, Kuo FC, Hsu WH, et al. Comparison of the performance of guaiac-based and two immunochemical fecal occult blood tests for identifying advanced colorectal neoplasia in Taiwan. Journal of Digestive Diseases. Sep. 2013;14(9):474-83. KQ2E4a. [pmid: 23701988].
270 Fini L, Laghi L, Hassan C, et al. Noncathartic CT Colonography to Screen for Colorectal Neoplasia in Subjects with a Family History of Colorectal Cancer. Radiology. Nov. 2013;22:130373. KQ2E4a. [pmid: 24475809].
271 Plumb AA, Halligan S, Nickerson C, et al. Use of CT colonography in the English Bowel Cancer Screening Programme. Gut. 2013. Aug. 27. KQ2E4a. [pmid: 23955527].
272 Regge D, Della MP, Galatola G, et al. Efficacy of computer-aided detection as a second reader for 6–9-mm lesions at CT colonography: Multicenter prospective trial. Radiology. 2013;266:168-76. KQ2E4a. [pmid: 23151831].
273 Cubiella J, Castro I, Hernandez V, et al. Characteristics of adenomas detected by fecal immunochemical test in colorectal cancer screening. Cancer Epidemiology, Biomarkers & Prevention. Sep. 2014;23(9):1884-92. KQ2E4a. [pmid: 24962836].
274 Rosenfeld G, Fu YT, Quiney B, et al. Does training and experience influence the accuracy of computed tomography colonography interpretation?. World Journal of Gastroenterology. Feb. 14. 2014;20(6):1574-81. KQ2E4a. [pmid: 24587633].
275 Castro I, Estevez P, Cubiella J, et al. Diagnostic Performance of Fecal Immunochemical Test and Sigmoidoscopy for Advanced Right-Sided Colorectal Neoplasms. Dig Dis Sci. 2014. Nov. 19. KQ2E4a. [pmid: 25407805].
276 Zappa M, Castiglione G, Paci E, et al. Measuring interval cancers in population-based screening using different assays of fecal occult blood testing: the District of Florence experience. Int J Cancer. Apr. 1. 2001;92(1):151-4. KQ2E5. [pmid: 11279619].
277 Grazzini G, Visioli CB, Zorzi M, et al. Immunochemical faecal occult blood test: number of samples and positivity cutoff. What is the best strategy for colorectal cancer screening?. British Journal of Cancer. Jan. 27. 2009;100(2):259-65. KQ2E5. [pmid: 19142185].
278 Zorzi M, Fedato C, Grazzini G, et al. High sensitivity of five colorectal screening programmes with faecal immunochemical test in the Veneto Region, Italy. Gut. Jul. 2011;60(7):944-9. KQ2E5. [pmid: 21193461].
279 Parente F, Marino B, DeVecchi N, et al. Faecal occult blood test-based screening programme with high compliance for colonoscopy has a strong clinical impact on colorectal cancer. British Journal of Surgery. May. 2009;96(5):533-40. KQ2E5, KQ3E5a. [pmid: 19358181].
280 Parente F, Boemo C, Ardizzoia A, et al. Outcomes and cost evaluation of the first two rounds of a colorectal cancer screening program based on immunochemical fecal occult blood test in northern Italy. Eur J Radiol. 2013;45(1):27-34. KQ2E5. [pmid: 23254404].
281 Pickhardt PJ, Nugent PA, Choi JR, et al. Flat colorectal lesions in asymptomatic adults: implications for screening with CT virtual colonoscopy. AJR American journal of roentgenology. Nov. 2004;183(5):1343-7. KQ2E5a. [pmid: 15505301].
282 Pickhardt PJ, Choi JR, Hwang I, et al. Nonadenomatous polyps at CT colonography: prevalence, size distribution, and detection rates. Radiology. Sep. 2004;232(3):784-90. KQ2E5a. [pmid: 15247435].
283 Pickhardt PJ, Choi JR, Nugent PA, et al. The effect of diagnostic confidence on the probability of optical colonoscopic confirmation of potential polyps detected on CT colonography: prospective assessment in 1,339 asymptomatic adults. AJR Am J Roentgenol. Dec. 2004;183(6):1661-5. KQ2E5a. [pmid: 15547207].
284 Kim SH, Lee JM, Eun HW, et al. Two- versus Three-dimensional Colon Evaluation with Recently Developed Virtual Dissection Software for CT Colonography. Radiology. Sep. 2007;244(3):852-64. KQ2E5a. [pmid: 17709833].
285 Pickhardt P, Lee A, Taylor A, et al. Primary 2D versus Primary 3D Polyp Detection at Screening CT Colonography. Am J Roentgenol. Dec. 2007;189(6):1451-6. KQ2E5a. [pmid: 18029884].
286 Sutradhar R, Paszat L, Rabeneck L. Accuracy of CT colonography for colorectal cancer screening. N Engl J Med. Dec. 25. 2008;359(26):2843-4. KQ2E5a. [pmid: 19115493].
287 Juchems MS, Ernst A, Johnson P, et al. Electronic colon-cleansing for CT colonography: diagnostic performance. Abdominal Imaging. May. 2009;34(3):359-64. KQ2E5a. [pmid: 18343970].
288 Van Rossum LG, van Rijn AF, Laheij RJ, et al. Cutoff value determines the performance of a semi-quantitative immunochemical faecal occult blood test in a colorectal cancer screening programme. British Journal of Cancer. Oct. 20. 2009;101(8):1274-81. KQ2E5a. [pmid: 19755997].
289 Fletcher JG, Chen MH, Herman BA, et al. Can radiologist training and testing ensure high performance in CT colonography? Lessons From the National CT Colonography Trial. AJR Am J Roentgenol. Jul. 2010;195(1):117-25. KQ2E5a. [pmid: 20566804].
290 Haug U, Hundt S, Brenner H. Quantitative immunochemical fecal occult blood testing for colorectal adenoma detection: evaluation in the target population of screening and comparison with qualitative tests. Am J Gastroenterol. Mar. 2010;105(3):682-90. KQ2E5a. [pmid: 19953091].
291 Hara AK, Kuo MD, Blevins M, et al. National CT colonography trial (ACRIN 6664): comparison of three full-laxative bowel preparations in more than 2500 average-risk patients. AJR Am J Roentgenol. May. 2011;196(5):1076-82. KQ2E5a. [pmid: 21512073].
292 Hara AK, Blevins M, Chen MH, et al. ACRIN CT colonography trial: does reader’s preference for primary two-dimensional versus primary three-dimensional interpretation affect performance?. Radiology. May. 2011;259(2):435-41. KQ2E5a. [pmid: 21364081].
293 Mang T, Hermosillo G, Wolf M, et al. Time-efficient CT colonography interpretation using an advanced image-gallery-based, computer-aided “first-reader” workflow for the detection of colorectal adenomas. European Radiology. Dec. 2012;22(12):2768-79. KQ2E5a. [pmid: 22903619].
294 Stegeman I, de Wijkerslooth TR, Stoop EM, et al. Risk factors for false positive and for false negative test results in screening with fecal occult blood testing. International Journal of Cancer. Nov. 15. 2013;133(10):2408-14. KQ2E5a. [pmid: 23649826].
295 Tao S, Brenner H. Well adjusted qualitative immunochemical faecal occult blood tests could be a promising alternative for inexpensive, high-quality colorectal cancer screening. Eur J Cancer Prev. Jul. 2013;22(4):305-10. KQ2E5a. [pmid: 23702679].
296 Rex DK, Vining D, Kopecky KK. An initial experience with screening for colon polyps using spiral CT with and without CT colography (virtual colonoscopy). Gastrointest Endosc. Sep. 1999;50(3):309-13. KQ2E6. [pmid: 10462648].
297 Macari M, Milano A, Lavelle M, et al. Comparison of time-efficient CT colonography with two- and three-dimensional colonic evaluation for detecting colorectal polyps. AJR Am J Roentgenol. Jun. 2000;174(6):1543-9. KQ2E6. [pmid: 10845478].
298 Sung JJ, Chan FK, Leung WK, et al. Screening for colorectal cancer in Chinese: comparison of fecal occult blood test, flexible sigmoidoscopy, and colonoscopy. Gastroenterology. Mar. 2003;124(3):608-14. KQ2E6. [pmid: 12612899].
299 Mesihovic R, Vanis N, Gribajcevic M. Test for obscure bleeding vs colonoscopy in the prevention of colorectal cancer. Medicinski Arhiv. 2008;62(3):153-5. KQ2E6. [pmid: 18822943].
300 Brenner H, Hoffmeister M, Birkner B, et al. Diagnostic Performance of Guaiac-Based Fecal Occult Blood Test in Routine Screening: State-Wide Analysis from Bavaria, Germany. Am J Gastroenterol. 2013. Dec. 17. KQ2E6. [pmid: 24343548].
301 Spada C, Hassan C, Barbaro B, et al. Colon capsule versus CT colonography in patients with incomplete colonoscopy: a prospective, comparative trial. Gut. 2014. Jun. 24. KQ2E6. [pmid: 24964317].
302 Nakazato M, Yamano H, Matsushita H, et al. Immunologic fecal occult blood test for colorectal cancer screening. Japan Medical Association Journal. 2006;49(5–6):203-7. PMID: None. KQ2E7.
303 Parra-Blanco A, Gimeno-Garcia AZ, Quintero E, et al. Diagnostic accuracy of immunochemical versus guaiac faecal occult blood tests for colorectal cancer screening. Journal of Gastroenterology. Jul. 2010;45(7):703-12. KQ2E7. [pmid: 20157748].
304 Wong MC, Ching JY, Chan VC, et al. Factors associated with false-positive and false-negative fecal immunochemical test results for colorectal cancer screening. Gastrointest Endosc. 2014. Oct. 4. KQ2E7. [pmid: 25293827].
305 Imperiale TF, Wagner DR, Lin CY, et al. Risk of advanced proximal neoplasms in asymptomatic adults according to the distal colorectal findings. N Engl J Med. Jul. 20. 2000;343(3):169-74. KQ2E8. [pmid: 10900275].
306 Ikeda Y, Mori M, Miyazaki M, et al. Significance of small distal adenoma for detection of proximal neoplasms in the colorectum. Gastrointest Endosc. Sep. 2000;52(3):358-61. KQ2E8. [pmid: 10968850].
307 Lieberman DA, Weiss DG, Bond JH, et al. Use of colonoscopy to screen asymptomatic adults for colorectal cancer. Veterans Affairs Cooperative Study Group 380. N Engl J Med. Jul. 20. 2000;343(3):162-8. KQ2E8. [pmid: 10900274].
308 Imperiale TF, Wagner DR, Lin CY, et al. Using risk for advanced proximal colonic neoplasia to tailor endoscopic screening for colorectal cancer. Ann Intern Med. Dec. 16. 2003;139(12):959-65. KQ2E8. [pmid: 14678915].
309 Anderson JC, Alpern Z, Messina CR, et al. Predictors of proximal neoplasia in patients without distal adenomatous pathology. Am J Gastroenterol. Mar. 2004;99(3):472-7. KQ2E8. [pmid: 15056088].
310 Betes-Ibanez M, Munoz-Navas MA, Duque JM, et al. Diagnostic value of distal colonic polyps for prediction of advanced proximal neoplasia in an average-risk population undergoing screening colonoscopy. Gastrointest Endosc. May. 2004;59(6):634-41. KQ2E8. [pmid: 15114305].
311 Schoenfeld P, Cash B, Flood A, et al. Colonoscopic screening of average-risk women for colorectal neoplasia. N Engl J Med. May. 2005;352(20):2061-8. KQ2E8. [pmid: 15901859].
312 Kato J, Morikawa T, Kuriyama M, et al. Combination of sigmoidoscopy and a fecal immunochemical test to detect proximal colon neoplasia. Clinical Gastroenterology & Hepatology. Dec. 2009;7(12):1341-6. KQ2E8. [pmid: 19426835].
313 Jaboori KA, Domagalski JE, Eckert LD, et al. Colonoscopy by a family physician: detecting proximal neoplasia in asymptomatic adults. Military Medicine. May. 2011;176(5):573-7. KQ2E8, KQ3E5. [pmid: 21634304].
314 Zhu MM, Xu XT, Nie F, et al. Comparison of immunochemical and guaiac-based fecal occult blood test in screening and surveillance for advanced colorectal neoplasms: a meta-analysis. Journal of Digestive Diseases. Jun. 2010;11(3):148-60. KQ2E9. [pmid: 20579218].
315 Haug U, Knudsen AB, Brenner H, et al. Is fecal occult blood testing more sensitive for left- versus right-sided colorectal neoplasia? A systematic literature review. Expert Review of Molecular Diagnostics. Jul. 2011;11(6):605-16. KQ2E9. [pmid: 21745014].
316 de Haan MC, van Gelder RE, Graser A, et al. Diagnostic value of CT-colonography as compared to colonoscopy in an asymptomatic screening population: a meta-analysis. European Radiology. Aug. 2011;21(8):1747-63. KQ2E9. [pmid: 21455818].
317 Lee JK, Liles EG, Bent S, et al. Accuracy of Fecal Immunochemical Tests for Colorectal Cancer Systematic Review and Meta-analysis. Ann Intern Med. Feb. 4. 2014;160(3):171-81. KQ2E9. [pmid: 24658694].
318 Stermer E, Lavy A, Rainis T, et al. Incidental colorectal computed tomography abnormalities: would you send every patient for a colonoscopy?. Canadian Journal of Gastroenterology. Sep. 2008;22(9):758-60. KQ3E1. [pmid: 18818789].
319 Sawhney MS, Salfiti N, Nelson DB, et al. Risk factors for severe delayed postpolypectomy bleeding. Eur J Radiol. Feb. 2008;40(2):115-9. KQ3E1. [pmid: 18253906].
320 Berzin TM, Blanco PG, Lamont JT, et al. Persistent psychological or physical symptoms following endoscopic procedures: an unrecognized post-endoscopy adverse event. Digestive Diseases & Sciences. Oct. 2010;55(10):2869-73. KQ3E1. [pmid: 20393877].
321 Randriamarolahy A, Cucchi JM, Brunner P, et al. Two rare cases of spontaneous splenic rupture. Clinical Imaging. Jul. 2010;34(4):306-8. KQ3E1. [pmid: 20630345].
322 Siewert B, Kruskal JB, Eisenberg R, et al. Quality initiatives: quality improvement grand rounds at Beth Israel Deaconess Medical Center: CT colonography performance review after an adverse event. Radiographics. Jan. 2010;30(1):23-31. KQ3E1. [pmid: 19901086].
323 Ko CW, Dominitz JA, Green P, et al. Accuracy of Medicare claims for identifying findings and procedures performed during colonoscopy. Gastrointest Endosc. Mar. 2011;73(3):447-53. KQ3E1. [pmid: 20950800].
324 Gimeno-Garcia AZ, de Ganzo ZA, Sosa AJ, et al. Incidence and predictors of postpolypectomy bleeding in colorectal polyps larger than 10 mm. European Journal of Gastroenterology & Hepatology. May. 2012;24(5):520-6. KQ3E1. [pmid: 22465971].
325 La TM, Velluti F, Giuliani G, et al. Promptness of diagnosis is the main prognostic factor after colonoscopic perforation. Colorectal Disease. Jan. 2012;14(1):e23-e26. KQ3E1. [pmid: 21831176].
326 Hamilton W, Coleman MG, Rubin G. Colorectal cancer. BMJ. 2013;346:f3172. KQ3E1. [pmid: 23693056].
327 Callejas MF, Errazuriz JI, Castillo F, et al. Incidental venous thromboembolism detected by PET-CT in patients with cancer: prevalence and impact on survival rate. Thrombosis Research. May. 2014;133(5):750-5. KQ3E1. [pmid: 24565275].
328 Neri E, Laghi A, Regge D. Re: Colonic perforation during screening CT colonography using automated CO2 insufflation in an asymptomatic adult. Abdominal Imaging. Nov. 2008;33(6):748-9. KQ3E2. [pmid: 18546033].
329 Liedenbaum MH, Venema HW, Stoker J. Radiation dose in CT colonography--trends in time and differences between daily practice and screening protocols. European Radiology. Oct. 2008;18(10):2222-30. KQ3E2. [pmid: 18491095].
330 Consolo P, Luigiano C, Strangio G, et al. Efficacy, risk factors and complications of endoscopic polypectomy: ten year experience at a single center. World Journal of Gastroenterology. Apr. 21. 2008;14(15):2364-9. KQ3E2. [pmid: 18416463].
331 Berland LL. Incidental extracolonic findings on CT colonography: the impending deluge and its implications. Journal of the American College of Radiology. Jan. 2009;6(1):14-20. KQ3E2. [pmid: 19111266].
332 Araujo SE, Seid VE, Caravatto PP, et al. Incidence and management of colonoscopic colon perforations: 10 years’ experience. Hepatogastroenterology. Nov. 2009;56(96):1633-6. KQ3E2. [pmid: 20214207].
333 Panteris V, Haringsma J, Kuipers EJ. Colonoscopy perforation rate, mechanisms and outcome: from diagnostic to therapeutic colonoscopy. Eur J Radiol. Nov. 2009;41(11):941-51. KQ3E2. [pmid: 19866393].
334 Yee J, Sadda S, Aslam R, et al. Extracolonic findings at CT colonography. Gastrointestinal Endoscopy Clinics of North America. Apr. 2010;20(2):305-22. KQ3E2. [pmid: 20451819].
335 Oka S, Tanaka S, Kanao H, et al. Current status in the occurrence of postoperative bleeding, perforation and residual/local recurrence during colonoscopic treatment in Japan. Digestive Endoscopy. Oct. 2010;22(4):376-80. KQ3E2. [pmid: 21175503].
336 Berrington de GA, Kim KP, Yee J. CT colonography: perforation rates and potential radiation risks. Gastrointestinal Endoscopy Clinics of North America. Apr. 2010;20(2):279-91. KQ3E2. [pmid: 20451817].
337 Berrington de GA, Kim KP, Knudsen AB, et al. Radiation-related cancer risks from CT colonography screening: a risk-benefit analysis. AJR. Apr. American. 2011;(4):816-23. KQ3E2. [pmid: 21427330].
338 ASGE Standards of Practice Committee. Fisher DA, Maple JT, et al. Complications of colonoscopy. Gastrointest Endosc. Oct. 2011;74(4):745-52. KQ3E2. [pmid: 21951473].
339 Ghevariya V, Kevorkian N, Asarian A, et al. Splenic injury from colonoscopy: a review and management guidelines. Southern Medical Journal. Jul. 2011;104(7):515-20. KQ3E2. [pmid: 21886052].
340 Buddingh KT, Herngreen T, Haringsma J, et al. Location in the right hemi-colon is an independent risk factor for delayed post-polypectomy hemorrhage: a multi-center case-control study. Am J Gastroenterol. Jun. 2011;106(6):1119-24. KQ3E2. [pmid: 21266961].
341 Khan JS, Moran BJ. Iatrogenic perforation at colonic imaging. Colorectal Disease. May. 2011;13(5):481-93. KQ3E2. [pmid: 20015266].
342 Kapetanos D, Beltsis A, Chatzimavroudis G, et al. Postpolypectomy bleeding: incidence, risk factors, prevention, and management. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. Apr. 2012;22(2):102-7. KQ3E2. [pmid: 22487620].
343 Sarkar S, Geraghty J, Moore AR, et al. A multicentre study to determine the incidence, demographics, aetiology and outcomes of 6-day emergency readmission following day-case endoscopy. European Journal of Gastroenterology & Hepatology. Dec. 2012;24(12):1438-46. KQ3E2. [pmid: 23114746].
344 DeRoux SJ, Sgarlato A. Upper and lower gastrointestinal endoscopy mortality: the medical examiner’s perspective. Forensic Science, Medicine & Pathology. Mar. 2012;8(1):4-12. KQ3E2. [pmid: 21667169].
345 Raju GS, Vadyala V, Slack R, et al. Adenoma detection in patients undergoing a comprehensive colonoscopy screening. Cancer Medicine. Jun. 2013;2(3):391-402. KQ3E2. [pmid: 23930215].
346 Pendse DA, Taylor SA. Splenic rupture: an uncommon complication after colonoscopy. European Journal of Radiology. Aug. 2013;82(8):1159-65. KQ3E2. [pmid: 22595505].
347 Yao J, Burns JE. Extracolonic findings on CT colonography: does the benefit outweigh the cost?. Academic Radiology. Jun. 2013;20(6):665-6. KQ3E2. [pmid: 23664396].
348 Wu XR, Church JM, Jarrar A, et al. Risk factors for delayed postpolypectomy bleeding: how to minimize your patients’ risk. International Journal of Colorectal Disease. Aug. 2013;28(8):1127-34. KQ3E2. [pmid: 23440363].
349 Gimeno-Garcia AZ, Quintero E. Post-polypectomy complications: high risk in the cecum. Eur J Radiol. Feb. 2014;46(2):88-9. KQ3E2. [pmid: 24477362].
350 Tagg W, Woods S, Razdan R, et al. Hemoperitoneum after colonoscopy. Eur J Radiol. Sep. 2008;40:Suppl-7. KQ3E2c. [pmid: 18633865].
351 Bassett JT, Liotta RA, Barlow D, et al. Colonic perforation during screening CT colonography using automated CO2 insufflation in an asymptomatic adult. Abdominal Imaging. Sep. 2008;33(5):598-600. KQ3E2c. [pmid: 18446401].
352 Ahlawat SK, Charabaty A, Benjamin S. Rectal perforation caused by retroflexion maneuver during colonoscopy: closure with endoscopic clips. Gastrointest Endosc. Apr. 2008;67(4):771-3. KQ3E2c. [pmid: 18206880].
353 Gross RG, Reiter B, Korsten MA. Pyogenic liver abscess complicating colonoscopic polypectomy. Gastrointest Endosc. Apr. 2008;67(4):767-8. KQ3E2c. [pmid: 18155212].
354 Sarhan M, Ramcharan A, Ponnapalli S. Splenic injury after elective colonoscopy. Journal of the Society of Laparoendoscopic Surgeons. Oct. 2009;13(4):616-9. KQ3E2c. [pmid: 20202406].
355 Patselas TN, Gallagher EG. Splenic rupture: an uncommon complication after colonoscopy. American Surgeon. Mar. 2009;75(3):260-1. KQ3E2c. [pmid: 19350865].
356 Lewis SR, Ohio D, Rowley G. Splenic injury as a rare complication of colonoscopy. Emergency Medicine Journal. Feb. 2009;26(2):147. KQ3E2c. [pmid: 19164635].
357 Desai B. Splenic laceration following routine colonoscopy. Southern Medical Journal. Nov. 2010;103(11):1181-3. KQ3E2c. [pmid: 20890252].
358 Hlivko JT, Esber EJ, Porter JA, et al. Small-bowel obstruction precipitated by bowel preparation for screening colonoscopy. Eur J Radiol. 2010;42:Suppl. KQ3E2c. [pmid: 20878603].
359 Gonzalez-Candelas F, Guiral S, Carbo R, et al. Patient-to-patient transmission of hepatitis C virus (HCV) during colonoscopy diagnosis. Virology Journal. 2010;7:217. KQ3E2c. [pmid: 20825635].
360 Alder AC, Scott DL, Browning JD. Colonoscopy: an unusual complication. Gastroenterology. 2010;138(2):434. KQ3E2c. [pmid: 20034601].
361 Pothula A, Lampert J, Mazeh H, et al. Splenic rupture as a complication of colonoscopy: report of a case. Surgery Today. 2010;40(1):68-71. KQ3E2c. [pmid: 20037844].
362 Maddur H, Agrawal S, Fayad N, et al. Acute cholecystitis after colonoscopy: a case series. Gastrointest Endosc. Jul. 2011;74(1):211-3. KQ3E2c. [pmid: 21549374].
363 Langer K, Kriegler S, Moser M. Colonoscopy complicated by arterial avulsion and retroperitoneal hemorrhage. Eur J Radiol. 2011;43:Suppl. KQ3E2c. [pmid: 21590605].
364 Rustagi T. Intestinal obstruction from diaphragmatic hernia following colonoscopy. American Journal of the Medical Sciences. May. 2011;341(5):423-5. KQ3E2c. [pmid: 21358390].
365 Bildzukewicz NA, Weinstein MS. Appendicitis following virtual colonoscopy: a case report. Journal of Gastrointestinal Surgery. Dec. 2012;16(12):2291-3. KQ3E2c. [pmid: 22918862].
366 Cheng YC, Wu CC, Lee CC, et al. Rare complication following screening colonoscopy: ischemic colitis. Digestive Endoscopy. Sep. 2012;24(5):379. KQ3E2c. [pmid: 22925295].
367 Singla S, Keller D, Thirunavukarasu P, et al. Splenic injury during colonoscopy--a complication that warrants urgent attention. Journal of Gastrointestinal Surgery. Jun. 2012;16(6):1225-34. KQ3E2c. [pmid: 22450952].
368 Saludes V, Esteve M, Casas I, et al. Hepatitis C virus transmission during colonoscopy evidenced by phylogenetic analysis. Journal of Clinical Virology. Jul. 2013;57(3):263-6. KQ3E2c. [pmid: 23567025].
369 Lee CK, Shim JJ, Jang JY. Ceco-colic intussusception with subsequent bowel infarction as a rare complication of colonoscopic polypectomy. Eur J Radiol. 2013;45:Suppl-7. KQ3E2c. [pmid: 23526500].
370 Hammadah M, Gaber L, Raghavan R. Renal cortical necrosis following a colonoscopy. Clinical Nephrology. Jan. 2013;79(1):67-71. KQ3E2c. [pmid: 22913920].
371 April MD, Simmons JR, Nielson AS. An unusual cause of postcolonoscopy abdominal pain. American Journal of Emergency Medicine. Jan. 2013;31(1):273-4. KQ3E2c. [pmid: 22795421].
372 Shaw D, Gallardo G, Basson MD. Post-colonoscopy appendicitis: A case report and systematic review. World Journal of Gastrointestinal Surgery. Oct. 27. 2013;5(10):259-63. KQ3E2c. [pmid: 24179623].
373 Yu JY, Kim SK, Jang EC, et al. Boerhaave’s syndrome during bowel preparation with polyethylene glycol in a patient with postpolypectomy bleeding. World Journal of Gastrointestinal Endoscopy. May. 16. 2013;5(5):270-2. KQ3E2c. [pmid: 23678383].
374 Ignjatovic M, Jovic J. Tension pneumothorax, pneumoretroperitoneum, and subcutaneous emphysema after colonoscopic polypectomy: a case report and review of the literature. Langenbecks Archives of Surgery. Jan. 2009;394(1):185-9. KQ3E3a. [pmid: 18283482].
375 Aswakul P, Prachayakul V, Lohsiriwat V, et al. Screening colonoscopy from a large single center of Thailand - something needs to be changed?. Asian Pacific Journal of Cancer Prevention: Apjcp. 2012;13(4):1361-4. KQ3E3a. [pmid: 22799332].
376 Rogge JD, Elmore MF, Mahoney SJ, et al. Low-cost, office-based, screening colonoscopy. Am J Gastroenterol. Oct. 1994;89(10):1775-80. KQ3E4. [pmid: 7942665].
377 Newcomer MK, Shaw MJ, Williams DM, et al. Unplanned work absence following outpatient colonoscopy. J Clin Gastroenterol. Jul. 1999;29(1):76-8. KQ3E4. [pmid: 10405238].
378 Dafnis G, Ekbom A, Pahlman L, et al. Complications of diagnostic and therapeutic colonoscopy within a defined population in Sweden. Gastrointest Endosc. Sep. 2001;54(3):302-9. KQ3E4. [pmid: 11522969].
379 Edwards JK, Norris TE. Colonoscopy in rural communities: can family physicians perform the procedure with safe and efficacious results?. J Am Board Fam Pract. Sep. 2004;17(5):353-8. KQ3E4. [pmid: 15355949].
380 Syn WK, Tandon U, Ahmed MM. Colonoscopy in the very elderly is safe and worthwhile. Age Ageing. Sep. 2005;34(5):510-3. KQ3E4. [pmid: 16107458].
381 Newman RJ, Nichols DB, Cummings DM. Outpatient colonoscopy by rural family physicians. Ann Fam Med. Mar. 2005;3(2):122-5. KQ3E4. [pmid: 15798037].
382 Lee YC, Wang HP, Chiu HM, et al. Factors determining post-colonoscopy abdominal pain: prospective study of screening colonoscopy in 1000 subjects. Journal of Gastroenterology & Hepatology. 2006;21(10):1575-80. Oct. KQ3E4. [pmid: 16928219].
383 Duncan JE, Sweeney WB, Trudel JL, et al. Colonoscopy in the elderly: low risk, low yield in asymptomatic patients. Dis Colon Rectum. May. 2006;49(5):646-51. KQ3E4. [pmid: 16482421].
384 Russmann S, Lamerato L, Marfatia A, et al. Risk of impaired renal function after colonoscopy: a cohort study in patients receiving either oral sodium phosphate or polyethylene glycol. Am J Gastroenterol. Dec. 2007;102(12):2655-63. KQ3E4. [pmid: 17970832].
385 Guerra JF, San FI, Pimentel F, et al. Splenic rupture following colonoscopy. World Journal of Gastroenterology. Nov. 7. 2008;14(41):6410-2. KQ3E4. [pmid: 19009661].
386 Ballas KD, Rafailidis SF, Triantaphyllou A, et al. Retroperitoneal, mediastinal, and subcutaneous emphysema, complicating colonoscopy and rectal polypectomy. Journal of Laparoendoscopic & Advanced Surgical Techniques. Oct. 2008;(Part(5)):717-20. KQ3E4. [pmid: 18803515].
387 Hough DM, Kuntz MA, Fidler JL, et al. Detection of occult colonic perforation before CT colonography after incomplete colonoscopy: perforation rate and use of a low-dose diagnostic scan before CO2 insufflation. AJR. Oct. American. 2008;(4):1077-81. KQ3E4. [pmid: 18806146].
388 Michail O, Griniatsos J, Daskalaki M, et al. Two cases of cervical emphysema after colonoscopy. Eur J Radiol. Sep. 2008;40:Suppl-2. KQ3E4. [pmid: 18668467].
389 Saad A, Rex DK. Colonoscopy-induced splenic injury: report of 3 cases and literature review. Digestive Diseases & Sciences. Apr. 2008;53(4):892-8. KQ3E4. [pmid: 17934832].
390 Pasumarthy L, Srour J, Johnson D. Jejunal Perforation following Screening Colonoscopy. Case Reports Gastroenterology. 2008;2(2):187-90. KQ3E4. [pmid: 21490886].
391 Ha JF, Minchin D. Splenic injury in colonoscopy: a review. International Journal Of Surgery. Oct. 2009;7(5):424-7. KQ3E4. [pmid: 19638324].
392 Uraoka T, Kato J, Kuriyama M, et al. CO(2) insufflation for potentially difficult colonoscopies: efficacy when used by less experienced colonoscopists. World Journal of Gastroenterology. Nov. 7. 2009;15(41):5186-92. KQ3E4. [pmid: 19891018].
393 Chalumeau C, Facy O, Radais F, et al. Colonoscopy-related esophageal perforation: report of two cases. Eur J Radiol. 2009;41:Suppl. KQ3E4. [pmid: 19866419].
394 Dellon ES, Lippmann QK, Galanko JA, et al. Effect of GI endoscopy nurse experience on screening colonoscopy outcomes. Gastrointest Endosc. Aug. 2009;70(2):331-43. KQ3E4. [pmid: 19500788].
395 Bechtold ML, Hammad HT, Arif M, et al. Perforation upon retroflexion: an endoscopic complication and repair. Eur J Radiol. 2009;41:Suppl-6. KQ3E4. [pmid: 19544277].
396 Rao KV, Beri GD, Sterling MJ, et al. Splenic injury as a complication of colonoscopy: a case series. Am J Gastroenterol. Jun. 2009;104(6):1604-5. KQ3E4. [pmid: 19491881].
397 Ranganath R, Selinger S. An uncommon complication of a common procedure. Postgraduate Medical Journal. Apr. 2009;85(1002):224. KQ3E4. [pmid: 19417175].
398 Nguyen HD, Borum ML. Acute hepatitis in a patient given propofol during colonoscopy. Southern Medical Journal. Mar. 2009;102(3):333-4. KQ3E4. [pmid: 19204630].
399 Kimberly JR, Phillips KC, Santago P, et al. Extracolonic findings at virtual colonoscopy: an important consideration in asymptomatic colorectal cancer screening. Journal of General Internal Medicine. Jan. 2009;24(1):69-73. KQ3E4. [pmid: 18958531].
400 Mai CM, Wen CC, Wen SH, et al. Iatrogenic colonic perforation by colonoscopy: a fatal complication for patients with a high anesthetic risk. International Journal of Colorectal Disease. Apr. 2010;25(4):449-54. KQ3E4. [pmid: 19855987].
401 Kipple JC. Bilateral tension pneumothoraces and subcutaneous emphysema following colonoscopic polypectomy: a case report and discussion of anesthesia considerations. AANA Journal. Dec. 2010;78(6):462-7. KQ3E4. [pmid: 21309293].
402 Michetti CP, Smeltzer E, Fakhry SM. Splenic injury due to colonoscopy: analysis of the world literature, a new case report, and recommendations for management. American Surgeon. Nov. 2010;76(11):1198-204. KQ3E4. [pmid: 21140684].
403 Theodoropoulos J, Krecioch P, Myrick S, et al. Delayed presentation of a splenic injury after colonoscopy: a diagnostic challenge. International Journal of Colorectal Disease. Aug. 2010;25(8):1033-4. KQ3E4. [pmid: 20217421].
404 Tribonias G, Konstantinidis K, Theodoropoulou A, et al. Rectal perforation caused by colonoscopic retroflexion. Gastrointest Endosc. Mar. 2010;71(3):662. KQ3E4. [pmid: 20189536].
405 Sheikh A, Watt J, Tee M, et al. Appendicitis as a complication of colonoscopy. Journal of Surgical Case Reports. 2010;2010(9):1. KQ3E4. [pmid: 24946353].
406 Akhtar AJ, Padda MS. Safety and efficacy of colonoscopy in the elderly: experience in an innercity community hospital serving African American and Hispanic patients. Ethnicity & Disease. 2011;21(4):412-4. KQ3E4. [pmid: 22428343].
407 Khan S, Ahmed J, Lim M, et al. Colonoscopy in the octogenarian population: diagnostic and survival outcomes from a large series of patients. Surgeon Journal of the Royal Colleges of Surgeons of Edinburgh & Ireland. Aug. 2011;9(4):195-9. KQ3E4. [pmid: 21672659].
408 Wu AY, Oestreicher JH. Endogenous bacterial endophthalmitis after routine colonoscopy. Canadian Journal of Ophthalmology. Dec. 2011;46(6):556-7. KQ3E4. [pmid: 22153651].
409 Fishback SJ, Pickhardt PJ, Bhalla S, et al. Delayed presentation of splenic rupture following colonoscopy: clinical and CT findings. Emergency Radiology. Dec. 2011;18(6):539-44. KQ3E4. [pmid: 21887533].
410 Sutherland T, Coyle E, Lui B, et al. Extracolonic findings at CT colonography: a review of 258 consecutive cases. Journal of Medical Imaging & Radiation Oncology. Apr. 2011;55(2):149-52. KQ3E4. [pmid: 21501403].
411 Hasan AG, Brown WR. Colonic cleansing for colonoscopy: a risk to be taken seriously. Gastrointest Endosc. Mar. 2011;73(3):616-8. KQ3E4. [pmid: 21353860].
412 Emmanouilidis N, Jager MD, Winkler M, et al. Boerhaave syndrome as a complication of colonoscopy preparation: a case report. Journal of Medical Case Reports [Electronic Resource]. 2011;5:544. KQ3E4. [pmid: 22054124].
413 Azzopardi J, DeWitt DE. Quality and safety issues in procedural rural practice: a prospective evaluation of current quality and safety guidelines in 3000 colonoscopies. Rural & Remote Health. 2012;12:1949. KQ3E4. [pmid: 22985075].
414 Matharoo GS, Goldfarb MA. Treatment and outcomes of iatrogenic colon perforations at a community teaching hospital. American Surgeon. Sep. 2012;78(9):975-8. KQ3E4. [pmid: 22964207].
415 Hagel AF, Boxberger F, Dauth W, et al. Colonoscopy-associated perforation: a 7-year survey of in-hospital frequency, treatment and outcome in a German university hospital. Colorectal Disease. Sep. 2012;14(9):1121-5. KQ3E4. [pmid: 22122526].
416 Buchner AM, Guarner-Argente C, Ginsberg GG. Outcomes of EMR of defiant colorectal lesions directed to an endoscopy referral center. Gastrointest Endosc. Aug. 2012;76(2):255-63. KQ3E4. [pmid: 22657404].
417 DeMuro JP. Incarcerated spigelian hernia after colonoscopy. American Surgeon. May. 2012;78(5):E260-E261. KQ3E4. [pmid: 22691321].
418 Villafanez-Garcia MC, San Gil JG, Ortega-Abengozar H, et al. Massive pneumoperitoneum after colonoscopy. Journal of Emergency Medicine. Jan. 2012;42(1):58-9. KQ3E4. [pmid: 19828276].
419 Wernli KJ, Rutter CM, Dachman AH, et al. Suspected extracolonic neoplasms detected on CT colonography: literature review and possible outcomes. [Review]. Academic Radiology. Jun. 2013;20(6):667-74. KQ3E4. [pmid: 23465379].
420 Randall JK, Good CS, Gilbert JM. 22-year longitudinal study of repetitive colonoscopy in patients with a family history of colorectal cancer. Annals of the Royal College of Surgeons of England. Nov. 2013;95(8):586-90. KQ3E4. [pmid: 24165342].
421 Pineda L, Sarhan M, Suman P, et al. Splenic rupture after screening colonoscopy. American Surgeon. Jan. 2013;79(1):E43-E44. KQ3E4. [pmid: 23317606].
422 Okholm C, Hadikhadem T, Andersen LT, et al. No increased risk of perforation during colonoscopy in patients undergoing Nurse Administered Propofol Sedation. Scand J Gastroenterol. Nov. 2013;48(11):1333-8. KQ3E4. [pmid: 24063514].
423 Kotwal VS, Attar BM, Carballo MD, et al. Morning-only polyethylene glycol is noninferior but less preferred by hospitalized patients as compared with split-dose bowel preparation. Journal of Clinical Gastroenterology. 2014;48:414-8. KQ3E4. [pmid: 24406474].
424 Pierzchajlo RP, Ackermann RJ, Vogel RL. Colonoscopy performed by a family physician. A case series of 751 procedures. J Fam Pract. May. 1997;44(5):473-80. KQ3E4a. [pmid: 9152265].
425 Xiong T, Richardson M, Woodroffe R, et al. Incidental lesions found on CT colonography: their nature and frequency. Br J Radiol. Jan. 2005;78(925):22-9. KQ3E4a. [pmid: 15673525].
426 Paspatis GA, Vardas E, Theodoropoulou A, et al. Complications of colonoscopy in a large public county hospital in Greece. A 10-year study. Digestive & Liver Disease. Dec. 2008;40(12):951-7. KQ3E4a. [pmid: 18417433].
427 Baudet JS, Diaz-Bethencourt D, Arguinarena X, et al. Cat scratch colon is caused by barotrauma secondary to insufflation during colonoscopy. Eur J Radiol. Oct. 2008;40(10):878-9. KQ3E4a. [pmid: 18828090].
428 Avgerinos DV, Llaguna OH, Lo AY, et al. Evolving management of colonoscopic perforations. Journal of Gastrointestinal Surgery. Oct. 2008;12(10):1783-9. KQ3E4a. [pmid: 18683006].
429 Alabraba E, Gourevitch D, Hejmadi R, et al. Post-colonoscopy tension pneumothorax resulting from colonic barotrauma in a previously unrecognised left-sided diaphragmatic hernia. Eur J Radiol. Sep. 2008;40:Suppl-9. KQ3E4a. [pmid: 18633881].
430 Yuksel O, Bolat AD, Koklu S, et al. Ischemic colitis, an unusual complication of colonoscopy. Southern Medical Journal. Sep. 2008;101(9):972-3. KQ3E4a. [pmid: 18708963].
431 Famularo G, Minisola G, De SC. Rupture of the spleen after colonoscopy: a life-threatening complication. American Journal of Emergency Medicine. Sep. 2008;26(7):834. KQ3E4a. [pmid: 18774051].
432 Atiq M, Aduli F, Refai W, et al. Postpolypectomy acute colonic pseudo-obstruction (Ogilvie’s syndrome). Eur J Radiol. Sep. 2008;40:Suppl. KQ3E4a. [pmid: 18668452].
433 Sohns C, Heuser M, Sossalla S, et al. Current role and future potential of computed tomographic colonography for colorectal polyp detection and colon cancer screening-incidental findings. Clinical Imaging. Jul. 2008;32(4):280-6. KQ3E4a. [pmid: 18603183].
434 Siddiki H, Fletcher JG, McFarland B, et al. Incidental findings in CT colonography: literature review and survey of current research practice. Journal of Law, Medicine & Ethics. 2008;36(2):320-31. KQ3E4a. [pmid: 18547201].
435 Parker WT, Edwards MA, Bittner JG, et al. Splenic hemorrhage: an unexpected complication after colonoscopy. American Surgeon. May. 2008;74(5):450-2. KQ3E4a. [pmid: 18481509].
436 Tominaga K, Shigiyama F, Ito S, et al. Emergence of “cat scratch colon” during a colonoscopy. Eur J Radiol. Apr. 2008;40(4):353. KQ3E4a. [pmid: 18389454].
437 Ugajin T, Miyatani H, Momomura S, et al. Ventricular fibrillation during colonoscopy: a case report--colonoscopy in high-risk patients should be performed with ECG monitoring. Internal Medicine. 2008;47(7):609-12. KQ3E4a. [pmid: 18379145].
438 Petersen CR, Adamsen S, Gocht-Jensen P, et al. Splenic injury after colonoscopy. Eur J Radiol. Jan. 2008;40(1):76-9. KQ3E4a. [pmid: 18058621].
439 Quer J, Esteban JI, Sanchez JM, et al. Nosocomial transmission of hepatitis C virus during contrast-enhanced computed tomography scanning. European Journal of Gastroenterology & Hepatology. Jan. 2008;20(1):73-8. KQ3E4a. [pmid: 18090995].
440 Duarte CG. Splenic rupture after colonoscopy. American Journal of Emergency Medicine. Jan. 2008;26(1):117-3. KQ3E4a. [pmid: 18082812].
441 Hunter IA, Sarkar R, Smith AM. Small bowel obstruction complicating colonoscopy: a case report. Journal of Medical Case Reports [Electronic Resource]. 2008;2:179. KQ3E4a. [pmid: 18505563].
442 Cappellani A, Di VM, Zanghi A, et al. Splenic rupture after colonoscopy: Report of a case and review of literature. World Journal Of Emergency Surgery. 2008;3:8. KQ3E4a. [pmid: 18261241].
443 Skipworth JR, Raptis DA, Rawal JS, et al. Splenic injury following colonoscopy--an underdiagnosed, but soon to increase, phenomenon?. Annals of the Royal College of Surgeons of England. May. 2009;91(4):W6-11. KQ3E4a. [pmid: 19416579].
444 Park SK, Park DI, Lee SY, et al. Extracolonic findings of computed tomographic colonography in Koreans. World Journal of Gastroenterology. Mar. 28. 2009;15(12):1487-92. KQ3E4a. [pmid: 19322923].
445 Kolber M, Szafran O, Suwal J, et al. Outcomes of 1949 endoscopic procedures: performed by a Canadian rural family physician. Can Fam Physician. Feb. 2009;55(2):170-5. KQ3E4a. [pmid: 19221080].
446 Beetham M, Khan MI. Incarceration of an umbilical hernia following colonoscopy. New Zealand Medical Journal. Dec. 11. 2009;122(1307):97-9. KQ3E4a. [pmid: 20148050].
447 Atalla MA, Rozen WM, Master M, et al. Education and Imaging. Colonic perforation during ‘virtual’ CT colonography. Journal of Gastroenterology & Hepatology. Nov. 2009;24(11):1800. KQ3E4a. [pmid: 20136963].
448 Witt DM, Delate T, McCool KH, et al. Incidence and predictors of bleeding or thrombosis after polypectomy in patients receiving and not receiving anticoagulation therapy. Journal of Thrombosis & Haemostasis. Dec. 2009;7(12):1982-9. KQ3E4a. [pmid: 19719825].
449 Ho JM, Cavalcanti RB. A shocking bowel preparation: severe electrolyte disturbances after polyethylene glycol-based bowel preparation. Journal of the American Geriatrics Society. Sep. 2009;57(9):1729-30. KQ3E4a. [pmid: 19895448].
450 de VJ, Ronnen HR, Oomen AP, et al. Splenic rupture following colonoscopy, a rare complication. Netherlands Journal of Medicine. Jun. 2009;67(6):230-3. KQ3E4a. [pmid: 19749393].
451 Younes NA, Al-Ardah MI, Daradkeh SS. Rupture of spleen post colonoscopy. Saudi Medical Journal. Aug. 2009;30(8):1095-7. KQ3E4a. [pmid: 19668895].
452 Dong Q, Wang Q, Li Y. Ischemic colitis after colonoscopy in a female patient. Am J Gastroenterol. Aug. 2009;104(8):2123-4. KQ3E4a. [pmid: 19455113].
453 Kume K, Yoshikawa I, Harada M. A rare complication: incarceration of a colonoscope in an inguinal hernia. Eur J Radiol. 2009;41:Suppl. KQ3E4a. [pmid: 19629941].
454 Kiosoglous AJ, Varghese R, Memon MA. Splenic rupture after colonoscopy: a case report. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. Jun. 2009;19(3):e104-e105. KQ3E4a. [pmid: 19542830].
455 Fazeli MS, Keramati MR, Lebaschi AH, et al. Extensive subcutaneous emphysema due to colonic perforation following colonoscopy. Jcpsp, Journal of the College of Physicians & Surgeons - Pakistan. Jun. 2009;19(6):383-5. KQ3E4a. [pmid: 19486580].
456 Nogales RO, Yepes BI, Hernando AA, et al. Large intramural colonic hematoma after polypectomy. Eur J Radiol. 2009;41:Suppl. KQ3E4a. [pmid: 19177292].
457 Exbrayat C, Poncet F, Billette dV, et al. Colonoscopy practices, and colorectal cancer and polyp screening, as assessed in the French district of Isere from May to July in 2004. Gastroenterologie Clinique et Biologique. Dec. 2010;34(12):702-11. KQ3E4a. [pmid: 20970271].
458 Hardy D, Roach M. Hemothorax and splenic hematoma as complications of colonoscopy. American Surgeon. Jun. 2010;76(6):E39-E40. KQ3E4a. [pmid: 21418762].
459 Hutchinson B, Heeney A, Conneely J, et al. Splenic laceration following colonoscopy. Irish Journal of Medical Science. Dec. 2010;179(4):633-4. KQ3E4a. [pmid: 20865345].
460 Fortea JI, Marin JI, Nogales RO, et al. Postcolonic polypectomy pancreatitis. Eur J Radiol. 2010;42:Suppl-2. KQ3E4a. [pmid: 20931450].
461 Sekino Y, Fujisawa N, Suzuki K, et al. A case of recurrent infective endocarditis following colonoscopy. Eur J Radiol. 2010;42:Suppl. KQ3E4a. [pmid: 20845280].
462 Moorman ML, Miller JP, Khanduja KS, et al. Postcolonoscopy appendicitis. American Surgeon. Aug. 2010;76(8):892-5. KQ3E4a. [pmid: 20726424].
463 Murariu D, Takekawa S, Furumoto N. Splenic rupture: a case of massive hemoperitoneum following therapeutic colonoscopy. Hawaii Medical Journal. Jun. 2010;69(6):140-1. KQ3E4a. [pmid: 20535686].
464 D’Ovidio V, Di CM, Pimpo MT, et al. An unusual complicated polypectomy and inverted colonic diverticula. Colorectal Disease. May. 2010;12(5):491-2. KQ3E4a. [pmid: 19486101].
465 DuCoin C, Acholonu E, Ukleja A, et al. Splenic rupture after screening colonoscopy: case report and literature review. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. Feb. 2010;20(1):e31-e33. KQ3E4a. [pmid: 20173607].
466 Lee KJ, Ehrenpreis ED, Greenberg J, et al. Mesenteric panniculitis following colonoscopy, polypectomy, and epinephrine injection. Eur J Radiol. 2010;42:Suppl-5. KQ3E4a. [pmid: 20157883].
467 Sullivan JL, Maxwell PJ, Kastenberg DM, et al. Rectal perforation by retroflexion of the colonoscope managed by endoclip closure. American Surgeon. Jan. 2010;76(1):108-10. KQ3E4a. [pmid: 20135951].
468 Niv Y, Gershtansky Y, Kenett RS, et al. Complications in colonoscopy: analysis of 7-year physician-reported adverse events. European Journal of Gastroenterology & Hepatology. Jun. 2011;23(6):492-8. KQ3E4a. [pmid: 21537124].
469 Ahlawat SK, Gupta N, Benjamin SB, et al. Large colorectal polyps: endoscopic management and rate of malignancy: does size matter?. Journal of Clinical Gastroenterology. Apr. 2011;45(4):347-54. KQ3E4a. [pmid: 20871408].
470 Tung LM, Co CS, Cheung HY, et al. A case report of small bowel perforation at colonoscopy. Asian Journal of Endoscopic Surgery. Nov. 2011;4(4):171-3. KQ3E4a. [pmid: 22776302].
471 Dumoulin FL, Textor J. An unusual presentation of a typical complication after endoscopic polypectomy. BMJ Case Reports. 2011;2011:2011. KQ3E4a. [pmid: 22679055].
472 Penkov P. Acute appendicitis following colonoscopy: causality or coincidence. ANZ Journal of Surgery. Jun. 2011;81(6):491-2. KQ3E4a. [pmid: 22295367].
473 Shih HY, Wu DC, Huang WT, et al. Glutaraldehyde-induced colitis: case reports and literature review. Kaohsiung Journal of Medical Sciences. Dec. 2011;27(12):577-80. KQ3E4a. [pmid: 22208542].
474 Peterlejtner T, Szewczyk T, Buczynska E, et al. Colonoscopic polypectomy--evaluation of the effectiveness and safety (single center experience). Polski Przeglad Chirurgiczny. Aug. 2011;83(8):438-42. KQ3E4a. [pmid: 22166717].
475 Khashram M, Frizelle FA. Colonoscopy--a rare cause of pancreatitis. New Zealand Medical Journal. Nov. 4. 2011;124(1345):74-6. KQ3E4a. [pmid: 22072170].
476 Hong KD, Lee SI, Moon HY. Rectal diverticular perforation complicating diagnostic colonoscopy: a case report and review of the literature. Journal of Laparoendoscopic & Advanced Surgical Techniques. Oct. 2011;(Part(8)):745-8. KQ3E4a. [pmid: 21819215].
477 Kocak E, Ergul B, Koklu S, et al. Abundant intraperitoneal bleeding after colonoscopy. Clinics & Research in Hepatology & Gastroenterology. Sep. 2011;35(8–9):599-600. KQ3E4a. [pmid: 21659014].
478 Singh-Ranger G, Halls A, Grundy A, et al. An unusual case of severe colitis after colonoscopy. Journal of Crohn’s & colitis. Jun. 2011;5(3):267-8. KQ3E4a. [pmid: 21575897].
479 Aslinia FM, Von Rosenvinge EC. Case report: colonoscopy-associated splenic injury in a 56-year-old woman. American Family Physician. Apr. 1. 2011;83(7):786. KQ3E4a. [pmid: 21524041].
480 Nguyen AB, Lee PC, Paul S. Crepitus: an uncommon complication of a common procedure. Annals of Thoracic Surgery. Apr. 2011;91(4):e63. KQ3E4a. [pmid: 21440112].
481 Alcaide N, Atienza R, Barrio J, et al. Hemoperitoneum caused by hemorrhage of tubal vessels, a previously undescribed complication of colonoscopy. Eur J Radiol. 2011;43:Suppl. KQ3E4a. [pmid: 21425027].
482 Meier RP, Toso C, Volonte F, et al. Splenic rupture after colonoscopy. American Journal of Emergency Medicine. Feb. 2011;29(2):241-2. KQ3E4a. [pmid: 20825894].
483 Seddik H, Rabhi M. Two cases of appendiceal intussusception: a rare diagnostic pitfall in colonoscopy. Diagnostic & Therapeutic Endoscopy. 2011;2011:198984. KQ3E4a. [pmid: 21603019].
484 Kim dH, Lim SW. Analysis of delayed postpolypectomy bleeding in a colorectal clinic. Journal of the Korean Society of Coloproctology. Feb. 2011;27(1):13-6. KQ3E4a. [pmid: 21431091].
485 Sewitch MJ, Jiang M, Joseph L, et al. Rate of serious complications of colonoscopy in Quebec. Canadian Journal of Gastroenterology. Sep. 2012;26(9):611-3. KQ3E4a. [pmid: 22993732].
486 Beitz A, Riphaus A, Meining A, et al. Capnographic monitoring reduces the incidence of arterial oxygen desaturation and hypoxemia during propofol sedation for colonoscopy: a randomized, controlled study (ColoCap Study). Am J Gastroenterol. Aug. 2012;107(8):1205-12. KQ3E4a. [pmid: 22641306].
487 Lee TJ, Rutter MD, Blanks RG, et al. Colonoscopy quality measures: experience from the NHS Bowel Cancer Screening Programme. Gut. Jul. 2012;61(7):1050-7. KQ3E4a. [pmid: 21940723].
488 Repici A, Hassan C, Vitetta E, et al. Safety of cold polypectomy for <10mm polyps at colonoscopy: a prospective multicenter study. Eur J Radiol. Jan. 2012;44(1):27-31. KQ3E4a. [pmid: 22125197].
489 Carey JL, Napoli AM. Tension pneumoperitoneum during routine colonoscopy. American Journal of Emergency Medicine. Jan. 2012;30(1):261-2. KQ3E4a. [pmid: 21185666].
490 Loffeld RJ, Liberov B, Dekkers PE. Incidence and causes of colonoscopic perforations: a single-center case series. Geriatrics & gerontology international. Apr. 2012;12(2):298-303. KQ3E4a. [pmid: 22050603].
491 Alcaide N, Diez-Redondo P, Herranz-Bachiller MT, et al. Serosal lacerations during colonoscopy - a rare complication. Eur J Radiol. 2012;44:Suppl. KQ3E4a. [pmid: 22814914].
492 Yin AX, Park GH, Garnett GM, et al. Chilaiditi syndrome precipitated by colonoscopy: a case report and review of the literature. Hawai’i Journal of Medicine & Public Health : A Journal of Asia Pacific Medicine & Public Health. Jun. 2012;71(6):158-62. KQ3E4a. [pmid: 22787564].
493 Moore H, Dodd N. Computed tomographic colonography: colonic and extracolonic findings in an Auckland population. New Zealand Medical Journal. Jun. 8. 2012;125(1356):68-74. KQ3E4a. [pmid: 22729061].
494 Lasithiotakis K, Grisbolaki E, Filis D, et al. Ileocolic intussusception precipitated by diagnostic colonoscopy: a case report. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. Jun. 2012;22(3):e161-e163. KQ3E4a. [pmid: 22678343].
495 Lucendo AJ, Olveira A, Friginal-Ruiz AB, et al. Nonanesthesiologist-administered propofol sedation for colonoscopy is safe and effective: a prospective Spanish study over 1000 consecutive exams. European Journal of Gastroenterology & Hepatology. Jul. 2012;24(7):787-92. KQ3E4a. [pmid: 22517241].
496 Niv Y, Bogolavski I, Ilani S, et al. Impact of colonoscopy on quality of life. European Journal of Gastroenterology & Hepatology. Jul. 2012;24(7):781-6. KQ3E4a. [pmid: 22441512].
497 De JV, Sint NJ, van BO, et al. The incidence of 30-day adverse events after colonoscopy among outpatients in the Netherlands. Am J Gastroenterol. Jun. 2012;107(6):878-84. KQ3E4a. [pmid: 22391645].
498 Tang RS, Hunt GC. Recurrent pneumothoraces after diagnostic colonoscopy. Gastroenterology. May. 2012;142(5):e9-e10. KQ3E4a. [pmid: 22449583].
499 Zandona C, Turrina S, Pasin N, et al. Medico-legal considerations in a case of splenic injury that occurred during colonoscopy. Journal of Forensic & Legal Medicine. May. 2012;19(4):229-33. KQ3E4a. [pmid: 22520377].
500 Sharma G, Boopathy SN, Juneja R, et al. Neurocardiogenic syncope during a routine colonoscopy: an uncommon malignant presentation. Internal Medicine. 2012;51(8):891-3. KQ3E4a. [pmid: 22504245].
501 Sachdev S, Thangarajah H, Keddington J. Splenic rupture after uncomplicated colonoscopy. American Journal of Emergency Medicine. Mar. 2012;30(3):515-2. KQ3E4a. [pmid: 21450434].
502 Agko M, Gociman B, Keilani ZM, et al. Cecal volvulus: a rare complication of colonoscopy. International Journal of Colorectal Disease. Feb. 2012;27(2):265-6. KQ3E4a. [pmid: 21538052].
503 Nachnani J, Burns E, Margolin D, et al. Colocolonic intussusception after colonoscopy. Gastrointest Endosc. Jan. 2012;75(1):223-5. KQ3E4a. [pmid: 21481863].
504 Sansoni I, Piccolo CL, Di GI, et al. Portomesenteric Venous System Gas after CT Colonography: A Case Report. Case Reports in Radiology. 2012;2012:420901. KQ3E4a. [pmid: 23050186].
505 Falidas E, Anyfantakis G, Vlachos K, et al. Pneumoperitoneum, Retropneumoperitoneum, Pneumomediastinum, and Diffuse Subcutaneous Emphysema following Diagnostic Colonoscopy. Case Reports in Surgery. 2012;2012:108791. KQ3E4a. [pmid: 23024878].
506 Badiani S, Tomas-Hernandez S, Karandikar S, et al. Extracolonic findings (ECF) on CT colonography (CTC) in patients presenting with colorectal symptoms. Acta Radiologica. Oct. 2013;54(8):851-62. KQ3E4a. [pmid: 23761550].
507 Denis B, Gendre I, Sauleau EA, et al. Harms of colonoscopy in a colorectal cancer screening programme with faecal occult blood test: a population-based cohort study. Digestive & Liver Disease. Jun. 2013;45(6):474-80. KQ3E4a. [pmid: 23414583].
508 Pourmand A, Shokoohi H. Tension Pneumothorax, Pneumoperitoneum, and Cervical Emphysema following a Diagnostic Colonoscopy. Case Reports in Emergency Medicine Print. 2013;2013:583287. KQ3E4a. [pmid: 23819071].
509 Gavin DR, Valori RM, Anderson JT, et al. The national colonoscopy audit: a nationwide assessment of the quality and safety of colonoscopy in the UK. [Erratum appears in Gut. 2013 Feb;62(2):249]. Gut. Feb. 2013;62(2):242-9. KQ3E4a. [pmid: 22661458].
510 Denadai R, Medeiros CC, Toledo AP, et al. Rectal perforation after colonoscopic polypectomy presented as subcutaneous emphysema, pneumomediastinum and pneumoretroperitoneum successfully treated conservatively in an elderly adult. Journal of the American Geriatrics Society. Aug. 2013;61(8):1433-5. KQ3E4a. [pmid: 23937504].
511 Singhal S, Changela K, Momeni M, et al. Outcome and safety of colonoscopy in minorities aged 85 and older. Journal of the American Geriatrics Society. May. 2013;61(5):832-4. KQ3E4a. [pmid: 23672553].
512 Blumenstein I, Tacke W, Bock H, et al. Prevalence of colorectal cancer and its precursor lesions in symptomatic and asymptomatic patients undergoing total colonoscopy: results of a large prospective, multicenter, controlled endoscopy study. European Journal of Gastroenterology & Hepatology. May. 2013;25(5):556-61. KQ3E4a. [pmid: 23283303].
513 Sopena-Falco J, Poch-Vall N, Brullet E, et al. Fatal massive air embolism following diagnostic colonoscopy. Eur J Radiol. 2013;45:Suppl. KQ3E4a. [pmid: 23526536].
514 Noordzij W, Slart RH, Zeebregts CJ, et al. Gastrocolocutaneous fistula detected by [8F]fluorodeoxyglucose positron emission tomography with low-dose computed tomography: a rare iatrogenic complication of colonoscopy. Eur J Radiol. 2013;45:Suppl-8. KQ3E4a. [pmid: 23526522].
515 Kim BH, Yoon SJ, Lee JY, et al. Subcutaneous emphysema, pneumomediastinum, pneumoretroperitoneum, and pneumoperitoneum secondary to colonic perforation during colonoscopy. Korean Journal of Anesthesiology. Dec. 2013;65(6:Suppl):Suppl-4. KQ3E4a. [pmid: 24478831].
516 Li Y, Li Q. Diaphragmatic hernia: a rare adverse event of colonoscopy. Eur J Radiol. Nov. 2013;45:Suppl-1. KQ3E4a. [pmid: 24285070].
517 Tan VP, Lee YT, Poon JT. Incarceration of a colonoscope in an inguinal hernia: Case report and literature review. World Journal of Gastrointestinal Endoscopy. Jun. 16. 2013;5(6):304-7. KQ3E4a. [pmid: 23772270].
518 Severe rhabdomyolysis and hyponatremia induced by picosulfate and bisacodyl during the preparation of colonoscopy. Rev Esp Enferm Dig. May. 2013;105(3):180-2. KQ3E4a. [pmid: 23735032].
519 Lin BW, Thanassi W. Tension pneumoperitoneum. Journal of Emergency Medicine. 2014. KQ3E4a. [pmid: 18571362].
520 Taylor T, Williamson S, Wardle J, et al. Acceptability of flexible sigmoidoscopy screening in older adults in the United Kingdom. J Med Screen. 2000;7(1):38-45. KQ3E5. [pmid: 10807146].
521 Brasso K, Ladelund S, Frederiksen BL, et al. Psychological distress following fecal occult blood test in colorectal cancer screening--a population-based study. Scand J Gastroenterol. Oct. 2010;45(10):1211-6. KQ3E5. [pmid: 20443744].
522 Summers RM, Baecher N, Yao J, et al. Feasibility of simultaneous computed tomographic colonography and fully automated bone mineral densitometry in a single examination. Journal of Computer Assisted Tomography. Mar. 2011;35(2):212-6. KQ3E5. [pmid: 21412092].
523 Khalid-de Bakker CA, Jonkers DM, Hameeteman W, et al. Cardiopulmonary events during primary colonoscopy screening in an average risk population. Netherlands Journal of Medicine. Apr. 2011;69(4):186-91. KQ3E5. [pmid: 21527807].
524 Robb KA, Lo SH, Power E, et al. Patient-reported outcomes following flexible sigmoidoscopy screening for colorectal cancer in a demonstration screening programme in the UK. J Med Screen. 2012;19(4):171-6. KQ3E5. [pmid: 23486697].
525 Kilgert B, Rybizki L, Grottke M, et al. Prospective long-term assessment of sedation-related adverse events and patient satisfaction for upper endoscopy and colonoscopy. Digestion. 2014;90(1):42-8. KQ3E5. [pmid: 25139268].
526 Pickhardt P, Bodeen G, Brett A, et al. Comparison of Femoral Neck BMD Evaluation Obtained Using Lunar DXA and QCT With Asynchronous Calibration From CT Colonography. J Clin Densitom. 2014. May. 28. KQ3E5. [pmid: 24880495].
527 Ko CW, Riffle S, Morris CG, et al. Complications after Screening and Surveillance Colonoscopy. Gastroenterology. 2007;132:A149. KQ3E5a.
528 Rabeneck L, Saskin R, Paszat LF. Onset and clinical course of bleeding and perforation after outpatient colonoscopy: a population-based study. Gastrointest Endosc. Mar. 2011;73(3):520-3. KQ3E5a. [pmid: 21195406].
529 Morse JW, Fowler SA, Morse AL. Endoscopist-administered propofol: a retrospective safety study. Canadian Journal of Gastroenterology. Jul. 2008;22(7):617-20. KQ3E6. [pmid: 18629390].
530 Rathore F, Sultan N, Byrne D. Tolerance of colonoscopy and questioning its utility in the elderly population. Irish Medical Journal. Sep. 2014;107(8):247. KQ3E7. [pmid: 25282969].