# Detailed Methods

## Literature Search Strategies for Primary Literature

Key:

/: MeSH subject heading
$: truncation
*: truncation
ab: word in abstract
ae: adverse effects
adj#: adjacent within x number of words
kw: keyword
mo: mortality
nm: name of substance
pt: publication type
ti: word in title

### Cochrane Central Register of Controlled Trials (via Wiley)

#1 (colorectal or colon or colonic or rectal or rectum or rectosigmoid or adenomat*):ti,ab,kw near/3 (cancer* or carcinoma* or adenocarcinoma* or malignan* or tumor* or tumour* or neoplas* or polyp*):ti,ab,kw
#2 screen*:ti,ab,kw or detect*:ti,ab,kw
#3 #1 and #2
#4 colonoscop*:ti,ab,kw
#5 colonograph*:ti,ab,kw
#6 sigmoidoscop*:ti,ab,kw
#7 (fecal or faecal or stool):ti,ab,kw near/5 molecular*:ti,ab,kw
#8 (fecal or faecal or stool):ti,ab,kw near/5 (DNA or "deoxyribonucleic acid"):ti,ab,kw
#9 (f-dna or fdna):ti,ab,kw
#10 (s-dna or sdna):ti,ab,kw
#11 (fecal or faecal or stool):ti,ab,kw near/5 test*:ti,ab,kw
#12 (fecal or faecal or stool):ti,ab,kw near/5 (immunochemical or immunoassay):ti,ab,kw
#13 (fecal or faecal or stool):ti,ab,kw next occult:ti,ab,kw
#14 "occult blood":ti,ab,kw
#15 guaiac:ti,ab,kw
#16 (FOBT or IFOBT):ti,ab,kw
#17 ("SEPTIN 9" or SEPT9 or mSEPT9):ti,ab,kw
#18 #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 from 2008 to 2014, in Trials

### Ovid MEDLINE search strategy

#### KQ1

1. Colonoscopy/
2. colonoscop$.ti,ab.
3. Sigmoidoscopy/
4. sigmoidoscop$.ti,ab.
5. Colonography, Computed Tomographic/
6. colonograph$.ti,ab.
7. Occult Blood/
8. occult blood.ti,ab.
9. ((fecal or faecal or stool) adj occult).ti,ab.
10. (fobt or ifobt or gfobt).ti,ab.
11. guaiac.ti,ab.
12. ((fecal or faecal or stool) adj5 test$).ti,ab.
13. ((fecal or faecal or stool) and (immunochemical or immunoassay)).ti,ab.
14. DNA/
15. DNA Methylation/
16. DNA Mutational Analysis/
17. DNA, neoplasm/
18. 14 or 15 or 16 or 17
19. Feces/
20. 18 and 19
21. ((fecal or faecal or stool) adj5 (DNA or deoxyribonucleic acid)).ti,ab.
22. ((fecal or faecal or stool) adj5 (genetic$ or genomic$)).ti,ab.
23. ((fecal or faecal or stool) adj5 molecular).ti,ab.
24. (f-dna or fdna or s-dna or sdna).ti,ab.
25. "SEPT9 protein, human".nm.
26. Septins/
27. (SEPTIN9 or SEPTIN 9 or SEPT9 or mSEPT9).ti,ab.
28. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27
29. Mass screening/ or "Early Detection of Cancer"/
30. (screen$ or detect$).ti,ab.
31. 29 or 30
32. 28 and 31
33. Colorectal Neoplasms/
34. Adenomatous Polyposis Coli/
35. Colonic Neoplasms/
36. Sigmoid Neoplasms/
37. Colorectal Neoplasms, Hereditary Nonpolyposis/
38. Rectal Neoplasms/
39. Anus Neoplasms/
40. Anal Gland Neoplasms/
41. Colonic Polyps/
42. Adenomatous Polyps/
43. 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42
44. ((colorectal or colon or colonic or rectal or rectum or rectosigmoid$ or adenomat$) adj3 (cancer$ or carcinoma$ or adenocarcinoma$ or malignan$ or tumor$ or tumour$ or neoplas$ or polyp$)).ti,ab.
45. limit 44 to ("in data review" or in process or "pubmed not medline")
46. 43 or 45
47. (screen$ or detect$).ti.
48. 46 and (29 or 47)
49. 32 or 48
50. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (165918)
51. meta-analysis as topic/
52. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
53. control groups/ or double-blind method/ or single-blind method/
54. Random$.ti,ab.
55. clinical trial$.ti,ab.
56. controlled trial$.ti,ab.
57. meta analy$.ti,ab.
58. 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57
59. 49 and 58
60. Mortality/
61. mortality.fs.
62. Survival rate/
63. Survival analysis/
64. Life Expectancy/
65. "Cause of Death"/
66. mortality.ti,ab.
67. (death or deaths).ti,ab.
68. survival.ti,ab.
69. (registry or registries).ti,ab.
70. 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69
71. 49 and 70
72. 59 or 71
73. limit 72 to humans
74. limit 72 to animals
75. 74 not 73
76. 72 not 75
77. limit 76 to english language
78. limit 77 to yr="2008 -Current"
79. remove duplicates from 78

#### KQ2

1. Colonoscopy/
2. colonoscop$.ti,ab.
3. Sigmoidoscopy/
4. sigmoidoscop$.ti,ab.
5. Colonography, Computed Tomographic/
6. colonograph$.ti,ab.
7. Occult Blood/
8. occult blood.ti,ab.
9. ((fecal or faecal or stool) adj occult).ti,ab.
10. (fobt or ifobt or gfobt).ti,ab.
11. guaiac.ti,ab.
12. ((fecal or faecal or stool) adj5 test$).ti,ab.
13. ((fecal or faecal or stool) and (immunochemical or immunoassay)).ti,ab.
14. DNA/
15. DNA Methylation/
16. DNA Mutational Analysis/
17. DNA, neoplasm/
18. 14 or 15 or 16 or 17
19. Feces/
20. 18 and 19
21. ((fecal or faecal or stool) adj5 (DNA or deoxyribonucleic acid)).ti,ab.
22. ((fecal or faecal or stool) adj5 (genetic$ or genomic$)).ti,ab.
23. ((fecal or faecal or stool) adj5 molecular).ti,ab.
24. (f-dna or fdna or s-dna or sdna).ti,ab.
25. "SEPT9 protein, human".nm.
26. Septins/
27. (SEPTIN9 or SEPTIN 9 or SEPT9 or mSEPT9).ti,ab.
28. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27
29. "Sensitivity and Specificity"/
30. "Predictive Value of Tests"/
31. ROC Curve/
32. False Negative Reactions/
33. False Positive Reactions/
34. Diagnostic Errors/
35. "Reproducibility of Results"/
36. Reference Values/
37. Reference Standards/
38. Observer Variation/
39. Receiver operat$.ti,ab.
40. ROC curve$.ti,ab.
41. sensitivit$.ti,ab.
42. specificit$.ti,ab.
43. predictive value.ti,ab.
44. accuracy.ti,ab.
45. false positive$.ti,ab.
46. false negative$.ti,ab.
47. miss rate$.ti,ab.
48. error rate$.ti,ab.
49. detection rate$.ti,ab.
50. diagnostic yield$.ti,ab.
51. likelihood ratio$.ti,ab.
52. diagnostic odds ratio$.ti,ab.
53. 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52
54. 28 and 53
55. Colonoscopy/st
56. Sigmoidoscopy/st
57. Colonography, Computed Tomographic/st
58. 55 or 56 or 57
59. 54 or 58
60. Mass screening/ or "Early Detection of Cancer"/
61. (screen$ or detect$).ti,ab.
62. 60 or 61
63. 59 and 62
64. limit 63 to english language
65. limit 64 to yr="2008 -Current"
66. remove duplicates from 65

#### KQ3

1. Colonoscopy/ae, mo [Adverse Effects, Mortality]
2. Sigmoidoscopy/ae, mo
3. Colonography, Computed Tomographic/ae, mo
4. 1 or 2 or 3
5. Colonoscopy/
6. Sigmoidoscopy/
7. Colonography, Computed Tomographic/
8. Occult Blood/
9. DNA/
10. DNA Methylation/
11. DNA Mutational Analysis/
12. DNA, neoplasm/
13. 9 or 10 or 11 or 12
14. Feces/
15. 13 and 14
16. "SEPT9 protein, human".nm.
17. Septins/
18. 5 or 6 or 7 or 8 or 15 or 16 or 17
19. Colorectal Neoplasms/
20. Adenomatous Polyposis Coli/
21. Colonic Neoplasms/
22. Sigmoid Neoplasms/
23. Colorectal Neoplasms, Hereditary Nonpolyposis/
24. Rectal Neoplasms/
25. Anus Neoplasms/
26. Anal Gland Neoplasms/
27. Colonic Polyps/
28. Adenomatous Polyps/
29. 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28
30. Mass screening/ or "Early Detection of Cancer"/
31. (screen$ or detect$).ti.
32. 29 and (30 or 31)
33. Mortality/
34. Morbidity/
35. Death/
36. Hemorrhage/
37. Gastrointestinal hemorrhage/
38. Postoperative hemorrhage/
39. Intraoperative complications/
40. Postoperative complications/
41. incidental findings/
42. (harm or harms or harmful or harmed).ti.
43. (adverse adj (effect$ or event$ or outcome$)).ti.
44. safety.ti.
45. complication$.ti.
46. (death or deaths).ti.
47. (hemorrhag$ or haemorrhag$).ti.
48. bleed$.ti.
49. (death or deaths).ti.
50. ((incidental or extracolonic) adj finding$).ti.
51. 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50
52. (18 or 32) and 51
53. 4 or 52
54. limit 53 to humans
55. limit 53 to animals
56. 55 not 54
57. 53 not 56
58. limit 57 to (english language and yr="2008 -Current")
59. colonoscop$.ti,ab.
60. sigmoidoscop$.ti,ab.
61. colonograph$.ti,ab.
62. occult blood.ti,ab.
63. ((fecal or faecal) adj occult).ti,ab.
64. (fobt or ifobt or gfobt).ti,ab.
65. guaiac.ti,ab.
66. ((fecal or faecal or stool) adj5 test$).ti,ab.
67. ((fecal or faecal or stool) and (immunochemical or immunoassay)).ti,ab.
68. ((fecal or faecal or stool) adj5 (DNA or deoxyribonucleic acid)).ti,ab.
69. ((fecal or faecal or stool) adj5 (genetic$ or genomic$)).ti,ab.
70. ((fecal or faecal or stool) adj5 molecular).ti,ab.
71. (f-dna or fdna or s-dna or sdna).ti,ab.
72. (SEPTIN9 or SEPTIN 9 or SEPT9 or mSEPT9).ti,ab.
73. 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72
74. ((colorectal or colon or colonic or rectal or rectum or rectosigmoid$ or adenomat$) adj3 (cancer$ or carcinoma$ or adenocarcinoma$ or malignan$ or tumor$ or tumour$ or neoplas$ or polyp$)).ti,ab.
75. (screen$ or detect$).ti.
76. 74 and 75
77. 73 or 76
78. (harm or harms or harmful or harmed).ti,ab.
79. (adverse adj (effect$ or event$ or outcome$)).ti,ab.
80. safety.ti,ab.
81. complication$.ti,ab.
82. (death or deaths).ti,ab.
83. (hemorrhag$ or haemorrhag$).ti,ab.
84. bleed$.ti,ab.
85. perforat$.ti,ab.
86. ((incidental or extracolonic) adj finding$).ti,ab.
87. 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86
88. 77 and 87
89. limit 88 to ("in data review" or in process or "pubmed not medline")
90. limit 89 to (english language and yr="2008 -Current")
91. 58 or 90
92. remove duplicates from 91

### PubMed search strategy (publisher-supplied)

1. Search (colorectal[ti] OR colon[ti] OR colonic[ti] OR rectal[ti] OR rectum[ti] OR rectosigmoid*[ti] OR adenoma*[ti]) AND (cancer*[ti] OR carcinoma*[ti] OR adenocarcinoma*[ti] OR malignan*[ti] OR tumor[ti] OR tumors[ti] OR tumour[ti] OR tumours[ti] OR neoplas*[ti] OR polyp[ti] OR polyps[ti] OR polyposis[ti])
2. Search (screen*[ti] OR detect*[ti] OR surveillance[ti])
3. Search #1 AND #2
4. Search (colonoscop*[ti] OR colonograph*[ti] OR sigmoidoscop*[ti])
5. Search (fecal[ti] OR faecal[ti] OR stool[ti]) AND (DNA[ti] OR "deoxyribonucleic acid"[ti])
6. Search (fecal[ti] OR faecal[ti] OR stool[ti]) AND (molecular[ti] OR genetic[ti] OR genetics[ti])
7. Search (fdna[ti] OR f-dna[ti] OR sdna[ti] OR s-dna[ti])
8. Search (fecal[ti] OR faecal[ti] OR stool[ti]) AND (immunochemical[ti] OR immunoassay[ti])
9. Search ("fecal occult"[ti] OR "faecal occult"[ti] OR “stool occult”[ti] OR "occult blood"[ti] OR FOBT[ti] OR IFOBT[ti])
10. Search ("septin 9"[ti] OR septin9[ti] OR sept9[ti])
11. Search #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10
12. Search #11 AND publisher[sb] Filters: English
13. Search #11 AND publisher[sb] Filters: Publication date from 2008/01/01 to 2014/12/31; English

Appendix B Figure 1 Literature Flow Diagram

Abbreviations: FS = flexible sigmoidoscopy; MA = meta-analysis; SER = systematic evidence review; USPSTF = U.S. Preventive Services Task Force

Appendix A Figure 1 displays the literature search results and article flow for the review. A total of 8052 articles were identified through database searching, 372 through selected systematic evidence reviews and other sources, and 68 from the 2008 USPSTF evidence review. 8492 articles were screened and 696 full-text articles were assessed for eligibility. 47 articles (25 studies) were included for key question 1. 44 articles (33 studies) were included for key question 2. 112 articles (97 studies) were included for key question 3.

Appendix B Table 1 Inclusion and Exclusion Criteria

| KQ | Inclusion | Exclusion
Populations | 1–3 | Age ≥40 years, average risk or unselected populations; Screening populations (i.e., asymptomatic) | Populations selected for personal or family history of CRC, known genetic susceptibility syndromes (e.g., Lynch Syndrome, FAP), personal history of inflammatory bowel disease; Non-screening populations (e.g., symptomatic, screening test positive, iron deficiency anemia, surveillance for previous colorectal lesion)
Settings | 1–3 | Settings representative of community practice for FS and colonoscopy studies; Developed countries (as defined by “very high” development using the Human Development Index [top quartile of 2012 rankings])^*^ | Primarily research based settings (or select academic settings that would not be applicable to most practice settings) for endoscopy studies (e.g., small studies aimed at evaluating new endoscopy technologies, studies with operator or resource characteristics not applicable to community practice); Developing countries
Screening tests | 1 | Any program of CRC screening, including endoscopy, imaging, stool or blood testing
Screening tests | 2–3 | Colonoscopy; Flexible sigmoidoscopy (FS); Computed tomography colonography (CTC); Stool screening tests:; i. High sensitivity guaiac fecal occult blood test (gFOBT) (i.e., Hemoccult SENSA); ii. Fecal immunochemical test (FIT) (quantitative and qualitative testing); iii. Stool DNA test;; Blood screening test: mSEPT9 | Hemoccult II (note: review of test performance and harms limited to high-sensitivity gFOBT); Stool testing using in-office digital rectal exam (DRE); Double contrast barium enema (DCBE); Capsule endoscopy [Pill Cam]; Magnetic resonance colonography (MRC)
Comparisons | 1 | No screening or alternate screening strategy
Comparisons | 2 | Diagnostic accuracy studies must use colonoscopy as a reference standard
Comparisons | 3 | No comparator necessary
Outcomes | 1 | CRC incidence (by stage), interval CRC; CRC-specific or all-cause mortality | Incidence of adenomas or advanced neoplasia (composite outcome of advanced adenomas and CRC)
Outcomes | 2 | Test performance including: Sensitivity and specificity (per person); Positive (PPV) and negative (NPV) predictive value (per person); Yield and miss rates (per lesion) for structural exams (i.e., colonoscopy, FS, CTC); For CRC, advanced adenoma (high grade dysplasia, villous histology, and/or ≥10 mm), and/or adenomatous polyps by size (i.e., ≤5 mm, 6–9 mm, ≥10 mm) By location in colon (e.g., proximal versus distal)
Outcomes | 3 | Serious adverse events requiring unexpected or unwanted medical attention and/or resulting in death (e.g., requiring hospitalization), including but not limited to perforation, major bleeding, severe abdominal symptoms, cardiovascular events; Extra-colonic findings and subsequent diagnostic work-up and adverse events from diagnostic testing for incidental findings on CTC Radiation exposure per CTC exam | Minor adverse events defined as those not necessarily needing or resulting in medical attention (e.g., patient dissatisfaction, anxiety/worry, minor GI complaints)
Study design | 1–3 | Fair to good quality studies | Poor quality studies with a fatal flaw
Study design | 1 | Systematic reviews (of included study designs), RCT, selected well-designed CCT, cohort studies, or case-control studies | Decision analyses
Study design | 2 | Systematic reviews (of included study designs), trials, cohort or well-conducted nested case-control diagnostic accuracy studies, screening registry studies | Diagnostic accuracy studies without colonoscopy as a reference standard, diagnostic accuracy studies without representation of a full spectrum of disease (e.g., case-control studies, excluded indeterminate results)
Study design | 3 | Systematic reviews (of included study designs), RCT/CCT, large screening registry or database observational studies, cohort studies, systematically selected case series

* Taiwan is not incorporated into HDI calculations for the People’s Republic of China. Therefore it is considered very high HDI based on calculations from Taiwan’s government.

Abbreviations: CCT = controlled clinical trial; CRC = colorectal cancer; CTC = computed tomographic colonography; DCBE = Double contrast barium enema; DRE = digital rectal exam; e.g. = exempli gratia; FAP = familial adenomatous polyposis; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; GI = gastrointestinal; HDI = human development index; i.e. = id est; mm = millimeter; MRC = Magnetic resonance colonography; NPV = negative predictive value; PPV = positive predictive value; RCT = randomized controlled trial.

Appendix B Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods97 | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was there a difference in attrition between groups?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was there intervention fidelity?; - Was there risk of contamination?; - Was there adequate adherence to the intervention?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there acceptable followup?; - Was there evidence of selective reporting of outcomes?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)100 | - Was there representativeness of the exposed cohort?; - Was the non-exposed systematically selected?; - Was the ascertainment of exposure reported?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid and reliable?; - Were outcome assessors blinded?; - Was followup long enough for the outcome to occur?; - Was there acceptable followup?
Diagnostic accuracy studies, adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) I102 and II101 instrument | - Could the selection of patients have introduced bias?; ○ Was the spectrum of patients representative of the patients who will receive the test in PC?; ○ Was the selection process clearly defined?; ○ Are there concerns that the included patients and setting do not match review question?; - Could the conduct or interpretation of the index test have introduced bias?; ○ Was the index test interpreted without knowledge of the reference standard results?; ○ If a threshold was use, was it pre-specified?; ○ Are there concerns that the index test, its conduct, or its interpretation differ from the review question?; - Could the conduct or interpretation of the reference standard have introduced bias?; ○ Is the reference standard likely to correctly classify the target condition?; ○ Was the reference standard interpreted without knowledge of the index test results?; ○ Are there concerns that the target condition as defined by the reference standard does not match the review question?; ○ Did the whole or partial selection of patients receive the reference standard?; - Could the patient flow have introduced bias?; ○ Was there an appropriate interval between the index test and reference standard?; ○ Did all patients receive the same reference standard?; ○ Were all patients included in the analysis?
Assessment of Multiple Systematic Reviews (AMSTAR)99 | - Was an ‘a priori’ design provided?; - Was there dual study selection?; - Was there dual data extraction?; - Was a comprehensive literature search performed?; - Was the status of publication used as an inclusion criterion?; - Was a list of studies included provided?; - Was a list of excluded studies provided?; - Were the characteristics of the included studies provided?; - Was the scientific quality of the included studies assessed and documented?; - Was the scientific quality of the included studies used appropriately in formulating conclusions?; - Were the methods used to combine the findings of studies appropriate?; - Was the likelihood of publication bias assessed?; - Were potential conflicts of interest/source(s) of support of the systematic review stated?; - Were potential conflicts of interest/source(s) of support of the included studies stated?