# Society or Professional Organization Recommendations

Appendix A Table 1 Recommended Screening Tests for Colorectal Cancer by Selected Society or Professional Organization Since 2008

Society or Professional Organization, Year | Colonoscopy | FS^*^ | gFOBT^†^ | FIT | CTC | Stool DNA | DCBE | MRC
USPSTF, 2008^87^ | Y | Y | Y | Y | I | I | -- | --
ACS/USMSTF^***^/ACR, 2008^88^ | Y^**^ | Y^**^ | Y | Y | Y^**^ | Y | Y^**^ | --
KPCMI, 2008^407^ | Y | Y | Y | Y | N | N | N | --
ACG, 2008^392^ | Y | M | Y | Y | Y | M | -- | --
ACR, 2010^408^ | -- | -- | -- | -- | Y | -- | Y | M
SIGN, 2011^409^ | -- | -- | Y | -- | -- | -- | -- | --
ICSI, 2012^410^ | Y | Y | Y | Y | Y | -- | -- | --
ACP, 2012^411^ | Y | Y | Y | Y | I | Y | Y | --
NCCN, 2013^412^ | Y^‡^ | Y^‡^ | Y | Y | Y^‡^ | Y | -- | --

* with or without stool testing

† high sensitivity

** The ACS/USMSTF/ACR guideline strongly recommends screening tests that are designed to detect both early cancer and adenomatous polyps if resources are available and patients are willing to receive an invasive test.

‡ NCNN encourages tests that are designed to detect both early cancer and adenomatous polyps.

*** USMSTF includes American Gastroenterological Association, American College of Gastroenterology, and American Society for Gastrointestinal Endoscopy

Abbreviations: ACG = American College of Gastroenterology; ACP = American College of Physicians; ACR = American College of Radiology; ACS = American Cancer Society; CTC = computed tomography colonography; DCBE = double-conrast barium enema; DNA = deoxyribonucleic acid; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; I = insufficient evidence to evaluate; ICSI = Institute for Clinical Systems Improvement; KPCMI = Kaiser Permanente Care Management Institute; M = maybe, weak recommendation or may be appropriate; MRC = magnetic resonance colonography; N = no, not recommended; NCCN = National Comprehensive Cancer Network; SIGN = Scottish Intercollegiate Guidelines Network; USMSTF = U.S. Multi-Society Task Force; USPSTF = U.S. Preventive Services Task Force; Y = yes, recommended as an acceptable option; -- = not addressed in the guideline