# References

1 U.S.Preventive Services Task Force. Counseling and interventions to prevent tobacco use and tobacco-caused disease in adults and pregnant women: U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. Apr. 21. 2009;150(8):551-5. [pmid: 19380855].
2 Fiore MC. A clinical practice guideline for treating tobacco use and dependence: A US Public Health Service report. The Tobacco Use and Dependence Clinical Practice Guideline Panel, Staff, and Consortium Representatives. JAMA. Jun. 28. 2000;283(24):3244-54. [pmid: 10866874].
3 Fiore MC, jaen CR, Baker TB. Treating Tobacco Use and Dependence: 2008 Update (Clinical Practice Guideline). U.S. Department of Health and Human Services. 2008. PMID: None.
4 Cobb NK, Byron MJ, Abrams DB, et al. Novel nicotine delivery systems and public health: the rise of the “e-cigarette”. Am J Public Health. Dec. 2010;100(12):2340-2. [pmid: 21068414].
5 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders: DSM-IV. Washington D.C. American Psychiatric Association. 1994. PMID: None.
6 World Health Organization. International statistical classification of diseases and related health problems. Washington D.C. World Health Organization. 1992. PMID: None.
7 Baker TB, Breslau N, Covey L, et al. DSM criteria for tobacco use disorder and tobacco withdrawal: a critique and proposed revisions for DSM-5. Addiction. Feb. 2012;107(2):263-75. [pmid: 21919989].
8 Office on Smoking and Health. How Tobacco Smoke Causes Disease: The Biology and Behavioral Basis for Smoking-Attributable Disease: A Report of the Surgeon General. Atlanta, GA. Centers for Disease Control and Prevention. 2010. PMID:.
9 Hatsukami DK, Stead LF, Gupta PC. Tobacco addiction. Lancet. Jun. 14. 2008;371(9629):2027-38. PMID:. [pmid: 18555914].
10 U.S.Department of Health and Human Services. The Health Consequences of Smoking: 50 Years of Progress. A Report of the Surgeon General. Atlanta, GA. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 2014. PMID: None.
11 Office on Smoking and Health. Women and Smoking: A Report of the Surgeon General. Atlanta, GA. Centers for Disease Control and Prevention. 2001. PMID:.
12 World Health Organization. WHO Recommendations for the prevention and management of tobacco use and second-hand smoke exposure in pregnancy. Geneva, Switzerland. World Health Organization. 2013. PMID: None.
13 Jamal A, Agaku IT, O'Connor E, et al. Current cigarette smoking among adults--United States, 2005-2013. MMWR Morb Mortal Wkly Rep. Nov. 28. 2014;63(47):1108-12. [pmid: 25426653].
14 Cook BL, Wayne GF, Kafali EN, et al. Trends in smoking among adults with mental illness and association between mental health treatment and smoking cessation. JAMA. Jan. 8. 2014;311(2):172-82. [pmid: 24399556].
15 Centers for Diesease Control and Prevention. Vital Signs: Current Cigarette Smoking Among Adults Aged >=18 Years with Mental Illness - United States, 2009-2011. Morbidity and Mortality Weekly Report. 2013;62(05). PMID: None.
16 McClave AK, McKnight-Eily LR, Davis SP, et al. Smoking characteristics of adults with selected lifetime mental illnesses: results from the 2007 National Health Interview Survey. Am J Public Health. Dec. 2010;100(12):2464-72. PMID:. [pmid: 20966369].
17 Substance Abuse and Mental Health Services Administration. The NSDUH Report: Smoking and Mental Illness. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2013. PMID: None.
18 Substance Abuse and Mental Health Services Administration. Results from the 2012 National Survey on Drug Use and Health: Summary of National Findings. NSDUH Series H-46, HHS Publication No. (SMA) 13-4795. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2013. PMID: None.
19 Centers for Disease Control and Prevention. Quitting smoking among adults--United States, 2001-2010. MMWR Morb Mortal Wkly Rep. Nov. 11. 2011;60(44):1513-9. [pmid: 22071589].
20 U.S.Department of Health and Human Services. The Health Benefits of Smoking Cessation. A Report of the Surgeon General. YO-K-116. Centers for Disease Control. 1990. PMID: None.
21 Jha P, Ramasundarahettige C, Landsman V, et al. 21st-century hazards of smoking and benefits of cessation in the United States. N Engl J Med. Jan. 24. 2013;368(4):341-50. [pmid: 23343063].
22 Gellert C, Schottker B, Brenner H. Smoking and all-cause mortality in older people: systematic review and meta-analysis. Arch Intern Med. Jun. 11. 2012;172(11):837-44. [pmid: 22688992].
23 Anthonisen NR, Skeans MA, Wise RA, et al. The effects of a smoking cessation intervention on 14.5-year mortality: a randomized clinical trial. Ann Intern Med. Feb. 15. 2005;142(4):233-9. [pmid: 15710956].
24 Rose G, Hamilton PJ. A randomised controlled trial of the effect on middle-aged men of advice to stop smoking. J Epidemiol Community Health. Dec. 1978;32(4):275-81. [pmid: 370171].
25 Rose G, Colwell L. Randomised controlled trial of anti-smoking advice: final (20 year) results. J Epidemiol Community Health. Feb. 1992;46(1):75-7. [pmid: 1573365].
26 Kawachi I, Colditz GA, Stampfer MJ, et al. Smoking cessation and decreased risk of stroke in women. JAMA. Jan. 13. 1993;269(2):232-6. [pmid: 8417241].
27 Wannamethee SG, Shaper AG, Whincup PH, et al. Smoking cessation and the risk of stroke in middle-aged men. JAMA. Jul. 12. 1995;274(2):155-60. [pmid: 7596004].
28 Taylor G, McNeill A, Girling A, et al. Change in mental health after smoking cessation: systematic review and meta-analysis. BMJ. 2014;348:g1151. PMID:. [pmid: 24524926].
29 U.S.Food and Drug Administration. Smoking Cessation Products to Help You Quit. U.S.Department of Health and Human Services. 2012. http://www.fda.gov/tobaccoproducts/resourcesforyou/ucm168231.htm. October 15 2014. PMID: None.
30 Food and Drug Administration. Modifications to labeling of nicotine replacement therapy products for over-the-counter human use. Federal Register. Apr. 2. 2013;78(63):19718-21. PMID: None.
31 Herman AI, Sofuoglu M. Comparison of available treatments for tobacco addiction. Curr Psychiatry Rep. Oct. 2010;12(5):433-40. PMID:. [pmid: 20623259].
32 Zhu SH, Sun JY, Bonnevie E, et al. Four hundred and sixty brands of e-cigarettes and counting: implications for product regulation. Tob Control. Jul. Suppl 3. 2014;23:iii3-iii9. [pmid: 24935895].
33 Etter JF, Bullen C, Flouris AD, et al. Electronic nicotine delivery systems: a research agenda. Tob Control. May. 2011;20(3):243-8. PMID:. [pmid: 21415064].
34 Goniewicz ML, Kuma T, Gawron M, et al. Nicotine levels in electronic cigarettes. Nicotine Tob Res. Jan. 2013;15(1):158-66. [pmid: 22529223].
35 Cameron JM, Howell DN, White JR, et al. Variable and potentially fatal amounts of nicotine in e-cigarette nicotine solutions. Tob Control. Jan. 2014;23(1):77-8. [pmid: 23407110].
36 Trehy ML, Ye W, Hadwiger ME, et al. Analysis of electronic cigarette cartridges, refill solutions, and smoke for nicotine and nicotine related impurities. Journal of Liquid Chromatography and Related Technologies. 2011;34(14):1442-58. PMID: None.
37 Davis B, Dang M, Kim J, et al. Nicotine concentrations in electronic cigarette refill and do-it-yourself fluids. Nicotine Tob Res. 2014. May. 26. [pmid: 24862971].
38 Food and Drug Administration. Electronic Cigarettes. Silver Spring, MD. U.S. Food and Drug Administration. 2014. PMID: None.
39 Food and Drug Administration. Proposed Rule: Deeming Tobacco Products To Be Subject to the Federal Food, Drug, and Cosmetic Act. 2014. PMID: None.
40 Campaign for Tobacco-Free Kids. New study finds dramatic rise in youth exposure to e-cigarette ads on TV, underscores need for FDA to regulate e-cigarette marketing. 2014.
41 King BA, Patel R, Nguyen KH, et al. Trends in Awareness and Use of Electronic Cigarettes Among U.S. Adults, 2010-2013. Nicotine Tob Res. 2014. Sep. 19. PMID:.
42 Regan AK, Promoff G, Dube SR, et al. Electronic nicotine delivery systems: adult use and awareness of the ‘e-cigarette’ in the USA. Tob Control. Jan. 2013;22(1):19-23. [pmid: 22034071].
43 Adkison SE, O'Connor RJ, Bansal-Travers M, et al. Electronic nicotine delivery systems: international tobacco control four-country survey. Am J Prev Med. Mar. 2013;44(3):207-15. [pmid: 23415116].
44 Cummins S, Zhu S, Tedeschi G, et al. Use of e-cigarettes by individuals with mental health conditions. To. Control. 2014. May. 12. PMID:.
45 World Health Organization. Marketers of electronic cigarettes should halt unproved therapy claims. 2008. PMID: None.
46 Auf R. Electronic cigarettes and smoking cessation: a quandary?. Lancet. Feb. 1. 2014;383(9915):408. [pmid: 24485577].
47 Benowitz NL. Emerging nicotine delivery products. Implications for public health. Ann Am Thorac Soc. Feb. 2014;11(2):231-5. [pmid: 24575992].
48 Bialous SA, Sarma L. Electronic cigarettes and smoking cessation: a quandary?. Lancet. Feb. 1. 2014;383(9915):407-8. [pmid: 24485576].
49 Brody JS. The promise and problems of e-cigarettes. Am J Respir Crit Care Med. Feb. 15. 2014;189(4):379-80. [pmid: 24528311].
50 Bullen C, Howe C, Laugesen M, et al. Electronic cigarettes and smoking cessation: a quandary? - Authors' reply. Lancet. Feb. 1. 2014;383(9915):408-9. [pmid: 24485579].
51 Bullen C, Knight-West O, O'Brien B, et al. Evidence, not conjecture, should guide clinical practice and policies on e-cigarettes. BMJ. 2014;348:g2008. [pmid: 24614753].
52 Chapman S. E-cigarettes: does the new emperor of tobacco harm reduction have any clothes?. Eur J Public Health. 2004. Apr. 26. [pmid: 24769546].
53 Doyle C, Patterson S, Scott J. Electronic cigarettes and smoking cessation: a quandary?. Lancet. Feb. 1. 2014;383(9915):408. [pmid: 24485578].
54 Glynn TJ. E-cigarettes and the future of tobacco control. CA Cancer J Clin. 2014. Mar. 14. [pmid: 24633865].
55 Hitchman SC, McNeill A, Brose LS. Electronic cigarettes: time for an accurate and evidence-based debate. Addiction. Jun. 2014;109(6):867-8. [pmid: 24796396].
56 Cobb NK, Abrams DB. The FDA, e-cigarettes, and the demise of combusted tobacco. N Engl J Med. Oct. 16. 2014;371(16):1469-71. PMID:. [pmid: 25317866].
57 Maziak W. Potential and pitfalls of e-cigarettes. JAMA. May. 14. 2014;311(18):1922. [pmid: 24825653].
58 Abrams DB. Potential and pitfalls of e-cigarettes--reply. JAMA. May. 14. 2014;311(18):1922-3. [pmid: 24825654].
59 Bhatnagar A, Whitsel LP, Ribisl KM, et al. Electronic Cigarettes: A Policy Statement From the American Heart Association. Circulation. 2014. Aug. 24. [pmid: 25156991].
60 Fiore MC, Schroeder SA, Baker TB. Smoke, the chief killer - Strategies for targeting combustible tobacco use. New England Journal of Medicine. 2014;370(4):297-9. [pmid: 24450888].
61 Wagener TL, Siegel M, Borrelli B. Electronic cigarettes: achieving a balanced perspective. Addiction. Sep. 2012;107(9):1545-8. [pmid: 22471757].
62 Caponnetto P, Russo C, Bruno CM, et al. Electronic cigarette: a possible substitute for cigarette dependence. Monaldi Arch Chest Dis. Mar. 2013;79(1):12-9. [pmid: 23741941].
63 Abrams DB. Promise and peril of e-cigarettes: can disruptive technology make cigarettes obsolete?. JAMA. Jan. 8. 2014;311(2):135-6. [pmid: 24399548].
64 Callahan-Lyon P. Electronic cigarettes: human health effects. Tob Control. May. Suppl 2. 2014;23:ii36-ii40. [pmid: 24732161].
65 Chen IL, Husten CG. Introduction to tobacco control supplement. Tob Control. May. Suppl 2. 2014;23:ii1-ii3. [pmid: 24732156].
66 Goniewicz ML, Knysak J, Gawron M, et al. Levels of selected carcinogens and toxicants in vapour from electronic cigarettes. Tob Control. Mar. 2014;23(2):133-9. [pmid: 23467656].
67 Hung DY, Leidig R, Shelley DR. What's in a setting?: Influence of organizational culture on provider adherence to clinical guidelines for treating tobacco use. Health Care Manage Rev. 2013. Apr. 30. [pmid: 23636103].
68 Jamal A, Dube SR, Malarcher AM, et al. Tobacco use screening and counseling during physician office visits among adults--National Ambulatory Medical Care Survey and National Health Interview Survey, United States, 2005-2009. MMWR Morb Mortal Wkly Rep. Jun. 15. 61 Suppl. 2012:38-45. [pmid: 22695462].
69 Messer K, Trinidad DR, Al-Delaimy WK, et al. Smoking cessation rates in the United States: a comparison of young adult and older smokers. Am J Public Health. Feb. 2008;98(2):317-22. [pmid: 18172143].
70 Conroy MB, Majchrzak NE, Silverman CB, et al. Measuring provider adherence to tobacco treatment guidelines: a comparison of electronic medical record review, patient survey, and provider survey. Nicotine Tob Res. Apr. Suppl 1. 2005;7:S35-S43. [pmid: 16036268].
71 Chase EC, McMenamin SB, Halpin HA. Medicaid provider delivery of the 5A's for smoking cessation counseling. Nicotine Tob Res. Nov. 2007;9(11):1095-101. [pmid: 17978983].
72 Papadakis S, McDonald P, Mullen KA, et al. Strategies to increase the delivery of smoking cessation treatments in primary care settings: a systematic review and meta-analysis. Preventive Medicine. 2010;51(3-4):199-213. [pmid: 20600264].
73 Herie M, Connolly H, Voci S, et al. Changing practitioner behavior and building capacity in tobacco cessation treatment: the TEACH project. Patient Educ Couns. Jan. 2012;86(1):49-56. [pmid: 21612884].
74 Sheffer CE, Anders M, Brackman SL, et al. Tobacco intervention practices of primary care physicians treating lower socioeconomic status patients. Am J Med Sci. May. 2012;343(5):388-96. [pmid: 22008779].
75 Haug S, Meyer C, Ulbricht S, et al. Predictors and moderators of outcome in different brief interventions for smoking cessation in general medical practice. Patient Educ Couns. Jan. 2010;78(1):57-64. [pmid: 19660890].
76 Kandra KL, Ranney LM, Lee JG, et al. Physicians' attitudes and use of e-cigarettes as cessation devices, North Carolina, 2013. PLoS ONE. 2014;9(7):e103462. [pmid: 25072466].
77 England L, Anderson B, Tong V, et al. Screening practices and attitudes of obstetricians-gynecologists toward new and emerging tobacco products. Am J Obste Gynecol. 2014. May. 29. [pmid: 24881828].
78 Guide to Community Preventive Services. Reducing tobacco use and secondhand smoke exposure. 2013. PMID: None.
79 Grant MJ, Booth A. A typology of reviews: an analysis of 14 review types and associated methodologies. Health Info Libr J. Jun. 2009;26(2):91-108. [pmid: 19490148].
80 Becker L, Oxman A, Higgins J, Green S, editors. Cochrane Handbook for Systmatic Reviews of Interventions (Version 5.1.0). The Cochrane Collaboration. 2011. PMID: None.
81 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. May. 20. 2008;148(10):776-82. [pmid: 18490690].
82 U.S.Preventive Services Task Force. Procedure Manual. Rockville, MD. Agency for Healthcare Quality and Research. 2011. PMID: None.
83 Canadian Agency for Drugs and Technologies in Health. Electronic cigarettes: a review of the clinical evidence and safety. 2012. PMID: None.
84 Drummond MB, Upson D. Electronic cigarettes. Potential harms and benefits. Ann Am Thorac Soc. Feb. 2014;11(2):236-42. [pmid: 24575993].
85 Farsalinos KE, Polosa R. Safety evaluation and risk assessment of electronic cigarettes as tobacco cigarette substitutes: a systematic review. Ther Adv Drug Saf. Apr. 2014;5(2):67-86. [pmid: 25083263].
86 Franck C, Budlovsky T, Windle SB, et al. Electronic cigarettes in north america: history, use, and implications for smoking cessation. Circulation. May. 13. 2014;129(19):1945-52. [pmid: 24821825].
87 Grana R, Benowitz N, Glantz SA. E-cigarettes: a scientific review. Circulation. May. 13. 2014;129(19):1972-86. [pmid: 24821826].
88 Hajek P, Etter JF, Benowitz N, et al. Electronic cigarettes: review of use, content, safety, effects on smokers and potential for harm and benefit. Addiction. 2014. Jul. 31. [pmid: 25078252].
89 Harrell PT, Simmons VN, Correa JB, et al. Electronic Nicotine Delivery Systems (“E-cigarettes”): Review of Safety and Smoking Cessation Efficacy. Otolaryngol Head Nec Surg. 2014. Jun. 4. [pmid: 24898072].
90 Pepper JK, Brewer NT. Electronic nicotine delivery system (electronic cigarette) awareness, use, reactions and beliefs: a systematic review. Tob Control. 2013. Nov. 20. [pmid: 24259045].
91 Peralta AR, Guntur VP. Safety and efficacy of electronic cigarettes: a review. Mo Med. May. 2014;111(3):238-44. [pmid: 25011347].
92 Coleman T, Chamberlain C, Davey MA, et al. Pharmacological interventions for promoting smoking cessation during pregnancy. Cochrane Database of Systematic Reviews. 2012. [pmid: 22972148].
93 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
94 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-20. [pmid: 19230606].
95 Kontopantelis E, Springate DA, Reeves D. A re-analysis of the Cochrane Library data: the dangers of unobserved heterogeneity in meta-analyses. PLoS ONE. 2013;8(7):e69930. [pmid: 23922860].
96 Cornell JE, Mulrow CD, Localio R, et al. Random-Effects Meta-analysis of Inconsistent Effects: A Time for Change. Ann Intern Med. Feb. 18. 2014;160(4):267-70. [pmid: 24727843].
97 The Cochrane Collaboration. Cochrane handbook for systematic reviews of interventions. 2011. PMID: None.
98 West R, Hajek P, Stead L, et al. Outcome criteria in smoking cessation trials: proposal for a common standard. Addiction. Mar. 2005;100(3):299-303. [pmid: 15733243].
99 Banham L, Gilbody S. Smoking cessation in severe mental illness: what works?. Addiction. Jul. 2010;105(7):1176-89. [pmid: 20491721].
100 Barnes J, Dong CY, McRobbie H, et al. Hypnotherapy for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2010;(10). [pmid: 20927723].
101 Berlin I, Grange G, Jacob N, et al. Nicotine patches in pregnant smokers: randomised, placebo controlled, multicentre trial of efficacy. BMJ. 2014;348:g1622. [pmid: 24627552].
102 Bize R, Burnand B, Mueller Y, et al. Biomedical risk assessment as an aid for smoking cessation. Cochrane Database of Systematic Reviews. 2012. [pmid: 23235615].
103 Bodner ME, Dean E. Advice as a smoking cessation strategy: a systematic review and implications for physical therapists. Physiother Theory Pract. Jul. 2009;25(5-6):369-407. [pmid: 19842864].
104 Brown J. A review of the evidence on technology-based interventions for the treatment of tobacco dependence in college health. Worldviews Evid Based Nurs. Aug. 2013;10(3):150-62. [pmid: 23421669].
105 Bullen C, Howe C, Laugesen M, et al. Electronic cigarettes for smoking cessation: a randomised controlled trial. Lancet. 2013. Sep. 9. [pmid: 24029165].
106 Cahill K, Lancaster T, Green N. Stage-based interventions for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2010;(11). [pmid: 21069681].
107 Caponnetto P, Campagna D, Cibella F, et al. EffiCiency and Safety of an eLectronic cigAreTte (ECLAT) as tobacco cigarettes substitute: a prospective 12-month randomized control design study. PLoS ONE. 2013;8(6):e66317. [pmid: 23826093].
108 Carr AB, Ebbert J. Interventions for tobacco cessation in the dental setting. Cochrane Database of Systematic Reviews: Reviews. 2012;(6). [pmid: 22696348].
109 Carson KV, Brinn MP, Peters M, et al. Interventions for smoking cessation in Indigenous populations. Cochrane Database of Systematic Reviews: Reviews. 2012;(1). [pmid: 22258998].
110 Chamberlain C, O'Mara-Eves A, Oliver S, et al. Psychosocial interventions for supporting women to stop smoking in pregnancy. Cochrane Database Syst Rev. 2013;10. CD001055. [pmid: 24154953].
111 Chen YF, Madan J, Welton N, et al. Effectiveness and cost-effectiveness of computer and other electronic aids for smoking cessation: a systematic review and network meta-analysis. Health Technol Assess. 2012;16(38):1-v. [pmid: 23046909].
112 Cheng HM, Chung YC, Chen HH, et al. Systematic review and meta-analysis of the effects of acupoint stimulation on smoking cessation. American Journal of Chinese Medicine. 2012;40(3):429-42. [pmid: 22745061].
113 Civljak M, Stead LF, Hartmann-Boyce J, et al. Internet-based interventions for smoking cessation. Cochrane Database Syst Rev. 2013;7. CD007078. [pmid: 23839868].
114 Di YM, May BH, Zhang AL, et al. A meta-analysis of ear-acupuncture, ear-acupressure and auriculotherapy for cigarette smoking cessation. Drug Alcohol Depend. 2014. Jul. 11. [pmid: 25064021].
115 Ebbert J, Montori VM, Erwin PJ, et al. Interventions for smokeless tobacco use cessation. Cochrane Database of Systematic Reviews: Reviews. 2011;(2). [pmid: 21328266].
116 Filion KB, Abenhaim HA, Mottillo S, et al. The effect of smoking cessation counselling in pregnant women: a meta-analysis of randomised controlled trials. BJOG An International Journal of Obstetrics and Gynaecology. 2011;118(12):1422-8. [pmid: 21880109].
117 Gierisch JM, Bastian LA, Calhoun PS, et al. Comparative Effectiveness of Smoking Cessation Treatments for Patients With Depression: A Systematic Review and Meta-analysis of the Evidence. [Internet]. VA Evidence-based Synthesis Program Reports. 2010. Nov. PMID:.
118 Hartmann-Boyce J, Lancaster T, Stead LF. Print-based self-help interventions for smoking cessation. Cochrane Database Syst Rev. 2014;6. CD001118. PMID:.
119 Hettema JE, Hendricks PS. Motivational interviewing for smoking cessation: a meta-analytic review. J Consult Clin Psychol. Dec. 2010;78(6):868-84. [pmid: 21114344].
120 Huang Y, Li W, Yang L, et al. Long-term efficacy and safety of varenicline for smoking cessation: a systematic review and meta-analysis of randomized controlled trials. Journal of Public Health. 2012;20(4):355-65. PMID: None.
121 Hughes JR, Stead LF, Hartmann BJ, et al. Antidepressants for smoking cessation. Cochrane Database of Systematic Reviews. 2014. [pmid: 24402784].
122 Hutton HE, Wilson LM, Apelberg BJ, et al. A systematic review of randomized controlled trials: Web-based interventions for smoking cessation among adolescents, college students, and adults. Nicotine Tob Res. Apr. 2011;13(4):227-38. [pmid: 21350042].
123 Johnston V, Westphal DW, Glover M, et al. Reducing smoking among indigenous populations: new evidence from a review of trials. Nicotine Tob Res. Aug. 2013;15(8):1329-38. [pmid: 23519776].
124 Lai Douglas TC, Cahill K, Qin Y, et al. Motivational interviewing for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2010;(1). [pmid: 20091612].
125 Likis FE, Andrews JC, Fonnesbeck CJ, et al. Smoking Cessation Interventions in Pregnancy and Postpartum Care. Evidence Report/Technology Assessment No. 214. Rockville, MD. Agency for Healthcare Research and Quality. 2014. PMID: None.
126 Liu JJ, Wabnitz C, Davidson E, et al. Smoking cessation interventions for ethnic minority groups: a systematic review of adapted interventions. Preventive Medicine. 2013;57(6):765-75. [pmid: 24076130].
127 Lumley J, Chamberlain C, Dowswell T, et al. Interventions for promoting smoking cessation during pregnancy. Cochrane Database of Systematic Reviews: Reviews. 2009;(3). [pmid: 19588322].
128 Mills EJ, Wu P, Lockhart I, et al. Adverse events associated with nicotine replacement therapy (NRT) for smoking cessation. A systematic review and meta-analysis of one hundred and twenty studies involving 177,390 individuals. Tob Induc Dis. 2010;8:8. [pmid: 20626883].
129 Mills EJ, Wu P, Lockhart I, et al. Comparisons of high-dose and combination nicotine replacement therapy, varenicline, and bupropion for smoking cessation: a systematic review and multiple treatment meta-analysis. Annals of Medicine. 2012;44(6):588-97. [pmid: 22860882].
130 Mills EJ, Thorlund K, Eapen S, et al. Cardiovascular events associated with smoking cessation pharmacotherapies: a network meta-analysis. Circulation. Jan. 7. 2014;129(1):28-41. [pmid: 24323793].
131 Mottillo S, Filion KB, Belisle P, et al. Behavioural interventions for smoking cessation: a meta-analysis of randomized controlled trials. European Heart Journal. 2009;30(6):718-30. [pmid: 19109354].
132 Myung SK, McDonnell DD, Kazinets G, et al. Effects of Web- and computer-based smoking cessation programs. Archives of Internal Medicine. 2009;169(10):929-37. [pmid: 19468084].
133 Myung SK, Ju W, Jung HS, et al. Efficacy and safety of pharmacotherapy for smoking cessation among pregnant smokers: a meta-analysis. BJOG. Aug. 2012;119(9):1029-39. [pmid: 22780818].
134 Nierkens V, Hartman MA, Nicolaou M, et al. Effectiveness of Cultural Adaptations of Interventions Aimed at Smoking Cessation, Diet, and/or Physical Activity in Ethnic Minorities. A Systematic Review. PLoS ONE. 2013;8(10):e73373. [pmid: 24116000].
135 Prochaska JJ, Hilton JF. Risk of cardiovascular serious adverse events associated with varenicline use for tobacco cessation: systematic review and meta-analysis. BMJ. 2012;344:e2856. [pmid: 22563098].
136 Rice VH, Stead LF. Nursing interventions for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2013;(1). [pmid: 23932719].
137 Shahab L, McEwen A. Online support for smoking cessation: a systematic review of the literature. Addiction. 2009;104(11):1792-804. [pmid: 19832783].
138 Stead LF, Lancaster T. Combined pharmacotherapy and behavioural interventions for smoking cessation. Cochrane Database Syst Rev. 2012;10. CD008286. [pmid: 23076944].
139 Stead LF, Buitrago D, Preciado N, et al. Physician advice for smoking cessation. Cochrane Database Syst Rev. 2013;5. CD000165. [pmid: 23728631].
140 Stead LF, Perera R, Bullen C, et al. Nicotine replacement therapy for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2012;(1). [pmid: 23152200].
141 Stead LF, Hartmann BJ, Perera R, et al. Telephone counselling for smoking cessation. Cochrane Database of Systematic Reviews. 2013. [pmid: 23934971].
142 Stead LF, Lancaster T. Behavioural interventions as adjuncts to pharmacotherapy for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2013;(2). [pmid: 23235680].
143 Su A, Buttenheim AM. Maintenance of Smoking Cessation in the Postpartum Period: Which Interventions Work Best in the Long-Term?. Matern Child Health J. 2013. Jun. 29. [pmid: 23812798].
144 Tahiri M, Mottillo S, Joseph L, et al. Alternative smoking cessation aids: a meta-analysis of randomized controlled trials. American Journal of Medicine. 2012;125(6):576-84. [pmid: 22502956].
145 Tran K, Asakawa K, Cimon K, et al. Pharmacologic-based strategies for smoking cessation. 2010. PMID: None.
146 Tsoi DT, Porwal M, Webster AC. Interventions for smoking cessation and reduction in individuals with schizophrenia. Cochrane Database Syst Rev. 2013;2. CD007253. [pmid: 23450574].
147 Tzelepis F, Paul CL, Walsh RA, et al. Proactive telephone counseling for smoking cessation: meta-analyses by recruitment channel and methodological quality. J Natl Cancer Inst. Jun. 22. 2011;103(12):922-41. [pmid: 21666098].
148 Ussher MH, Taylor AH, Faulkner GE. Exercise interventions for smoking cessation. Cochrane Database Syst Rev. 2014;8. CD002295. [pmid: 25170798].
149 van der Meer RM, Willemsen MC, Smit F, et al. Smoking cessation interventions for smokers with current or past depression. Cochrane Database Syst Rev. 2013;8. CD006102. [pmid: 23963776].
150 Villanti AC, McKay HS, Abrams DB, et al. Smoking-cessation interventions for U.S. young adults: a systematic review. Am J Prev Med. Dec. 2010;39(6):564-74. [pmid: 21084078].
151 White AR, Rampes H, Liu JP, et al. Acupuncture and related interventions for smoking cessation. Cochrane Database Syst Rev. 2014;1. CD000009. PMID:.
152 Whittaker R, McRobbie H, Bullen C, et al. Mobile phone-based interventions for smoking cessation. Cochrane Database Syst Rev. 2012;11. CD006611. [pmid: 23152238].
153 Zbikowski SM, Magnusson B, Pockey JR, et al. A review of smoking cessation interventions for smokers aged 50 and older. Maturitas. Feb. 2012;71(2):131-41. [pmid: 22209349].
154 Cahill K, Stead LF, Lancaster T. Nicotine receptor partial agonists for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2012;(4). [pmid: 22513936].
155 Croghan GA, Sloan JA, Croghan IT, et al. Comparison of nicotine patch alone versus nicotine nasal spray alone versus a combination for treating smokers: a minimal intervention, randomized multicenter trial in a nonspecialized setting. Nicotine Tob Res. Apr. 2003;5(2):181-7. [pmid: 12745490].
156 Lerman C, Kaufmann V, Rukstalis M, et al. Individualizing nicotine replacement therapy for the treatment of tobacco dependence: a randomized trial. Ann Intern Med. Mar. 16. 2004;140(6):426-33. [pmid: 15023708].
157 Piper ME, Smith SS, Schlam TR, et al. A randomized placebo-controlled clinical trial of 5 smoking cessation pharmacotherapies. Arch Gen Psychiatry. Nov. 2009;66(11):1253-62. [pmid: 19884613].
158 Schnoll RA, Martinez E, Tatum KL, et al. Nicotine patch vs. nicotine lozenge for smoking cessation: an effectiveness trial coordinated by the Community Clinical Oncology Program. Drug Alcohol Depend. Mar. 1. 2010;107(2-3):237-43. [pmid: 20004065].
159 Smith SS, McCarthy DE, Japuntich SJ, et al. Comparative effectiveness of 5 smoking cessation pharmacotherapies in primary care clinics. Arch Intern Med. Dec. 14. 2009;169(22):2148-55. [pmid: 20008701].
160 Tonnesen P, Mikkelsen KL. Smoking cessation with four nicotine replacement regimes in a lung clinic. Eur Respir J. Oct. 2000;16(4):717-22. [pmid: 11106218].
161 Jorenby DE, Leischow SJ, Nides MA, et al. A controlled trial of sustained-release bupropion, a nicotine patch, or both for smoking cessation. N Engl J Med. Mar. 4. 1999;340(9):685-91. [pmid: 10053177].
162 Hurt RD, Sachs DP, Glover ED, et al. A comparison of sustained-release bupropion and placebo for smoking cessation. N Engl J Med. Oct. 23. 1997;337(17):1195-202. [pmid: 9337378].
163 Swan GE, McAfee T, Curry SJ, et al. Effectiveness of bupropion sustained release for smoking cessation in a health care setting: a randomized trial. Arch Intern Med. Oct. 27. 2003;163(19):2337-44. [pmid: 14581254].
164 Hall SM, Humfleet GL, Reus VI, et al. Psychological intervention and antidepressant treatment in smoking cessation. Arch Gen Psychiatry. Oct. 2002;59(10):930-6. [pmid: 12365880].
165 McCarthy DE, Piasecki TM, Lawrence DL, et al. A randomized controlled clinical trial of bupropion SR and individual smoking cessation counseling. Nicotine Tob Res. Apr. 2008;10(4):717-29. [pmid: 18418793].
166 Schmitz JM, Stotts AL, Mooney ME, et al. Bupropion and cognitive-behavioral therapy for smoking cessation in women. Nicotine Tob Res. Jun. 2007;9(6):699-709. [pmid: 17558827].
167 Piper ME, Federman EB, McCarthy DE, et al. Efficacy of bupropion alone and in combination with nicotine gum. Nicotine Tob Res. Sep. 2007;9(9):947-54. [pmid: 17763111].
168 Aubin HJ, Bobak A, Britton JR, et al. Varenicline versus transdermal nicotine patch for smoking cessation: results from a randomised open-label trial. Thorax. Aug. 2008;63(8):717-24. [pmid: 18263663].
169 Tsukahara H, Noda K, Saku K. A randomized controlled open comparative trial of varenicline vs nicotine patch in adult smokers: efficacy, safety and withdrawal symptoms (the VN-SEESAW study). Circ J. Apr. 2010;74(4):771-8. [pmid: 20154405].
170 Cinciripini PM, Robinson JD, Karam-Hage M, et al. Effects of varenicline and bupropion sustained-release use plus intensive smoking cessation counseling on prolonged abstinence from smoking and on depression, negative affect, and other symptoms of nicotine withdrawal. JAMA Psychiatry. May. 2013;70(5):522-33. [pmid: 23536105].
171 Gonzales D, Rennard SI, Nides M, et al. Varenicline, an alpha4beta2 nicotinic acetylcholine receptor partial agonist, vs sustained-release bupropion and placebo for smoking cessation: a randomized controlled trial. JAMA. Jul. 5. 2006;296(1):47-55. [pmid: 16820546].
172 Jorenby DE, Hays JT, Rigotti NA, et al. Efficacy of varenicline, an alpha4beta2 nicotinic acetylcholine receptor partial agonist, vs placebo or sustained-release bupropion for smoking cessation: a randomized controlled trial. JAMA. Jul. 5. 2006;296(1):56-63. [pmid: 16820547].
173 Nides M, Oncken C, Gonzales D, et al. Smoking cessation with varenicline, a selective alpha4beta2 nicotinic receptor partial agonist: results from a 7-week, randomized, placebo- and bupropion-controlled trial with 1-year follow-up. Arch Intern Med. Aug. 14. 2006;166(15):1561-8. [pmid: 16908788].
174 White AR, Rampes H, Liu JP, et al. Acupuncture and related interventions for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2011;(1). [pmid: 21249644].
175 Rodgers A, Corbett T, Bramley D, et al. Do u smoke after txt? Results of a randomised trial of smoking cessation using mobile phone text messaging. Tob Control. Aug. 2005;14(4):255-61. [pmid: 16046689].
176 Free C, Whittaker R, Knight R, et al. Txt2stop: a pilot randomised controlled trial of mobile phone-based smoking cessation support. Tob Control. Apr. 2009;18(2):88-91. [pmid: 19318534].
177 Free C, Knight R, Robertson S, et al. Smoking cessation support delivered via mobile phone text messaging (txt2stop): a single-blind, randomised trial. Lancet. Jul. 2. 2011;378(9785):49-55. [pmid: 21722952].
178 Borland R, Balmford J, Benda P. Population-level effects of automated smoking cessation help programs: a randomized controlled trial. Addiction. Mar. 2013;108(3):618-28. [pmid: 22994457].
179 Whittaker R, Dorey E, Bramley D, et al. A theory-based video messaging mobile phone intervention for smoking cessation: randomized controlled trial. J Med Internet Res. 2011;13(1):e10. [pmid: 21371991].
180 Swan GE, McClure JB, Jack LM, et al. Behavioral counseling and varenicline treatment for smoking cessation. Am J Prev Med. May. 2010;38(5):482-90. [pmid: 20409497].
181 Parkes G, Greenhalgh T, Griffin M, et al. Effect on smoking quit rate of telling patients their lung age: the Step2quit randomised controlled trial. BMJ. Mar. 15. 2008;336(7644):598-600. [pmid: 18326503].
182 Bovet P, Perret F, Cornuz J, et al. Improved smoking cessation in smokers given ultrasound photographs of their own atherosclerotic plaques. Prev Med. Feb. 2002;34(2):215-20. [pmid: 11817917].
183 Johnson KM, Lando HA, Schmid LS, et al. The GAINS project: outcome of smoking cessation strategies in four urban Native American clinics. Giving American Indians No-smoking Strategies. Addict Behav. Mar. 1997;22(2):207-18. [pmid: 9113215].
184 Coleman T, Cooper S, Thornton JG, et al. A randomized trial of nicotine-replacement therapy patches in pregnancy. New England Journal of Medicine. Mar. 1. 2012;366(9):808-18. [pmid: 22375972].
185 Wisborg K, Henriksen TB, Jespersen LB, et al. Nicotine patches for pregnant smokers: a randomized controlled study. Obstet Gynecol. Dec. 2000;96(6):967-71. [pmid: 11084187].
186 Kapur B, Hackman R, Selby P, et al. Randomized, double-blind, placebo-controlled trial of nicotine replacement therapy in pregnancy. Curr Ther Res Clin Exp. 2001;62(4):274-8. PMID: None.
187 Hotham ED, Gilbert AL, Atkinson ER. A randomised-controlled pilot study using nicotine patches with pregnant women. Addict Behav. Apr. 2006;31(4):641-8. [pmid: 15985339].
188 Oncken C, Dornelas E, Greene J, et al. Nicotine gum for pregnant smokers: a randomized controlled trial. Obstet Gynecol. Oct. 2008;112(4):859-67. [pmid: 18827129].
189 Pollak KI, Oncken CA, Lipkus IM, et al. Nicotine replacement and behavioral therapy for smoking cessation in pregnancy. Am J Prev Med. Oct. 2007;33(4):297-305. [pmid: 17888856].
190 Cooper S, Taggar J, Lewis S, et al. Effect of nicotine patches in pregnancy on infant and maternal outcome at years: follow-up from the randomised, double-blind, placebo-controlled SNAP trial. The Lancet Respiratory Medicine. Aug. 2014;10(9):728-37. [pmid: 25127405].
191 Tsoi DT, Porwal M, Webster AC. Efficacy and safety of bupropion for smoking cessation and reduction in schizophrenia: systematic review and meta-analysis. Br J Psychiatry. May. 2010;196(5):346-53. [pmid: 20435957].
192 Fucito LM, Bars MP, Forray A, et al. Addressing the evidence for FDA nicotine replacement therapy label changes: a policy statement of the Association for the Treatment of Tobacco use and Dependence and the Society for Research on Nicotine and Tobacco. Nicotine Tob Res. Jul. 2014;16(7):909-14. [pmid: 24919399].
193 Koegelenberg CF, Noor F, Bateman ED, et al. Efficacy of varenicline combined with nicotine replacement therapy vs varenicline alone for smoking cessation: a randomized clinical trial. JAMA. Jul. 9. 2014;312(2):155-61. [pmid: 25005652].
194 Ramon JM, Morchon S, Baena A, et al. Combining varenicline and nicotine patches: a randomized controlled trial study in smoking cessation. BMC Med. 2014;12:172. [pmid: 25296623].
195 Ebbert JO, Hatsukami DK, Croghan IT, et al. Combination varenicline and bupropion SR for tobacco-dependence treatment in cigarette smokers: a randomized trial. JAMA. Jan. 8. 2014;311(2):155-63. [pmid: 24399554].
196 Food and Drug Administration. CHANTIX (varenicline) Label: Efficacy supplement with clinical data to support. Silver Springs, MD. FDA Center for Drug Evaluation and Research. 2013.
197 Food and Drug Administration. ZYBAN (bupropion) Labeling Revision. Silver Springs, MD. FDA Center for Drug Evaluation and Research. 2014.
198 Food and Drug Administration. FDA Drug Safety Communication: Safety review update of Chantix (varenicline) and risk of cardiovascular adverse events. Silver Springs, MD. FDA Center for Drug Evaluation and Research. 2012.
199 Food and Drug Administration. FDA Drug Safety Communication: Safety review update of Chantix (varenicline) and risk of neuropsychiatric adverse events. Silver Springs, MD. FDA Center for Drug Evaluation and Research. 2011.
200 Gibbons RD, Mann JJ. Varenicline, smoking cessation, and neuropsychiatric adverse events. Am J Psychiatry. Dec. 1. 2013;170(12):1460-7. [pmid: 24030388].
201 ClinicalTrials.gov. Study To Evaluate Cardiac Assessments Following Different Treatments of Smoking Cessation Medications In Subjects With and Without Psychiatric Disorders (CATS). www.ClinicalTrials.gov. September 19, 2014.
202 Orr KK, Asal NJ. Efficacy of Electronic Cigarettes for Smoking Cessation. An. Pharmacother. 2014. Aug. 18. [pmid: 25136064].
203 Gualano MR, Passi S, Bert F, et al. Electronic cigarettes: assessing the efficacy and the adverse effects through a systematic review of published studies. J Public Healt (Oxf). 2014. Aug. 9. [pmid: 25108741].
204 McRobbie H, Bullen C, Hartmann-Boyce J, et al. Electronic cigarettes for smoking cessation and reduction. Cochrane Database Syst Rev. Dec. 17. 2014;12. CD010216. PMID:.
205 Etter JF, Bullen C. Electronic cigarette: users profile, utilization, satisfaction and perceived efficacy. Addiction. Nov. 2011;106(11):2017-28. [pmid: 21592253].
206 Cahn Z, Siegel M, et al. Electronic cigarettes as a harm reduction strategy for tobacco control: a step forward or a repeat of past mistakes?. J Public Health Policy. Feb. 2011;32(1):16-31. [pmid: 21150942].
207 Orr MS. Electronic cigarettes in the USA: a summary of available toxicology data and suggestions for the future. Tob Control. May. Suppl 2. 2014;23:ii18-ii22. [pmid: 24732158].
208 Brown CJ, Cheng JM. Electronic cigarettes: product characterisation and design considerations. Tob Control. May. Suppl 2. 2014;23:ii4-ii10. [pmid: 24732162].
209 Dwyer JB, McQuown SC, Leslie FM. The dynamic effects of nicotine on the developing brain. Pharmacol Ther. May. 2009;122(2):125-39. [pmid: 19268688].
210 Chatham-Stephens K, Law R, Taylor E, et al. Notes from the field: calls to poison centers for exposures to electronic cigarettes--United States, September 2010-February 2014. MMWR Morb Mortal Wkly Rep. Apr. 4. 2014;63(13):292-3. [pmid: 24699766].
211 Hajek P, Stead LF, West R, et al. Relapse prevention interventions for smoking cessation. [Review]. Update of Cochrane Database Syst Rev. 2009;(1). CD003999. [pmid: 19160228].
212 National Institute for Health and Care Excellence. Tobacco harm reduction. London. National Institutes for Health and Care Excellence. 2013. PMID: None.
213 Lancaster T, Stead LF, et al. Silver acetate for smoking cessation. Cochrane Database of Systematic Reviews. 2012. [pmid: 22972041].
214 Hajek P, Stead LF, West R, et al. Relapse prevention interventions for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2009;(1). [pmid: 23963584].
215 Dhippayom T, Chaiyakunapruk N, Jongchansittho T. Safety of nortriptyline at equivalent therapeutic doses for smoking cessation: a systematic review and meta-analysis. Drug Safety. 2011;34(3):199-210. [pmid: 21332244].
216 Cahill K, Ussher MH. Cannabinoid type receptor antagonists for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2011;(3). [pmid: 21412887].
217 Boyle R, Solberg L, Fiore M. Use of electronic health records to support smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2011;(12). [pmid: 22161436].
218 Stead LF, Hughes JR. Lobeline for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2012;(2). [pmid: 22336780].
219 Leaviss J, Sullivan W, Ren S, et al. What is the clinical effectiveness and cost-effectiveness of cytisine compared with varenicline for smoking cessation? A systematic review and economic evaluation. Health Technol Assess. May. 2014;18(33):1-120. [pmid: 24831822].
220 SRNT Subcommittee on Biochemical Verification. Biochemical verification of tobacco use and cessation. Nicotine Tob Res. May. 2002;4(2):149-59. [pmid: 12028847].
221 Fiore MC. A clinical practice guideline for treating tobacco use and dependence: 2008 update. A U.S. Public Health Service report. (Clinical Summary). Am J Prev Med. Aug. 2008;35(2):158-76. [pmid: 18617085].
222 Cahill K, Stevens S, Perera R, et al. Pharmacological interventions for smoking cessation: an overview and network meta-analysis. Cochrane Database Syst Rev. 2013;5. CD009329. [pmid: 23728690].
223 Quality, Affordable Health Care for Americans: Immediate Improvements in Health Care Coverage for All Americans. H.R. 3590. December. 24. 2009. PMID: None.
224 Kofman M, Dunton K, Senkewicz M. Implementation of tobacco cessation coverage under the Affordable Care Act: Understanding how private health insurance policies cover tobacco cessation treatments. Washington D.C. Healthy Policy Institute. 2012. PMID: None.
225 American Academy of Family Physicians, et al. Group Letter to Secretary Sebelius re: Comprehensive Cessation Benefit. 2014. PMID: None.
226 U.S.Department of Health and Human Services. FAQs about Affordable Care Act Implementation (Part XIX). 2014. PMID: None.
227 Stotts AL, Northrup TF, Cinciripini PM, et al. Randomized, Controlled Pilot Trial of Bupropion for Pregnant Smokers: Challenges and Future Directions. Am J Perinatol. 2014. Aug. 11. [pmid: 25111040].
228 Combating Tobacco in Military and Veteran Populations. Institute of Medicine. 2009. PMID: None.