# Discussion

## Summary of Evidence

Behavioral counseling interventions for smoking cessation, with or without adjunct pharmacotherapies, are more completely studied than any other single behavioral health topic. Although often reported in our text as “pharmacotherapy” interventions for brevity, it is important to remind readers that these interventions almost always include some level of behavioral support in addition to the medication. This behavioral support level is often minimal and does not differ between treatment and placebo/control groups. Some trials explicitly examine more robust independent interventions (medications plus robust behavioral interventions). We explicitly identify when the behavioral support is intentionally varied as part of the experimental design.

We conducted a review of reviews approach to update the evidence supporting these interventions for three populations: unselected adults, pregnant adult women, and adults with mental health conditions. This approach allowed us to summarize evidence on health outcomes, cessation outcomes, and harms for three main types of pharmacotherapies (NRT in various forms, bupropion SR, and varenicline), nine categories of behavioral interventions, and various combinations of behavioral and pharmacotherapy approaches from 54 relevant systematic reviews. Twenty two of these provided primary review results for specific population-intervention combinations, with more than 800 RCTs represented. We compared review-level results from the other 32 nonprimary reviews relevant to specific population-intervention groups with results from the primary reviews to confirm overall consistency or to supplement findings (as in the case of harms reporting). We supplemented the review of reviews approach by conducting a primary search for trials evaluating the use of ENDS for smoking cessation given the more recent emergence of this technology. We also conducted a bridge search from the last search date of the primary systematic review to locate all recent primary literature related to pharmacotherapy interventions among pregnant women. As part of our a priori review of reviews approach, we specified the conduct of additional primary searching for population-intervention combination such as this one, characterized by a small number of included trials and imprecision in the effect estimate in the primary review.

### General Adult Population

Available evidence on health outcomes among general adults represented a single behavioral intervention (physician advice) with no pharmacological treatment (Table 18). The research field has largely progressed past this research question, recognizing that the health benefits of smoking cessation are already firmly established.3,10 The vast majority of studies reported cessation outcomes as primary outcomes and emphasized improved validity through biochemical verification or more stringent definitions of abstinence.

Table 18 Summary of Evidence for the General Adult Population

Key Question | Intervention | Number of included reviews | Summary of findings | Consistency | Major limitations | Applicability
1: Health outcomes | Pharm | 0 | NA | NA | NA | NA
1: Health outcomes | Combined pharm and behavioral | 0 | NA | NA | NA | NA
1: Health outcomes | Behavioral | 1 | One trial found favorable effects on all-cause and coronary disease mortality and lung cancer incidence and mortality 20 yrs following an intensive behavioral intervention, although results were not statistically significant. | NA | Only 1 review reported the results of 1 intervention in men on health outcomes. Within that trial, the rate of smoking in control group participants declined steadily over the followup period, narrowing the intervention effect. | One trial conducted among civil servant men aged 40-59 yrs in the UK with high risk of cardiorespiratory disease. Intervention took place in the 1970's.
1: Health outcomes | ENDS | 0 RCTs | NA | NA | NA | NA
2: Cessation outcomes | Pharm | 6 | NRT, bupropion SR, and varenicline improve the chances of quitting smoking. Reviews suggested that NRT might increase smoking abstinence at 6 months or longer by 53-68%; bupropion SR by 49-76%; and varenicline by 102-155%. Absolute quit differences averaged 7% for NRT; 8.2% for bupropion SR, and 26% for varenicline. No significant differences between different NRT products and relative rates of abstinence were similar across settings. Using a combination of NRT products increases quitting more than the use of a single NRT product. In general, there were no significant differences between different classes of medications in direct comparisons. | Consistent | Possibility of publication bias but unlikely that the presence of additional studies with lower relative risks would alter the findings given large number of studies and consistency in findings. Trials with pharmaceutical funding have been shown to have slightly higher effect sizes than nonindustry funded studies; given the number of included trials funded by pharmaceutical companies (particularly for varenicline) the magnitude of the effects may be smaller than estimates suggest. | Most of the included studies within each review were conducted in North America and should be applicable to the US health system. Treatment effects appear to be comparable in a range of populations, settings and types of interventions and in smokers with and without other comorbidities. The literature almost exclusively addressed treatment for cigarette smoking, as opposed to the use of other forms of tobacco, so results may not be generalizable to all forms of tobacco.
2: Cessation outcomes | Combined pharm and behavioral | 1 | Combined pharmacotherapy and behavioral interventions increase quit rates by 70-100% compared with no or minimal treatment. | Consistent | May be risk of bias due to lack of blinding of participants.
2: Cessation outcomes | Behavioral | 26 | Health provider advice and counseling, tailored self-help materials, and telephone counseling showed modest but significant increased smoking cessation at 6 or more months relative to controls (18% to 96%). Providing more intense adjunctive behavioral support to smokers receiving pharmacotherapy may increase cessation by 9-24%. Evidence on the use of mobile phone support, internet-based interventions, and complementary and alternative therapies was limited and not definitive. | Consistent | Individual trials may be represented in more than one review and/or meta-analysis. Several of the meta-analyses treated comparisons between different trial arms as separate studies and were not consistent in their reporting or handling of multiple comparisons. Fixed-effects models were used in nearly all meta-analyses.
2: Cessation outcomes | ENDS | 2 RCTs | One trial found no statistically significant difference in biochemically verified abstinence at 6 months between those receiving e-cigs vs nicotine patch or placebo e-cig (n=657). The other trial (n=300) found a borderline statistically significant higher quit rate among those receiving nicotine-containing e-cigs (11%) vs no nicotine e-cigs (4%) at 12 months. | Consistent | Insufficient statistical power to detect differences and differential high loss to followup in both trials (22-40%) | Two trials took place in New Zealand and Italy. Both trials used older models of e-cigs, one of which is no longer available. One trial conducted among smokers not wanting to quit.
3: Adverse events | Pharm | 8 | NRT, bupropion SR, and varenicline are not associated with an increased risk in major CV adverse events. NRT is associated with a higher rate of any CV adverse events largely driven by low-risk events, typically tachycardia. There was a marginal, nonsignificant increase in serious AEs in those taking bupropion SR, but no difference for serious psychiatric AEs. The evidence for the safety of varenicline is still under investigation; one review suggested a 36% increased risk of nonfatal serious AEs among those taking varenicline versus control. | Consistent | Many trials that report cessation effectiveness do no report AEs, particularly CV- or neuropsychiatric-specific AEs. AEs typically measured through passive reporting and therefore susceptible to underreporting. | Likely applicable across settings and populations.
3: Adverse events | Combined pharm and behavioral | 0 | NA | NA | NA | NA
3: Adverse events | Behavioral | 2 | Minor AEs related to ear-acupuncture, ear-acupressure and other auricolutherapy have been reported. AEs related to other behavioral or complementary and alternative therapies have not been documented. | NA | Only 2 reviews assessed AEs related to behavioral interventions; one found no studies that reported AEs. | Limited evidence on harms limits applicability.
3: Adverse events | ENDS | 2 RCTs | Two RCTs reported no serious AEs in either the intervention or control groups related to product use and no difference in the frequency of AEs among study groups. One trial found a higher proportion of serious AEs among the e-cig group vs. the NRT patch group (19.7% vs 11.8%). | Consistent | Insufficient statistical power to detect differences and differential high loss to followup in both trials (22-40%) One study did not report methods for AEs reporting. | Two trials took place in New Zealand and Italy. Both trials used older models of e-cigs, one of which is no longer available.

Abbreviations: ENDS = electronic nicotine delivery system; NA = not applicable; NRT = nicotine replacement therapy; pharm = pharmacotherapy; RCT = randomized controlled trial; SR = sustained release; UK = United Kingdom; US = United States; yrs = years.

Overwhelming evidence suggests that pharmacotherapy, behavioral, and combined pharmacotherapy and behavioral smoking cessation interventions readily available to primary care patients and clinicians can increase biochemically verified quit rates in adults at 6 months or longer followup (Table 18). Based on research involving almost 50,000 individuals, NRT over 1 to 12 months in all forms was effective and increased relative quit rates (mostly defined as continuous abstinence rather than point prevalence) by 53 to 68 percent compared with placebo or no NRT (RR 1.60 [95% CI, 1.53 to 1.68]). The absolute difference in mean cessation rates between the NRT and control groups was 7 percent (17.3% versus 10.3%). Based on research involving about 13,000 individuals, bupropion SR increased relative rates of biochemically verified cessation by about 62 percent at 6-12 months, defined primarily using continuous abstinence measures (RR 1.62 [95% CI, 1.49 to 1.76]). The absolute difference in mean cessation between the bupropion SR and control groups was 8.2 percent (19.7% for bupropion SR versus 11.5% for controls). A smaller body of evidence (n=6,166) comparing varenicline to placebo found relatively larger effects on smoking cessation (RR 2.27 [95% CI, 2.02 to 2.55]), defined stringently as 100 percent biochemically verified continuous abstinence.

Combination pharmacotherapy may also hold some promise. Combination NRT increased the chance of quitting by more than 30 percent compared with a single form of NRT (RR 1.34 [95% CI, 1.18 to 1.51]). This evidence led to recent changes in FDA-approved OTC NRT labeling allowing for the removal of a warning on using more than one NRT product simultaneously.30 Additionally, calls have been made for more explicit statements to be added to FDA labels for NRT that state that the use of longer-acting NRT concomitantly with faster-acting NRT is safe and likely improves quit rates among smokers who smoke 10 or more cigarettes per day.192 In terms of other combinations of drugs, a pooled analysis of four trials found a small, but significant effect favoring NRT plus bupropion SR versus bupropion SR alone; however, adding bupropion SR to NRT versus NRT alone did not suggest a significant benefit in 12 trials. Three recent trials that were not included within our review of reviews found mixed results regarding the effect of combined pharmacotherapy on cessation. Koegelenberg and colleagues reported that the use of varenicline and a NRT patch increased the odds of continuous abstinence at 24 weeks by almost 100 percent compared with varenicline only.193 In contrast, however, Ramon did not find a significant benefit of varenicline plus a NRT patch versus varenicline alone on continuous abstinence at 12 or 24 weeks.194 Ebbert and colleagues found slightly higher rates of prolonged abstinence at 6 months among those receiving bupropion SR plus varenicline versus varenicline alone, although this effect was not evident at 1 year.195

Combined behavioral counseling interventions and pharmacotherapy (primarily one or more forms of NRT or bupropion SR) also resulted in higher cessation rates compared with brief advice or self-help materials. The pooled estimate from a meta-analysis of 40 combined intervention trials (n=15,021) suggested that combined interventions might increase cessation by 66 to 100 percent (RR: 1.82). In a series of a priori subgroup analyses, combined intervention effects were significantly higher in participants from health care settings compared with community volunteers and tended to increase with greater numbers of sessions among interventions with an interpersonal component. No clear evidence was found to support an increased effect for combined interventions with greater total duration of personal contact. A separate review that examined variations in the amount (intensity) of behavioral intervention support in combination with pharmacological interventions among trials in 15,506 general adults found that the incremental effect of additional behavioral support was significant, but small (RR 1.16 [95% CI, 1.09 to 1.24]). Both groups, however, always received the same pharmacotherapy—mostly NRT, with several trials of bupropion SR and one of varenicline—and the incremental difference in intensity between arms was modest, in the neighborhood of 0.5 to 5 hours difference.

Research on behavioral counseling interventions that include no pharmacologic treatments in adults represent a broad range of approaches. These interventions can range from in-person advice and support from physicians and nurses to a plethora of non-face-to-face formats (tailored and nontailored self-help materials, quitlines, outreach telephone counseling, mobile phone interventions, internet interventions). Compared with various controls, behavioral interventions produced modest improvements in relative smoking cessation at 6 or more months (18%-96%). Physician advice, even brief, resulted in a significant relative improvement in quitting smoking compared with usual care (RR: 1.76 [95% CI, 1.58 to 1.96]). These data suggest that many options can effectively aid cessation and a range may provide options amenable to smokers' preferences. Given the small number of studies and heterogeneous findings, more research is needed on the use of nontailored print materials and mobile phones and in particular, text messaging to aid in cessation. The presence of two relatively large trials that show favorable effects of personalized text messages shows particular promise for this new behavioral approach. Similarly, despite a larger body of existing trials, internet-based interventions that involve a large number of participants seeking to quit and that obtain verified outcomes would be very useful.

Trials in general adults have also examined means to enhance motivation through biomedical risk assessment or to provide additional support during cessation through exercise, acupuncture, and hypnotherapy. Biomedical risk assessment had mixed results representing diverse interventions that could not be combined. Results for exercise, acupuncture, and hypnotherapy were not definitive.

NRT, bupropion SR, and varenicline were not generally associated with an increased risk in serious adverse events among the general adult population, including major cardiovascular (CV) adverse events (Table 18). NRT, however, was associated with a higher rate of any CV adverse event, although this was largely driven by low-risk events, typically tachycardia (a well-known risk). These reviews suggested a possible protective effect or very minor harm related to major CV events among users of bupropion SR (RR 0.57 [95% CI, 0.31 to 1.04]), but these analyses were based on a small number of events. Varenicline has been less completely studied for benefits as well as harms than NRT or bupropion SR.

Post-marketing surveillance of both bupropion SR and varenicline has raised concerns regarding their safety related to neuropsychiatric outcomes (including suicide ideation and attempts) as well as for serious CV events for varenicline. Labels for bupropion SR include a boxed warning related to increased risk of suicidal ideation and behavior in individuals taking antidepressants and serious neuropsychiatric events among those taking bupropion SR for smoking cessation.196,197 The FDA issued separate warnings related to varenicline and risk of CV adverse events in 2012^198^ and neuropsychiatric adverse events in 2011.^199^ The varenicline label currently contains a boxed warning related to serious neuropsychiatric events that may occur while taking varenicline or shortly after discontinuation.196 A pooled analysis of 17 Pfizer-sponsored placebo-controlled trials of varenicline (n=8,027) did not find an increased risk from varenicline on rates of suicidal ideation or behavior or neuropsychiatric events, however. Additionally, psychiatric illness was not found to moderate the effect of varenicline safety.200 While there is no boxed warning for varenicline regarding cardiovascular events, the Warnings and Precautions section of the varenicline label includes the results of a meta-analysis that found a nonstatistically significant higher occurrence of major adverse CV events among patients using varenicline, compared with placebo. The FDA is continuing to evaluate the risk of major adverse CV effects through a large safety clinical trial by the manufacturer of Chantix®.201 Continued monitoring of the safety of varenicline is warranted, particularly for neuropsychiatric events.

We found limited evidence on potential harms related to behavioral interventions with only two reviews synthesizing potential harms – one on ear acupuncture and one on hypnotherapy.

### Pregnant Women

Few trials estimated the effects of NRT on infant health outcomes, and our reviews included no trials evaluating other pharmacotherapies (Table 19). Three out of four trials reported fewer cases of preterm birth in the intervention arm, however, with one reporting a statistically significant difference. Higher birth weight in the intervention group was found in the two trials, but the two largest trials had null findings. Longer-term child health outcomes (up to age two) were reported based on followup data from the largest trial. Survival with no impairment was higher for the children of NRT-allocated women (73% versus 65%). Thus, the impacts on infant health outcomes with NRT were sparse, somewhat mixed, but generally favoring no harm or slight benefit.

Table 19 Summary of Evidence for Pregnant Women

Key Question | Intervention | Number of included reviews | Summary of findings | Consistency | Major limitations | Applicability
1: Health outcomes | Pharm | 4 | Limited evidence of NRT on perinatal and child health benefits. Three out of four NRT trials reported fewer preterm births in the intervention group, but only one was statistically less than placebo. Two trials reported higher birth weightin the NRT group; two larger trials found no difference. Followup data from the largest NRT trial found higher rate of ‘survival with no impairment’ at 2 years among children of women assigned to NRT intervention vs placebo (73% vs 65%). No trials of bupropion SR or varenicline among pregnant women. | NA | Rare health outcomes and few trials of NRT limited statistical precision and ability to draw conclusions based on the current evidence. Limited information on the women approached for participation that declined, and low participation rates. | Trials mainly conducted in high-income countries including the US, relevant and applicable. Pharmacotherapy trials were placebo controlled and outcomes based on well-established measures used in routine health care settings, likely applicable results. Given stigma of smoking during pregnancy, challenging to recruit pregnant smokers. Those who disclose smoking status and willing to participate in trials may differ from general population (e.g., motivation to quit).
1: Health outcomes | Behavioral | 3 | Statistically significant benefit of behavioral interventions on mean birthweight, low birthweight, and preterm birth vs usual care or control. | Consistent
2: Cessation outcomes | Pharm | 5 | No statistical evidence of NRT efficacy for validated smoking cessation in late pregnancy, but limited power, and all trials in the direction of benefit (pooled analysis based on 5 placebo-controlled trials). No trials of bupropion SR or varenicline among pregnant women. | Consistent | Limited information on the women approached for participation that declined, and low participation rates.
2: Cessation outcomes | Behavioral | 6 | Pooled estimates of a range of behavioral interventions from 70 studies suggested benefits for validated smoking cessation, with a similar benefit when limited to the most common intervention (counseling). Heterogeneity was moderate for the pooled effect, but there was no evidence of subgroup effects by intervention type, number of intervention components, or outcome ascertainment approach. | Consistent | Limited information on the women approached for participation that declined, and low participation rates.
3: Adverse events | Pharm | 5 | No evidence of perinatal harms from NRT. One trial found a higher rate of cesarean section for women assigned to NRT; followup from the same trial was reassuring for child health outcomes. No trials of bupropion SR or varenicline among pregnant women. | NA | Few trials of NRT and not all reported consistently on health outcomes and adverse events.
3: Adverse events | Behavioral | 1 | No serious adverse events reported. | NA | Inconsistent data collection across trials; most reliant on passive reporting.
3: Adverse events | Behavioral | 1 | No serious adverse events reported. | NA | Inconsistent data collection across trials; most reliant on passive reporting.

Abbreviations:; NA = not applicable; NRT = nicotine replacement therapy; pharm = pharmacotherapy; SR = sustained release; US = United States; vs = versus.

There was evidence of statistically significant infant health benefits from behavioral interventions. The mean birth weight of infants was modestly higher in the intervention group when considered across all types of interventions and when limited to counseling interventions. Consistent with this finding, the risk for low birth weight (< 2500g) and preterm birth were reduced with behavioral interventions. The number of trials reporting outcomes and event rates for stillbirth, VLBW, NICU admissions, and neonatal death were too low to estimate effects with enough precision to draw conclusions.

In terms of the effects of interventions on smoking cessation outcomes, there was considerably more evidence available on the effects of behavioral interventions during pregnancy than for pharmacotherapies (Table 19). Based on pooled data from trials among over 20,000 women, behavioral interventions were effective for smoking cessation in late pregnancy (RR 1.45 [95% CI, 1.27 to 1.64]). Although the most common type of intervention was counseling, trials of financial incentive interventions, feedback, social support, and health education had fairly consistent findings of benefit, including some significant individual trials.

In contrast, there was no evidence of NRT efficacy for validated smoking cessation in late pregnancy based on the currently available evidence (five placebo-controlled trials), although all trials reported slightly more cessation events in the intervention group (Table 19). The low adherence to NRT reported in the trials hinders interpretation of the available evidence. Benefits and harms from exposure to NRT are more difficult to discern when exposure is limited and variable. Additional evidence is expected in the relatively near future since there are three ongoing trials of NRT and three ongoing trials of bupropion SR for smoking cessation among pregnant women. There is also one ongoing trial of varenicline and one ongoing trial of bupropion SR investigating the effects of exposure to these therapies on perinatal health outcomes (Appendix G Table 1).

In terms of harms related to cessation interventions, among pregnant women, while evidence on the health outcomes of NRT are somewhat reassuring, there was limited power to rule out potential rare harms (Table 19). The largest trial of NRT observed higher cesarean section rates for women assigned to NRT compared with placebo (20% versus 15%), and a more recent trial reported a similar, but not statistically significant difference in cesarean section rates (26% versus 22%). While there was no evidence showing differences in rare outcomes such as miscarriage, stillbirth, and neonatal death, these data are limited. A recent NRT trial identified a rise in blood pressure of 0.02 mm Hg per day over the course of pregnancy occurring more commonly in the NRT compared with placebo group (12% versus 8%). This outcome was not assessed in earlier trials. There was no evidence of adverse events related to behavioral interventions among pregnant women.

### Individuals With Mental Health Conditions

Among individuals with mental health conditions, we found evidence from reviews on tobacco cessation interventions for individuals with depression and for individuals with schizophrenia and schizoaffective disorder (Table 20). There was no evidence on the effects of interventions on health outcomes among adults with mental health issues. For depression, intervention effects on smoking cessation were estimated separately for trial evidence from patients with current depression and those with past depression. Neither group provided adequate trial evidence to draw conclusions from pooled estimates on the efficacy of pharmacotherapy. The most common pharmacotherapy tested for patients with current or past depression was bupropion SR. Effects in individual trials were not statistically significant, with the exception of one trial in patients with past depression that included NRT as an adjunct in both study arms. While effects appeared to be fairly consistent, in a beneficial direction, the lack of precision limits interpretation.

Table 20 Summary of Evidence for Individuals With Mental Health Conditions

Key Question | Intervention | Number of included reviews | Summary of findings | Consistency | Major limitations | Applicability
1: Health outcomes | Pharm and/or behavioral | 2 | No evidence on health outcomes related to cessation interventions among individuals with depression. | NA | Some trials were subgroup analyses with post hoc determination of mental health status. | Trials were not all conducted in primary care settings; some were inpatient (especially for schizophrenia/affective disorder).
1: Health outcomes | Pharm and/or behavioral | 2 | Among individuals with schizophrenia, no evidence that bupropion SR worsened mental health outcomes (8 studies). | Consistent (bupropion SR) | Some trials were subgroup analyses with post hoc determination of mental health status. | Trials were not all conducted in primary care settings; some were inpatient (especially for schizophrenia/affective disorder).
2: Cessation outcomes | Pharm and/or behavioral | 4 | Too few trials available to draw conclusions from pooled analysis on pharmacological intervention for smokers with depression. Evidence of benefit of bupropion SR among people with schizophrenia however, results based on few events and participants in the 5 available trials (n=214). | NA | Some trials were subgroup analyses with post hoc determination of mental health status. Few studies, participants, and events, and heterogeneous interventions, limit statistical inference. | Trials were not all conducted in primary care settings; some were inpatient (especially for schizophrenia/affective disorder).
2: Cessation outcomes | Pharm and/or behavioral | 4 | Evidence that addition of a mood management intervention to standard smoking cessation interventions was beneficial for people with current or past depression. | Consistent | Some trials were subgroup analyses with post hoc determination of mental health status. Few studies, participants, and events, and heterogeneous interventions, limit statistical inference. | Trials were not all conducted in primary care settings; some were inpatient (especially for schizophrenia/affective disorder).
2: Cessation outcomes | Pharm and/or behavioral | 4 | Limited evidence of behavioral interventions among schizophrenics. | NA | Some trials were subgroup analyses with post hoc determination of mental health status. Few studies, participants, and events, and heterogeneous interventions, limit statistical inference. | Trials were not all conducted in primary care settings; some were inpatient (especially for schizophrenia/affective disorder).
3: Adverse events | Pharm and/or behavioral | 3 | Limited data available on serious AEs related to cessation interventions among individuals with depression or schizophrenia. Few trials suggested no severe, life-threatening AEs related to pharmacotherapies. | NA | Only 3 studies of pharmacotherapy treatment among individuals with depression reported detailed data on AEs. | Limited evidence on harms limits applicability.

Abbreviations: AE = adverse events; CV = cardiovascular; e-cig = electronic cigarette; ENDS = electronic nicotine delivery system; n = number of participants; NA = not applicable; NRT = nicotine replacement therapy; pharm = pharmacotherapy; RCT = randomized controlled trial; SR = sustained release.

There was far more trial evidence available on the effectiveness of behavioral interventions among smokers with depression. There was evidence of a smoking abstinence benefit at 6 months among current or past smokers with depression with the addition of a mood management component to standard smoking interventions. Results in both populations had low statistical heterogeneity, moderate effect sizes, and adequate precision. Trials of other types of behavioral interventions were too few and were too heterogeneous to allow us to draw conclusions.

We did identify evidence that bupropion SR increased smoking abstinence at 6 months in trials of people with schizophrenia or schizoaffective disorder, but this was based on very few events and few trial participants. There was no evidence on the effects of NRT alone in placebo controlled trials for this patient population. Likewise, three trials of different types of behavioral interventions in this population have also been published, but none provided evidence of a benefit.

The reviews found no severe adverse events attributed to pharmacological smoking cessation interventions among people with depression or schizophrenia, although these data are incomplete. There were no trials of behavioral interventions that suggested harm among those with mental illness.

## Electronic Nicotine Delivery Systems

ENDS are a relatively new product category and none of the specific products have been approved as a cessation intervention by the US FDA. Despite this, knowledge about these nicotine-containing devices may be important for providers who wish to deliver comprehensive tobacco-related counseling to their patients. Our review of two RCTs along with a number of recent systematic reviews83,84,86,87,89,202,203 generally concluded that available data on the use of ENDS for quitting conventional smoking are quite limited and suggest no benefit on smoking cessation among smokers intending to quit. The most recent systematic review on this subject 204 included the same two trials that we summarized, with neither trials suggesting benefit on smoking at 6 months or more. In addition, neither of these two trials nor a number of observational studies included in the recent review reported any serious adverse events considered to be plausibly related to ENDS use. The paucity of trial data on adverse events related to ENDS use is also part of the ongoing debate regarding the appropriateness of their use as a cessation tool.

Most e-cigarette users believe that e-cigarettes are less toxic than conventional cigarettes.205 Despite this belief, the toxicity and safety of e-cigarettes cannot be uniformly determined because of the large variation in devices and cartridge fluids available, and the new products rapidly entering the market. Among the brands that have been tested, levels of toxins have been found to be substantially lower than conventional cigarettes, but limited data are available.66,206,207 While the use of e-cigarettes does not include the inhalation of tar and carbon monoxide, other materials such as metals, plastics, rubber, ceramics, flavors, fibers, and foams that are often used in e-cigarettes can contribute to adverse health effects.208 Furthermore, the potential harms of long-term e-cigarette use are not known. In young people, concerns include the potential negative impact of nicotine on brain development,209 as well as the risk for initiating the use of conventional cigarettes or other tobacco products and nicotine addiction. In addition, the nicotine in the e-liquid can be hazardous if mishandled and can be toxic to children. The number of calls to poison centers involving e-cigarette liquids containing nicotine increased from one per month in September 2010 to 215 per month in February 2014.^210^ The use of e-cigarettes with illegal substances is also a concern. Patents for the devices acknowledge that with no or slight modification, the device can be used with narcotics, steroids, marijuana, and other substances.208

The high rate of dual use of electronic and conventional cigarettes among current e-cigarette users suggests that e-cigarettes are being used to satisfy their nicotine addiction rather than using them as a means for quitting smoking entirely. This is possible because they are allowed in venues where conventional smoking is prohibited. This raises concerns that the public health impact of e-cigarettes as a smoking cessation tool could be minimal whereas widespread e-cigarette use could re-normalize smoking and induce smoking adoption among youth.

Given the variation and current lack of regulatory oversight on the content of e-cigarettes and the limited evidence available from well-designed studies, further research is clearly needed. We identified a number of clinical trials currently under way or planned that address, or will address, the effectiveness and safety of e-cigarettes as a tobacco cessation aid that may be of interest to the USPSTF in the future (Appendix G Table 2).

## Limitations of the Review

Our review has several limitations, including our review of reviews approach, the methods and quality of the included reviews that synthesized the bodies of evidence, as well as the primary studies themselves.

The comprehensiveness of our review of reviews is inevitably limited by the recency and quality of the source reviews. Although most of the primary reviews that served as the basis for the main results included evidence at least through 2012, there may be evidence on particular population and intervention subsets that have been published after each review's last search date. If this occurred, it could contribute to each respective body of evidence not reflecting these newer studies. Given the consistency of the effects within each group over time, however, we expect that any new trials regardless of their sample size and effect estimates would have little bearing on the overall results of this review of reviews. We identified five published protocols for planned or ongoing systematic reviews related to the effectiveness and/or safety of tobacco cessation interventions (Appendix G Table 3). One pending review focuses on the effectiveness and safety of all three first-line pharmacotherapies and/or behavioral interventions among adults; one on combined pharmacotherapy and behavioral interventions among people of all ages; one specifically evaluates the effect of physician advice on smoking cessation, quality of life, and adverse events among people with schizophrenia or related disorders; one only includes adults aged 65 years and older; and the fifth review plans to report neuropsychiatric adverse events related to varenicline. The addition of these reviews, when published, might supplement the results of this review of reviews.

By adopting a review of reviews approach, we relied on the data as described and assessed by the original reviewers. In doing this we trusted that each review generally included the full available and eligible evidence base, that the data abstraction was accurate, and that the analyses were scientifically sound. We used scientific judgment, however, when choosing which reviews to present as the basis for the primary findings and which pooled data were appropriate to present. For instance, although review authors may have presented several pooled analyses based on various subgroups within the main analysis, we carefully chose which data to include in our synthesis based on our a priori questions of interest (e.g., type and intensity of intervention, setting and provider, participant selection, and verification of abstinence measures). We did not reassess the risk of bias or quality of individual trials, instead we reviewed the risk of bias as presented in the review and interpreted results in light of these potential biases. Although we did not quality rate the reviews based on the specific choice of meta-analytic models (i.e., random versus fixed effects), we were cautious about reporting pooled results for small numbers of studies or highly heterogeneous bodies of evidence. We did not present pooled estimates for meta-analyses of less than six studies except in the case of a small number of highly clinically and statistically homogeneous trials (e.g., NRT among pregnant women). We also narratively described results rather than presenting pooled estimates in cases of substantial or considerable statistical heterogeneity produced in meta-analyses. In the absence of review-generated forest plots, we created these plots to illustrate individual study-level results. Nineteen of the 22 primary reviews were Cochrane reviews. The general consistency and rigor of methods employed by authors of these reviews97 strengthen this review of reviews. We quality rated each review according to AMSTAR criteria and relied upon the available best quality reviews for each body of evidence.

We did not describe or cite individual trials because of the large volume of trials represented across the primary reviews (over 800). While we did cite individual trials for descriptive and clarifying purposes, our intent was not to call them out as exemplar interventions or studies. Although our text and descriptive tables provide some information on the types of interventions included in the bodies of evidence, we did not include a detailed description of each intervention or replicate the study characteristics data that were presented by the original review authors. More detailed information is available in the original reviews.

Because the included reviews were not mutually exclusive in their eligibility criteria and, as a result, were not mutually exclusive in their included studies, there are individual trials that are represented in more than one review and/or meta-analysis, particularly for trials related to behavioral interventions in adults. We could not address this overlap by recalculating all of the estimates reported in reviews, but we do not expect such adjustments would alter our conclusions. By basing our estimates on primary reviews rather than reporting results from multiple reviews, we likely mitigated this potential shortcoming.

We focused our review on systematic reviews that included health, cessation, or adverse event outcomes as primary outcomes. We included studies that were applicable to primary care. We did not include reviews or abstract data for other interventions, such as harm reduction, relapse prevention, or non-first-line FDA approved medications. Recent reviews on these subjects do exist, however, and some readers may find these of interest.211-219

Within the individual reviews, there were some limitations in the statistical analyses that are worth noting. In several of the main meta-analyses, for example, authors treated comparisons between different trial arms as separate studies in the analyses and were not consistent in their reporting or handling of multiple comparisons from a single trial in meta-analysis. For instance, a study with two active intervention arms (e.g., group 1 low-intensity and group 2 high-intensity) and one control group (group 3) was often included twice in one meta-analysis (group 1 versus group 3 and group 2 versus group 3). In essence, the control group was represented twice within the analysis, which inflated the total number of control participants and violated the assumption of independent observations. Unless correctly accounted for, this can result in slight overestimation of the precision of the pooled estimate confidence (e.g., a narrower confidence interval). To account for this, we interpreted confidence intervals close to null in these cases cautiously.

In addition, the default Mantel-Haenszel fixed-effect methods of meta-analysis used for most of the primary reviews assumes that the true effect of the intervention (in both magnitude and direction) is the same value in every study (i.e., fixed). The fixed effect model is appropriate if there is reason to believe that all studies are functionally similar (e.g., five studies conducted by the same researchers using the same protocol) and the goal is to compute the common effect that will be generalized to other examples of this same population. Fixed effect models are also used when event rates are low (e.g., ranging from 1% to 5%). In all of our included reviews, however, the participants and interventions differed in ways that could impact the results, and, as a result, one cannot really assume a common effect size. In these cases, random effects models are generally preferable to fixed effects models. Readers should note this limitation when interpreting the results of the pooled analyses.

The two primary reviews related to the effectiveness of NRT and bupropion SR declared potential conflicts of interest of the review authors including being involved in some of the included trials and receiving funds for consultancy work on behalf of the drug sponsors. In addition, review authors identified evidence of possible publication bias in some of the reviews. The review on the effectiveness of NRT among adults by Stead (2012a) and the review on combined pharmacotherapy and behavioral interventions also by Stead (2012b), for example, likely both include publication bias due to unpublished trials of NRT. In both, a funnel plot suggested some evidence of asymmetry with a few small to moderately sized trials finding effects in an unfavorable direction. As the authors of these reviews conclude, however, it is unlikely that the pooled estimates would change substantially if additional smaller studies with lower estimates were included given the large number of trials in these analyses. If this were true, however, the magnitude of effects may be smaller than the estimates we reported from the reviews.

While we did not reevaluate the risk of bias within individual trials, several limitations are applicable to all included studies. Biochemical validation of self-reported quitting ranged from 17 percent to 100 percent of trials within the included reviews. Most of the reviews that had a smaller percentage of included studies that required biochemical validation included a higher percentage of large community-based samples and included limited face-to-face contact (e.g., print-based self-help materials, telephone counseling, and computer-based interventions). It should be noted that the Society for Research on Nicotine and Tobacco subcommittee on measurement considers that verification is not necessary under these conditions.220 It is also important to remember that while the validation of quitting will almost always reduce the absolute quit rate, the absence of validation will only lead to an overestimate of effects if intervention participants are more likely to misreport abstinence than control group participants. The likelihood of differential misreporting is small among those studies of large community-based samples with limited face-to-face contact.

Finally, the mechanism by which adverse events are recorded (generally passively) makes them susceptible to underreporting. As a result, these findings may be less reliable than for those of efficacy.

## Applicability

Most of the included studies within each review were conducted in North America and, as such, should be applicable to the US health system. Most studies enrolled individuals who were all current smokers (or in some cases tobacco users or recent quitters) with varying degrees of baseline smoking (i.e., cigarettes smoked per day) and nicotine dependence. These trials took place within a very wide range of settings using different types of providers and included individuals with smoking-related disease and those with mental health conditions. The literature almost exclusively addressed treatment for cigarette smoking, as opposed to the use of other forms of tobacco, so the results may not be generalizable to all forms of tobacco. The homogeneity of results across interventions and specific populations reflects the general applicability of the evidence. To that end, we believe the body of evidence represented in this review-of-review is very applicable to primary care providers in the US.

## Comparison With 2008 Public Health Service Guideline and Other Related Reviews

The findings of our review of reviews are generally consistent with the 2008 US Public Health Service (PHS) Guideline (stated as Guideline hereafter) that serve as the basis for the current 2009 USPSTF recommendation.3,221 We similarly found consistent evidence of effectiveness among general adults for physician advice to quit; varying formats of behavioral interventions (telephone counseling, individual and group counseling); and all three first-line FDA-approved medications as well as for behavioral interventions among pregnant women. There are, however, a few areas within the Guideline that were not fully addressed in our review of reviews or that were not entirely consistent with our findings.

In addition to strongly recommending use of all first-line FDA-approved medications (NRT, bupropion SR, and varenicline) for cessation, the Guideline also recommended certain combinations of medications including (1) long-term (> 14 weeks) nicotine patch + other NRT (gum or spray); (2) the nicotine patch + the nicotine inhaler; and (3) the nicotine patch and bupropion SR. The included Stead (2012a) review140 found that trials that compared the use of two types of NRT with the use of a single type showed a statistically significantly greater cessation effect. There were only two trials included that reported the direct effect of NRT + bupropion SR versus placebo. One of these trials found a nearly four-fold greater quit rate among those receiving NRT patch and bupropion SR. The other study evaluated NRT lozenge + bupropion SR and found no difference with a placebo group.140

The Guideline concluded a “strong” dose-response relationship between the session length of person-to-person contact and successful treatment outcomes and stated that intensive interventions were more effective than less intensive interventions and should be used whenever possible. Based on their 2000 analysis, the estimated effects (odds ratio [OR]) of trials with 4-30 minutes contact time was 1.9 (95% CI, 1.1 to 1.8); the estimated effects for trials with 31-90 minutes was 3.0 (95% CI, 2.3 to 3.8); and the estimated effects for trials with 91-300 minutes of contact time, compared with minimal controls, was 3.2 (95% CI, 2.3 to 4.6) (PHS Guideline Table 6.9). Similarly, the Guideline concluded that there was a strong relationship between the number of counseling sessions, when combined with medication, and the likelihood of quitting (PHS Guideline Table 6.23). The reviews included in our review of reviews also suggested higher effect sizes among interventions of greater intensity. However, there was no clear evidence to support intervention modification by total number of sessions or duration of personal contact.136,138,139,142 While direct comparisons within trials between intensive versus minimal physician advice suggested an advantage of more intensive advice, this was small to nonexistent among smokers not selected as having smoking-related disease.139

A 2000 meta-analysis within the Guideline also concluded that behavioral smoking cessation interventions that are delivered in multiple formats increase abstinence rates and should be encouraged. For example, they found that treatment that used three or four format types (e.g., self-help materials, individual counseling, telephone support) were especially effective (OR 2.5 [95% CI, 2.1 to 3.0]) (PHS Guideline Table 6.14). We were not able to assess this effect within our included reviews.

All of the interventions that were found to be effective among the general adult population in the Guideline were also recommended for all individuals who smoke, including: those of low socioeconomic status; lesbian/gay/bisexual/transgender smokers; hospitalized smokers; HIV-positive smokers; smokers with medical comorbidities; older smokers; smokers with psychiatric disorders; including substance use disorders; racial and ethnic minorities; and women smokers. Specific groups such as pregnant women are typically excluded from cessation trials among the general adult population, thus, they were covered separately in the Guideline.

For pregnant women, the Guideline recommends that person-to-person psychosocial interventions that exceed minimal advice to quit be offered at the first prenatal visit as well as throughout the course of pregnancy. This recommendation was based on a 2008 meta-analysis that found a 80 percent higher odds of quitting smoking among those taking part in a psychosocial intervention versus usual care (PHS Guideline Table 7.5). The Guideline only included three RCTs of nicotine patch versus placebo among pregnant women—the same three were included in our review of reviews.185,186,189 Based on these three trials, no recommendation was made regarding medication use during pregnancy.

We did not include a number of other topics that were meta-analyzed as part of the PHS Guideline, including: screening for tobacco use; providing tobacco treatment as a health care insurance benefit; nonfirst-line FDA-approved medications; or systems-level interventions. Readers interested in those subjects are encouraged to review data presented in the Guideline. Additionally, because of our approach, we were limited by the included reviews in the extent to which we could comment on the effectiveness of specific intervention characteristics (e.g., intensity of person-to-person clinical contact; type of clinician; types and formats of behavioral treatments; and specific populations).

Our review of reviews differs from another ‘overview of reviews’ conducted by Cahill and colleagues222 on the effectiveness and safety of pharmacotherapies for tobacco cessation in that: we did not limit our inclusion to Cochrane reviews; we included behavioral interventions in addition to pharmacotherapies; we compared numerous reviews for consistency in results; and we included special attention to reviews among pregnant women and those with mental health conditions. Despite these differences, there was some overlap in the findings between our review and the Cahill overview of reviews on pharmacotherapy, with both finding that NRT, bupropion SR, and varenicline were all superior to placebo for smoking cessation and that none of them appear to have a risk of adverse events that would negate their use among the general adult population. This result is probably not surprising given that the Cahill review used the same three Cochrane reviews that served as the basis for our primary results. It is important to note, however, that the version of the review on bupropion SR included in the Cahill review was last updated in 2009 as opposed to the version we used which was updated in 2013.^121^ The Cahill overview review also reported the results of a network meta-analysis, finding increased odds of quitting for all three drugs versus placebo, but also suggesting varenicline may be superior to both NRT and bupropion SR.

In addition, a review of reviews and evidence-based recommendations for prevention of tobacco use and second-hand smoke exposure during pregnancy was recently published by the World Health Organization.12 Their analysis of the effects of smoking cessation interventions primarily relied on earlier versions of the Coleman and Chamberlain reviews that were the basis of the findings in our report. As such, their estimated pooled effects, qualitative results, and synthesis correspond closely to ours – with evidence of benefits for behavioral interventions, but absent or thin evidence on the efficacy or harms of pharmacotherapy for smoking cessation during pregnancy. The World Health Organization report also outlined important research questions to pursue with regard to conducting research and testing interventions on smoking cessation during pregnancy, both for behavioral and pharmacological cessation aids.

## Policy Implications of Tobacco Cessation Evidence

In 2010, the Affordable Care Act (ACA) required all new private health insurance plans to cover preventive services recommended by the USPSTF with an A or B recommendation, with no cost-sharing for the patient.223 As such, the ACA requires that tobacco cessation pharmacotherapy and counseling services be covered at no cost to the patient. Specific sections of the law as they relate to tobacco cessation can be found here: http://www.ctri.wisc.edu/Insurers/HeathReformTobaccoSummary.pdf. When the ACA was passed, the Act required providers to cover tobacco cessation services, but provided little guidance on which services should be covered. This led to concerns that the lack of specificity related to the ACA tobacco cessation benefit would diminish the number of health insurance companies that provided the full range of mandated coverage.

A 2012 review by Georgetown University's Health Policy Institute found significant variation in the implementation of tobacco cessation treatment coverage across private health insurance contracts.224 Only four of the 39 private health plans evaluated clearly covered a full range of evidence-based tobacco cessation services. Contract language contained vague or conflicting terminology that made it impossible to determine which–or even whether–tobacco cessation services were covered and whether there was cost-sharing for these services. None of the 39 reviewed contracts did all of the following: 1) stated clearly that tobacco cessation treatment was a covered benefit (without general exclusions); 2) provided coverage for individual, group, and phone counseling along with FDA-approved tobacco cessation medications; 3) provided tobacco cessation treatments by in-network providers with no cost-sharing; and 4) provided access to treatment without prerequisites, such as medical necessity or health risk assessment.

In response to these concerns, a number of nonprofit organizations prepared a joint letter to the U.S. Department of Health and Human Services (DHHS) asking for clear and comprehensive guidance on the tobacco cessation benefit in the ACA regulations.225 On May 2, 2014, as part of a larger ACA Guidance Document, DHHS released details on what insurers must cover regarding tobacco cessation services.226 Insurers are considered to be in compliance if the plan or issuer covers the following without cost-sharing: screening for tobacco use and, for those who use tobacco products, at least two tobacco cessation attempts per year. Covering a cessation attempt includes coverage for four tobacco cessation counseling sessions of at least 10 minutes each (including telephone counseling, group counseling and individual counseling) without prior authorization and all FDA-approved tobacco cessation medications (including both prescription and OTC medications) for a 90-day treatment regimen, when prescribed by a health care provider without prior authorization.

## Future Research Needs

Our synthesis and source reviews identified a number of areas where more research is warranted. In terms of pharmacotherapy cessation interventions conducted among adults, direct comparisons between different combinations and classes of drugs would be informative (e.g., use of combinations of NRT and bupropion SR versus placebo; NRT versus varenicline, bupropion SR versus varenicline). The evidence base for trials of varenicline, although consistent, is relatively smaller than that of NRT and bupropion SR. Further varenicline trials would also be useful, particularly those that closely monitor harms along with evaluating effectiveness. In contrast, more research on NRT versus placebo is unlikely to change our understanding of the treatment. The incidence of serious adverse events related to all three drugs should be closely monitored and described with greater precision than is currently provided. This includes long-term monitoring of varenicline to clarify the possibility of its implication in neuropsychiatric and cardiovascular events.

It is unlikely that the main findings of our review of reviews would be altered by additional trials of combined pharmacotherapy and behavioral interventions, behavioral support as an adjunct to pharmacotherapy, behavioral advice and counseling by health care providers, and telephone counseling compared with ‘usual care’ or minimal intervention controls. Future research could contribute to further understanding about the effects of various intensities of treatment, particular settings for treatment, or a treatment's effect among specific populations. This could include, for example, identifying the optimal amount of behavioral support to use with pharmacotherapy. Further research focusing on additional ways to personalize and tailor self-help materials and their effectiveness would also be beneficial. Additionally, more research is needed on different types of mobile phone- and internet-based cessation interventions, including text messaging and smartphone applications, which have very high potential applicability.

Among pregnant women, future research on the benefit and safety of NRT is warranted, including an assessment of optimal dosage and timing of treatment. Trials investigating the effects of bupropion SR and varenicline are required, if they are judged to be ethical and feasible. A recent pilot RCT on the safety and efficacy of bupropion SR for smoking cessation during pregnancy identified a number of challenges in the field and lessons to inform future trials.227 Screening of 820 women yielded only 11 women eligible and willing to consent, prompting the authors to recommend large multisite studies of pharmacotherapy. Careful collection of adverse events and systems for deriving long-term consequences of exposure during pregnancy is important in future trials as well. Despite the established importance of NRT for aiding cessation in general populations, it is surprising how few studies of NRT use have been conducted during pregnancy since exposure to nicotine is present with smoking or with NRT. Recent evidence of child health benefits from 2 year followup on the largest NRT trial highlight the importance of further research. For behavioral and NRT interventions, effort to identify and enroll more representative samples of women into trials is needed to ensure intervention effects are observed in less select populations, or to simply report clearly on the characteristics of women approached who declined participation. The effects of smoking cessation interventions on perinatal health outcomes are not recorded uniformly, and future behavioral trials should collect a comprehensive set of key outcomes, similar to those provided in recent NRT trials. Well-powered trials of behavioral therapies that show promise for strong effects could serve to make important contributions to maternal and child health. Although few have been conducted, trials using incentives to aid smoking cessation efforts suggest possibly strong effects, although it is unknown how long-term cessation efforts are affected by this kind of short-term motivation. Different interventions across pregnancy, postpartum, and beyond may also be beneficial and should include longer-term trials that combine multiple interventions in sequence and their consequences for fetal, infant, child and maternal health would be informative.

Evidence on the effectiveness of smoking cessation interventions among individuals with mental health conditions is restricted to only a few small studies. Given the high prevalence of smoking among those with mental illness, continued research on the effects of cessation interventions on health, cessation, and harms outcomes is justified.

As always, replicating promising interventions is a very important method that will strengthen the evidence base and should be supported.

## Conclusion

The extensive evidence on strategies to help people stop smoking reviewed in this report confirms the effectiveness of a range of pharmacological and behavioral interventions, alone and in combination, for smoking cessation in adults. Behavioral interventions are especially applicable to pregnant women and patients with some types of mental health condition. We also identified areas where evidence is thin, but suggestive, and where the current evidence could be bolstered or extended, particularly for adults with serious mental illness and pregnant women. Clinicians have an array of tools to choose from to aid the smoking cessation efforts of their patients, and can directly offer, refer, or prescribe those that their patients find most acceptable, with informed consideration of the likely magnitude of benefits for 6-month cessation and beyond from different behavioral and pharmacological interventions, and their combination.