# Results

## Literature Search

We identified 54 existing systematic reviews that met our eligibility criteria.92,99-146,147-154 Of the 114 full-text articles that were reviewed, the most common reasons for exclusion were study design (i.e., was not a systematic review; k=25), intervention type (e.g., harm reduction interventions, second-line or off-label medications; k=7), and poor-quality rating (k=8) (Appendix B Figure 1; Appendix D). Appendix E lists the eight reviews we excluded for receiving a poor-quality rating and the rationale for this rating.

As described in the methods section, we selected 22 of the 54 included reviews to serve as the basis for the primary findings of this review. We chose these reviews based on their comprehensiveness, appropriateness, and quality ratings. We listed the remaining 32 reviews in the descriptive tables; the results of these reviews were generally consistent in terms of the significance and magnitude of effects in relation to the primary reviews. Table 1 lists all 54 of the included reviews categorized by population and intervention approaches, with other descriptors including quality rating, the month and year through which the search was up-to-date, and the KQs the reviews addressed. This review of reviews addresses discrete populations of interest separately for each KQ: general adult population, pregnant women and adults with mental health conditions. Within each population, results are organized first by KQ and then by subpopulation-intervention specific categories. Within adults, we have general adult populations or specific adult subpopulations in combination with different types of interventions (i.e., pharmacotherapy or behavioral [or some combination of these], and e-cigarettes). Table 1 displays the number of primary reviews for each population-intervention category; primary reviews for each group are indicated with an asterisk.

Table 1 Characteristics of Included Existing Systematic Reviews by Population, Intervention, and Last Search Date (k=54)

Population Intervention Category | Intervention Type | Name of Review | Quality Rating | Specific Intervention or Population | Last Search Date | Number of Included Studies | KQ1: Health Outcomes | KQ2: Cessation | KQ3: Harms
Adults Pharm-Efficacy ESR=6 (Primary=3) | NRT | *Stead, 2012a140 | Good | NRT | July-12 | 150 | | X
Adults Pharm-Efficacy ESR=6 (Primary=3) | Varenicline | *Cahill, 2012^154^ | Good | Varenicline (Nicotine receptor partial agonists) | Dec-11 | 20 | | X | X
Adults Pharm-Efficacy ESR=6 (Primary=3) | Varenicline | Huang, 2012^120^ | Good | Varenicline | Mar-11 | 10 | | X | X
Adults Pharm-Efficacy ESR=6 (Primary=3) | Bupropion SR | *Hughes, 2014^121^ | Good | Bupropion SR (Antidepressants) | July-13 | 66 | | X | X
Adults Pharm-Efficacy ESR=6 (Primary=3) | All Pharm | Mills, 2012^129^ | Fair | NRT, Bupropion SR, Varenicline | Jan-12 | 146 | | X
Adults Pharm-Efficacy ESR=6 (Primary=3) | All Pharm | Tran, 2010^145^ | Fair | NRT, Bupropion SR, Varenicline | Feb-09 | 143 | | X | X
Adults Pharm-Harms ESR=3 (Primary=3) | All Pharm Harms | *Mills, 2014^130^ | Fair | NRT, Bupropion SR, Varenicline harms | Mar-13 | 63 | | | X
Adults Pharm-Harms ESR=3 (Primary=3) | Varenicline Harms | *Prochaska, 2012^135^ | Good | Varenicline harms | Sept-11 | 22 | | | X
Adults Pharm-Harms ESR=3 (Primary=3) | NRT Harms | *Mills, 2010^128^ | Fair | NRT harms | Nov-09 | 92 | | | X
Adults Combined pharm and behavioral ESR=1 (Primary=1) | Combined pharm and behavioral | *Stead, 2012b138 | Good | Combined pharmacotherapy and behavioral support | July-12 | 41 | | X
Adults Behavioral ESR=26 (Primary=11) | Behavioral support as an adjunct to pharmacotherapy | *Stead, 2013a142 | Good | Behavioral support as adjunct to pharmacotherapy | July-12 | 38 | | X
Adults Behavioral ESR=26 (Primary=11) | Behavioral support and counseling | *Rice, 2013^136^ | Good | Nurse support | June-13 | 49 | | X
Adults Behavioral ESR=26 (Primary=11) | Behavioral support and counseling | *Stead, 2013b139 | Good | Physician advice | Jan-13 | 42 | X | X
Adults Behavioral ESR=26 (Primary=11) | Behavioral support and counseling | Carr, 2012^108^ | Good | Interventions in dental settings | Nov-11 | 14 | | X
Adults Behavioral ESR=26 (Primary=11) | Behavioral support and counseling | Cahill, 2010^106^ | Good | Stage-based interventions | Aug-10 | 41 | | X
Adults Behavioral ESR=26 (Primary=11) | Behavioral support and counseling | Hettema, 2010^†,119^ | Fair | Motivational interviewing | June-08 | 23 | | X
Adults Behavioral ESR=26 (Primary=11) | Behavioral support and counseling | Lai, 2010^124^ | Good | Motivational interviewing | NR-08 | 14 | | X
Adults Behavioral ESR=26 (Primary=11) | Behavioral support and counseling | Bodner, 2009^103^ | Fair | Health professional advice | NR | 30 | | X
Adults Behavioral ESR=26 (Primary=11) | Behavioral support and counseling | Mottillo, 2009^131^ | Fair | Counseling | Aug-07 | 50 | | X
Adults Behavioral ESR=26 (Primary=11) | Print-based self-help materials | *Hartmann-Boyce, 2014^118^ | Good | Print-based self-help materials | April-14 | 74 | | X
Adults Behavioral ESR=26 (Primary=11) | Telephone Counseling | *Stead, 2013c141 | Good | Telephone counseling | May-13 | 77 | | X
Adults Behavioral ESR=26 (Primary=11) | Telephone Counseling | *Whittaker, 2012^152^ | Fair | Mobile phone | May-12 | 5 | | X
Adults Behavioral ESR=26 (Primary=11) | Telephone Counseling | Tzelepis, 2011^147^ | Fair | Proactive telephone counseling | Dec-08 | 24 | | X
Adults Behavioral ESR=26 (Primary=11) | Computer-based interventions | *Civljak, 2013^113^ | Good | Internet-based | April-13 | 28 | | X
Adults Behavioral ESR=26 (Primary=11) | Computer-based interventions | Brown, 2013^104^ | Fair | Internet-based, young adults | Feb-11 | 8 | | X
Adults Behavioral ESR=26 (Primary=11) | Computer-based interventions | Chen, 2012^111^ | Good | Computer and electronic aids | Dec-09 | 60 | | X
Adults Behavioral ESR=26 (Primary=11) | Computer-based interventions | Hutton, 2011^122^ | Good | Internet-based | Dec-09 | 21 | | X
Adults Behavioral ESR=26 (Primary=11) | Computer-based interventions | Myung, 2009^132^ | Good | Internet- or computer-based | Aug-08 | 22 | | X
Adults Behavioral ESR=26 (Primary=11) | Computer-based interventions | Shahab, 2009^137^ | Fair | Internet-based | Dec-08 | 11 | | X
Adults Behavioral ESR=26 (Primary=11) | Biomedical risk assessment | *Bize, 2012^102^ | Good | Biomedical risk assessment | June-12 | 15 | | X
Adults Behavioral ESR=26 (Primary=11) | Exercise | *Ussher, 2014^148^ | Fair | Exercise | May-14 | 20 | | X
Adults Behavioral ESR=26 (Primary=11) | Complementary and alternative therapies | *White, 2014^151^ | Good | Acupuncture | Oct-13 | 38 | | X
Adults Behavioral ESR=26 (Primary=11) | Complementary and alternative therapies | Di, 2014^114^ | Good | Acupuncture | Jan-13 | 25 | | X | X
Adults Behavioral ESR=26 (Primary=11) | Complementary and alternative therapies | Cheng, 2012^112^ | Fair | Acupoint stimulation | Mar-11 | 20 | | X
Adults Behavioral ESR=26 (Primary=11) | Complementary and alternative therapies | Tahiri, 2012^144^ | Fair | Alternative therapies | Dec-10 | 14 | | X
Adults Behavioral ESR=26 (Primary=11) | Complementary and alternative therapies | *Barnes, 2010^100^ | Good | Hypnotherapy | July-10 | 11 | | X | X
Adults Electronic nicotine delivery systems^‡^ RCTs=2 | Electronic nicotine delivery systems^‡^ | Bullen, 2013^105^ | Fair | Electronic cigarettes | NA | NA | | X | X
Adults Electronic nicotine delivery systems^‡^ RCTs=2 | Electronic nicotine delivery systems^‡^ | Caponnetto, 2013^107,107^ | Fair | Electronic cigarettes | NA | NA | | X | X
Specific Adult Subpopulations ESR=7 (Primary=0) | Behavioral | Liu, 2013^126^ | Fair | Adapted interventions for ethnic minorities | April-13 | 28 | | X
Specific Adult Subpopulations ESR=7 (Primary=0) | Behavioral | Johnston, 2013^123^ | Fair | Indigenous populations | May-12 | 5 | | X
Specific Adult Subpopulations ESR=7 (Primary=0) | Pharm and Behavioral | Zbikowski, 2012^153^ | Fair | Older adults | June-11 | 13 | | X
Specific Adult Subpopulations ESR=7 (Primary=0) | Pharm and Behavioral | Carson, 2012^109^ | Fair | Indigenous populations | April-11 | 4 | | X | X
Specific Adult Subpopulations ESR=7 (Primary=0) | Pharm and Behavioral | Ebbert, 2011^115^ | Good | Smokeless tobacco users | Oct-10 | 25 | | X
Specific Adult Subpopulations ESR=7 (Primary=0) | Behavioral | Nierkens, 2013^134^ | Good | Adapted interventions for ethnic minorities | April-10 | 5 | | X
Specific Adult Subpopulations ESR=7 (Primary=0) | Behavioral | Villanti, 2010^150^ | Fair | Young adults | Aug-09 | 14 | | X
Pregnant Women ESR=8 (Primary=2) | Pharm | *Coleman, 2012^92^ | Good | Pharm among pregnant women | Mar-12 | 6 | X | X | X
Pregnant Women ESR=8 (Primary=2) | Pharm | Myung, 2012^133^ | Good | Pharm among pregnant women | June-11 | 7 | X | X | X
Pregnant Women ESR=8 (Primary=2) | Behavioral | *Chamberlain, 2013^110^ | Good | Behavioral interventions among pregnant women | Mar-13 | 86 | X | X | X
Pregnant Women ESR=8 (Primary=2) | Behavioral | Filion, 2011^116^ | Fair | Behavioral interventions among pregnant women | June-10 | 8 | | X
Pregnant Women ESR=8 (Primary=2) | Behavioral | Hettema, 2010^†,119^ | Fair | Behavioral interventions among pregnant women | June-08 | 8 | | X
Pregnant Women ESR=8 (Primary=2) | Pharm and Behavioral | Likis, 2014^125^ | Good | Pharm and behavioral interventions among pregnant women | Jan-13 | 59 | X | X | X
Pregnant Women ESR=8 (Primary=2) | Pharm and Behavioral | Su, 2013^143^ | Fair | Pharm and behavioral interventions among pregnant women | Dec-12 | 32 | | X
Pregnant Women ESR=8 (Primary=2) | Pharm and Behavioral | Lumley, 2009^228^ | Good | Pharm and behavioral interventions among pregnant women | June-08 | 72 | X | X | X
Patients with Mental Health Conditions ESR=4 (Primary=2) | Pharm and Behavioral | *Van der Meer, 2013^149^ | Good | Patients with current or past depression | April-13 | 49 | | X
Patients with Mental Health Conditions ESR=4 (Primary=2) | Pharm and Behavioral | *Tsoi, 2013^146^ | Good | Patients with schizophrenia | Oct-12 | 34 | X | X | X
Patients with Mental Health Conditions ESR=4 (Primary=2) | Pharm and Behavioral | Gierisch, 2010^117^ | Fair | Patients with depression | Mar-10 | 16 | | X | X
Patients with Mental Health Conditions ESR=4 (Primary=2) | Pharm and Behavioral | Banham, 2010^99^ | Fair | Patients with severe mental illness | Jan-08 | 8 | X | X | X

* Primary review that served as the basis for the main findings

† Review includes both adults and pregnant women and is listed twice in Table 1

‡ The review of electronic nicotine delivery systems was not based on a review of reviews; we included two RCTs based on a primary search for evidence

Abbreviations: ESR = existing systematic review; k = number of studies; KQ = key question; NR = not reported; NRT = nicotine replacement therapy; Pharm = pharmacotherapy interventions; RCT = randomized controlled trial; SR = sustained release.

## Adults: Results of Included Reviews

Of the 54 included reviews, 43 addressed tobacco cessation interventions among a general adult population. Nine of these reviews evaluated the effectiveness and/or adverse events related to pharmacotherapy120,121,128-130,135,140,145,154 and one addressed combined pharmacotherapy and behavioral interventions.138 An additional 26 reviews addressed behavioral tobacco cessation treatments among adults.100,102-104,106,108,111-114,118,119,122,124,131,132,136,137,139,141,142,144,147,148,151,152 Seven of these 43 reviews focused on specific subpopulations within the general adult population (i.e., ethnic minorities, young adults, older adults, and smokeless tobacco users) and included behavioral and/or pharmacotherapy interventions.109,115,123,126,134,150,153

### Key Question 1 Do Tobacco Cessation Interventions Improve Mortality, Morbidity, and Other Health Outcomes in Current Adult Tobacco Users?

#### Pharmacotherapy Interventions Among Adults

We identified no existing systematic reviews that assessed pharmacotherapy interventions among adults that reported the effects of interventions on mortality, morbidity, or other health outcomes.

#### Behavioral Interventions Among Adults

A single systematic review reported the effect of one behavioral tobacco cessation intervention on health outcomes. This review, conducted by Stead and colleagues (2013a),139 searched for evidence through January, 2013 and included studies assessing the effectiveness of advice from medical practitioners on mortality and morbidity as a secondary outcome. This review's primary outcome was smoking cessation. The review included RCTs that were conducted among adult nonpregnant smokers that compared physician advice interventions with no advice, usual care, or with differing levels of physician advice. The review included one study that reported the effects of a stop smoking intensive intervention that included advice, written materials, and one followup visit on health outcomes among males considered to be at high risk of cardiorespiratory disease (n=1,445).24 Within this study, there were no statistically significant differences in the rates of total mortality, coronary disease mortality, and lung cancer incidence and mortality at 20 years followup. At 33 years followup, there was a significantly smaller number of deaths from respiratory illnesses among intervention versus control participants.25 None of the other reviews reported the effects of tobacco cessation interventions on health outcomes.

### Key Question 2 Do Tobacco Cessation Interventions Achieve Tobacco Abstinence in Current Adult Tobacco Users?

#### Pharmacotherapy Interventions Among Adults

We included six reviews that evaluated the effectiveness of pharmacotherapy interventions on tobacco cessation among current tobacco users (Tables 1 and 2).120,121,129,140,145,154

Table 2 Inclusion Criteria of Included Existing Systematic Reviews on the Efficacy and Adverse Events of Pharmacotherapy Tobacco Cessation Interventions Among Adults, Listed by Primary Review and Intervention Type

Review, Year Quality | Intervention | Comparison | Last Search Date | Number of Included Studies | Funding Source | Study Design^†^ | Population | Outcomes | Followup | Setting
*Stead, 2012a140 Good | NRT | Placebo; no treatment; or different doses of NRT or combinations of NRT | July-12 | NRT: 150 | NR | RCTs or quasi-RCTs | Adult smokers motivated to quit | Smoking abstinence; AEs | ≥6 months | Any
*Hughes, 2014^121^ Good | Antidepressants (Bupropion SR^*^) | Placebo; no treatment; or alternative pharm | July-13 | Total: 90 Bupropion SR: 66 | National Institute on Drug Abuse, NHS Research and Development Program | RCTs | Adult smokers | Smoking abstinence; AEs | ≥6 months | Any
*Cahill, 2012^154^ Good | Varenicline | Placebo; no treatment; or alternative pharm | Dec-11 | Total: 24 Varenicline: 20 | NHS Research and Development Fund | RCTs | Adult smokers | Smoking abstinence; AEs | ≥6 months | Any
Huang, 2012^120^ Good | Varenicline | Placebo or NRT | Mar-11 | Varenicline: 10 | NR | RCTs | Adult smokers | Smoking abstinence; AEs | ≥12 months | Any
Mills, 2012^129^ Fair | NRT, Bupropion SR, Varenicline | Placebo; no treatment; or alternative pharm | Jan-12 | Total: 146 NRT: 87 Bupropion SR: 48 Varenicline: 11 | Pfizer Ltd; Canadian Institutes of Health Research | RCTs | Adult smokers | Smoking abstinence | ≥ 3 months | Any
Tran, 2010^145^ Fair | NRT, Bupropion SR, Varenicline | Placebo or alternative pharm | Feb-09 | Total: 143 NRT: 102 Bupropion SR: 23 Varenicline: 10 Combined: 11 | Health Canada; government funded | RCTs | Adult smokers; special populations (e.g. pregnant women, mental illness, CVD) | Smoking abstinence; any treatment-related comorbidity; serious AEs | ≥6 months | Any
*Mills, 2014^130^ Fair | NRT, Bupropion SR, Varenicline | Placebo | Mar-13 | Total: 63 NRT: 21 Bupropion SR: 28 Varenicline: 18 | NR | RCTs | Adult smokers | Cardiovascular AEs | Any followup accepted | NR
*Mills, 2010^128^ Fair | NRT | Placebo or standard of care | Nov-09 | NRT: 92 | Pfizer Ltd; Canadian Institutes of Health Research | RCTs & observational studies | Adult smokers | AEs | ≥1 month | Any
*Prochaska, 2012^135^ Good | Varenicline | Placebo | Sept-11 | Varenicline: 22 | National Institute on Drug Abuse and the State of California Tobacco-Related Disease Research Program | RCTs | Adult smokers | Serious cardiovascular AEs | Within 30 days of treatment discontinuation | Any

* Review served as basis for primary finding

† Quasi-RCTS are those that use quasi-random methods of assignment including alternation, date of birth, or medical record number

Abbreviations: AE = adverse event; CVD = cardiovascular disease; NHS = National Health Service; NR = not reported; NRT = nicotine replacement therapy; Pharm = pharmacotherapy; RCT = randomized controlled trial; SR = sustained release.

##### Nicotine Replacement Therapy

Three reviews evaluated the evidence for the effectiveness of NRT on smoking cessation.129,140,145 The most recent good-quality review, conducted by Stead (2012a),140 systematically searched for evidence through July, 2012. This review included RCTs or quasi-RCTs that compared NRT (including chewing gum, transdermal patches, nasal and oral spray, inhalers and tablets or lozenges) with placebo or no NRT control among adult smokers who were motivated to quit. Two other fair-quality reviews, conducted by Mills129 and Tran,145 also evaluated evidence related to the effectiveness of NRT for smoking cessation, searching through January, 2012 and February, 2009, respectively (Table 2). We used the Stead (2012a) review as the basis for the primary evidence of NRT effectiveness because of its comprehensiveness and quality. The Stead review included most of the included evidence in the Mills129 and Tran145 reviews (Appendix C Figure 1).140

Stead (2012a) included 150 RCTs that ranged in size from fewer than 50 to over 3,500 participants (median: 240) (Table 3). The included trials generally recruited individuals who smoked at least 15 cigarettes a day and the average number of cigarettes smoked was over 20 per day in most studies. The majority of the studies took place in North America (k=77) or Europe (k=60). The primary analysis (i.e., the efficacy of one or more types of NRT compared with a placebo or a control group receiving no NRT) consisted of 117 trials reporting122 comparisons among 51,265 participants (Table 4). Of these 117 studies, 55 trials evaluated nicotine gum, 43 trials evaluated transdermal nicotine patch, six evaluated an oral nicotine tablet or lozenge, five evaluated offering a choice of products, four evaluated intranasal nicotine spray, four evaluated nicotine inhaler, one evaluated oral spray, one evaluated providing patch and inhaler, and one evaluated providing patch and lozenge. Seventy-five percent of the 55 trials that compared nicotine gum to a control provided the 2 milligram (mg) dose, while the remaining trials provided 4 mg. The treatment periods were usually 2 to 3 months, but ranged from 3 weeks to 12 months. Many of the trials included a variable period of dose tapering, but most encouraged participants to be gum-free by 6 to 12 months. Among the nicotine patch trials (k=43), the typical maximum daily dose was 15 mg for a 16-hour patch, or 21 mg for a 24-hour patch. Eight trials directly compared a higher dose patch to a standard dose patch. The minimum duration of therapy ranged from 3 weeks to 3 months. In the nicotine tablet or lozenge studies (k=6), three trials used 2 mg tablets, one trial used a 1 mg lozenge, and two trials used 2 mg or 4 mg lozenges. Doses were allotted according to participants' dependence levels or time to first cigarette of the day. Nine of these trials compared combinations of two forms of nicotine treatment with only one form and five trials directly compared a NRT product with bupropion SR. In terms of the treatment settings, 69 of the 150 trials included members of the community who volunteered in response to media advertisements who were treated in clinical settings. Twenty three trials were conducted in a primary care or similar setting in which smokers were typically recruited in response to a specific invitation from their doctor. The remaining trials were conducted in antenatal clinics, specialized smoking cessation clinics, hospitals, or in settings designed to resemble OTC use of NRT.

Table 3 Descriptive Characteristics of Included Studies Within the Primary Reviews on the Efficacy and Adverse Events of Pharmacotherapy Tobacco Cessation Interventions Among Adults, as Listed in Text

Review, Year | Number of Included Studies | Sample Size (Range) | Demographic Characteristics | Baseline Smoking Status | Readiness to Quit/ Quit History | Intervention Characteristics | Treatment Setting/Provider Characteristics
Stead, 2012a140 | NRT: 150 | <50 to >3,500 (Median: 240) | Average age (range): 40-50; 1 trial in adolescents Sex (% female): Most trials had equal female and male participants. 1 trial in only males; 4 in only women; and 4 in only pregnant women. Race: Recruited African American smokers (k=2) SES: NR Comorbidities:; - Alcohol-dependent participants or those with history of alcohol dependence (k=3); - History of cardiac disease (k=1) | Smoking status: Trials typically recruited people who smoked at least 15 cigs/day. Average number smoked per day was over 20/day in most studies.1 trial recruited relapsed smokers. Nicotine dependence: NR consistently | Readiness to quit: NR consistently Quit history: NR consistently | Nicotine gum (k=55) Transdermal nicotine patch (k=43) Oral nicotine tablet or lozenge (k=6) Choice of products offered (k=5) Intranasal nicotine spray (k=4) Nicotine inhaler (k=4) Oral spray (k=1) Patch and inhaler (k=1) Patch and lozenge (k=1) | Setting: Medical clinics, primary care, antenatal clinics, smoking clinics, hospitals, OTC community volunteers Providers: NR
Hughes, 2014^121^ | Bupropion SR: 66 | 15 to 1524 | Average age (range): 36 to 56; 2 studies included adolescents Sex (% female, range):16 to 100; 2 studies included males only Race:; - Recruited African American smokers only (k=2); - Recruited Maori smokers only (k=1); SES: NR Comorbidities/other substance abuse:; - Depression (current) (k=2) *Most of the bupropion SR trials excluded participants with current depression but not those with a history of depression.; - COPD (k=3); - Schizophrenia (k=5); - PTSD (k=1); - Cancer (k=1); - Suspected tuberculosis (k=1); - Alcoholism (k=2); - CVD (k=4) | Smoking status: 5 to 37 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: NR consistently Quit history: NR consistently | 66 studies included:; - 44 evaluated bupropion SR as a single pharmacotherapy to assist initial cessation; - 12 tested bupropion SR as an adjunct to NRT; Other studies made direct comparisons between bupropion SR and NRT, bupropion SR and nortriptyline, bupropion SR and varenicline | Setting: Variety of health care settings including community-based clinics, outpatient clinics, cessation clinics, universities, and mental health clinics Providers: NR
Cahill, 2012^154^ | Varenicline: 20 trials | 32 to 1,202 | Average age (range): 39 to 57 Sex (% female, range): 3 to 67 Race (% white, range): 68 to 93 SES: NR Comorbidities/other substance use: 1 study in smokers with schizophrenia or schizoaffective disorders; 2 studies included patients with CVD | Smoking status:19.6 to 28 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: NR consistently Quit history: NR consistently | 20 RCTs of varenicline; - 15 double-blinded RCTS evaluated varenicline for smoking cessation; - 1 single-blinded RCT compared varenicline plus counseling with counseling alone in patients admitted to hospital for smoking-related acute illnesses; - 2 open-label RCTs compared varenicline with NRT but without a placebo arm; - 1 RCT evaluated varenicline as an aid to relapse prevention; - 1 RCT gave varenicline to all the participants but delivered behavioral support either online or by telephone or both | Setting: NR Providers: NR
Mills, 2010^128^ | 120 | 7 to 1,429 (RCTs) 22 to 65,599 (obs) | Average age: NR Sex (% female): NR (4 RCTs in pregnant women, 1 in postmenopausal women) Race: NR SES: NR Comorbidities/other substance use:; - Conducted in populations with medical and psychiatric comorbidities (e.g., smoking-related diseases, chronic diseases, alcoholism, depression) (k=6); - Conducted in adult populations with medical comorbidities (k=2) | Smoking status: (observational studies) >10 to 35 (average cpd range) Nicotine dependence: (observational studies) Range: 1 to 50 yrs | Readiness to quit: In the majority of studies, participants were “planning on quitting.” Quit history: NR consistently | Evaluated all types of NRT. 120 studies included. RCTs: 92 RCTs; 83 placebo controlled Patch (k=42) Gum (k=26) Spray (k=6) Inhaler (k=6) Tablet (k=4) Lozenge (k=1) NRT combination (k=35) *59 RCTs included co-interventions Counseling (k=20) Behavioral or psychological treatment (k=19) Advice (k=12) Education (k=3) Additional NRT/placebo (k=4) Rimonabant (appetite suppressant) (k=1) Observational: Patch (k=17) Spray (k=2) Gum (k=1) NRT combination (k=8) *Majority of obs studies included co-interventions Counseling (k=12) Behavior/behavior modification (k=3) Education (k=3) Self-help booklet (k=1) | Setting: NR Providers: NR
Mills, 2014^130^ | 63 | 32 to 3,296 | Average age: 60.1 years Sex (% female, range): 0 to 100 Race: NR SES: NR Comorbidities/other substance use:; - Patients with CVD (k=8); - Patients with COPD (k=4); - Perioperative patients (k=1) | Smoking status: ≥10 to 31 (average cpd range) Nicotine dependence: ≥1 to 51 years | Readiness to quit: NR consistently Quit history: NR consistently | 63 trials included:; - NRT vs placebo (k=19); - Bupropion SR vs placebo (k=27); - Varenicline vs placebo (k=18); - High-dose NRT vs placebo (k=1); - Combination NRT vs control (k=1); - Bupropion SR vs varenicline (k=2); - Bupropion SR vs NRT (k=3); - Varenicline vs NRT (k=1) | Setting: NR Providers: NR
Prochaska, 2012^135^ | 22 | 31 to 1,210 (median 404) | Average age: NR Sex (% female, range): 0 to 51 Race (% white, range): 0 to 99.3 SES: NR Comorbidities/other substance use:; - Patients with current or past CVD (k=13) | Smoking status: 17.1 to 24.4 (average cpd range); mean 21.5 Nicotine dependence: 16.9 to 40.5 years; mean 25.1 | Readiness to quit: NR consistently Quit history: NR consistently | 22 trials included—all varenicline vs. placebo | Setting: NR Providers: NR

Abbreviations: cigs = cigarettes; COPD = Chronic Obstructive Pulmonary Disease; cpd = cigarettes per day; CVD = cardiovascular disease; k = number of studies; NR = not reported; NRT = nicotine replacement therapy; obs = observational; OTC = over the counter; RCT = randomized controlled trial; SES = socioeconomic status; SR = sustained release; yrs = years.

Table 4 Summary of Tobacco Abstinence Results (KQ 2) From Reviews of Pharmacotherapy Tobacco Cessation Interventions Among Adults

Review, Year | Intervention | Control | k | N | Abstinence Measures^*^ | Followup | IG Events | IG N | IG Quit Rate^†^ | CG Events | CG N | CG Quit Rate^†^ | Risk Ratio^‡^ | 95% CI | I^2^
Stead, 2012a140 | NRT, all forms | Placebo or no NRT^‖^ | 117 | 51,265 | 57% CA 87% BV | ≥6 months^§^ | 4,704 | 27,258 | 17.3% | 2,466 | 24,007 | 10.3% | 1.60 | 1.53, 1.68 | 30%
Stead, 2012a140 | NRT, gum | Placebo or no NRT^‖^ | 56 | 22,581 | 55% CA 82% BV | ≥6 months^§^ | 1,732 | 10,596 | 16.3% | 1,196 | 11,985 | 10.0% | 1.49 | 1.40, 1.60 | 40%
Stead, 2012a140 | NRT, patch | Placebo or no NRT^‖^ | 43 | 19,586 | 58% CA 88% BV | ≥6 months^§^ | 1,873 | 11,746 | 15.9% | 766 | 7,840 | 9.8% | 1.64 | 1.52, 1.78 | 19%
Stead, 2012a140 | NRT, tablets/lozenges | Placebo or no NRT^‖^ | 7 | 3,405 | 29% CA 100% BV | ≥6 months^§^ | 337 | 1,808 | 18.6% | 134 | 1,597 | 8.4% | 1.95 | 1.61, 2.36 | 24%
Stead, 2012a140 | Two forms of NRT (dual) | One form of NRT | 9 | 4,664 | 67% CA 89% BV | ≥6 months^§^ | 368 | 1,785 | 20.6% | 448 | 2,879 | 15.6% | 1.34 | 1.18, 1.51 | 34%
Hughes, 2014^121^ | Bupropion SR | Placebo or no bupropion SR^¶^ | 44 | 13,728 | 77% CA 95% BV | ≥6 months | 1,507 | 7,646 | 19.7% | 701 | 6,082 | 11.5% | 1.62 | 1.49, 1.76 | 18%
Hughes, 2014^121^ | Bupropion SR | Placebo or no bupropion SR^¶^ | 17 | 3,862 | 59% CA 100% BV | 6 months | 483 | 2,202 | 21.9% | 200 | 1,660 | 12.0% | 1.69 | 1.45, 1.97 | 0%
Hughes, 2014^121^ | Bupropion SR | Placebo or no bupropion SR^¶^ | 27 | 9,866 | 81% CA 93% BV | 12 months | 1024 | 5,444 | 18.8% | 501 | 4,422 | 11.3% | 1.59 | 1.44, 1.76 | 39%
Cahill, 2012^154^ | Varenicline | Placebo^#^ | 14 | 6,166 | 100% CA 100% BV | ≥6 months^§^ | 954 | 3,412 | 28.0% | 331 | 2,754 | 12.0% | 2.27 | 2.02, 2.55 | 63%

* Used strictest available criteria to define abstinence (i.e., continuous, sustained, or prolonged abstinence was preferred over point prevalence abstinence and biochemically validated rates were used where available). “Continuous abstinence” reflects reviews that reported outcomes as continuous (completely abstinent from quit date with 0-5 cigarettes during that time), “sustained” abstinence (not defined), or prolonged abstinence (allowing a grace period following the quit date to allow for lapses).

† Weighted average quit rate

‡ Pooled risk ratios estimated using the Mantel-Haenszel fixed-effects model

§ Longest followup time point reported

‖ The control group in 25/117 trials did not have a matched placebo control; findings were not sensitive to the exclusion on non-placebo controlled studies

¶ The control group in 3/44 trials did not have a matched placebo control.

# The control group in 1/14 included trials did not have a matched placebo control; a sensitivity analysis excluding it made no appreciable difference to the overall estimate.

Abbreviations: BV = biochemically verified; CA = continuous abstinence; CI = confidence interval; CG = control group; IG = intervention group; k = number of studies; N = number; NRT = nicotine replacement therapy; SR = sustained release.

Considering any form of NRT compared with placebo or no NRT, the pooled risk ratio (RR) for abstinence was 1.60 (95% CI, 1.53 to 1.68; I^2^=30%; k=117; n=51,265) at 6 months or more followup (Table 4; Appendix F Figure 1). Overall, 17.3 percent of participants who received some type of NRT achieved abstinence at 6 months or longer (range 2.9% to 60.0%), compared with 10.3 percent of control participants (range 1.1% to 46.0%). All forms of NRT, including choice of NRT, significantly increased the rate of smoking cessation compared with placebo or no NRT. No significant differences were found between the different NRT products through meta-regression. Six included trials155-160 directly compared different types of NRT (e.g., patch versus nasal spray) and none found statistically significant differences in quit rates. Biochemical validation of self-reported quitting was used in almost all trials (87%). The main findings were not sensitive to excluding trials that did not attempt to validate self-reported cessation. Twenty-five of the 117 trials in the main analysis did not have matched placebo control; however, the findings were not sensitive to the exclusion of these studies.

Nine trials that compared the use of two types of NRT with use of a single type showed a statistically significantly greater cessation effect in pooled analysis (RR 1.34 [95% CI, 1.18 to 1.51]; I^2^ =34%; n=4,664) (Table 4; Appendix F Figure 2). The trials were clinically heterogeneous in the combinations and comparisons used. Two of the trials, one comparing nasal spray and patch with patch alone, and one comparing patch plus lozenge compared with either alone showed a significantly higher rate of continuous abstinence at 1 year with the combined NRT treatment. The other seven trials generally favored combined NRT use versus single form NRT, though they were not statistically significant.

Two studies included within the Stead (2012a) review140 reported the direct effects of the combination of NRT and bupropion SR versus placebo. Jorenby and colleagues161 compared quit rates among those randomized to nicotine patch plus bupropion SR with those receiving placebo and found a nearly 4-times greater quit rate among those receiving NRT and bupropion SR (RR: 3.99 [95% CI, 2.03 to 7.85]; n=405). The study by Piper and colleagues157 did not identify a difference between those receiving NRT lozenge and bupropion SR (n=262) versus placebo (n=37) (RR: 1.54 [95% CI, 0.81 to 2.90]; n=299).

Indirect comparisons of studies based on the type of setting in which smokers were recruited or treated showed that relative rates of abstinence were similar across settings. The pooled RR for trials conducted in primary care was 1.52 (95% CI, 1.34 to 1.71; I^2^=9%; k=23, n=11,705). Quit rates among the control groups, however, differed by setting. The lowest quit rate, for example, was found in a trial that provided community volunteers treatment in an OTC setting (2.1%). The highest quit rate (12.1%) was found in a study conducted in smoking clinics. Control-group quit rates were 5.7 percent in primary care settings, 9.5 percent in community volunteers receiving treatment in a medical setting, and 10 percent in those receiving care in hospitals.

The Stead (2012a) review140 also provided data on indirect and direct comparisons for subgroups based on the level of behavioral support provided to all participants and the dose, duration, and scheduling of nicotine gum and patch. Relative risk estimates were similar across subgroups receiving low-intensity support, high-intensity individual support, and high-intensity group support among both the nicotine patch and gum trials. The other comparisons were based on relatively small subsets of studies and were not the primary focus of this review. Despite this, this information may be of interest to specific readers.140

##### Bupropion

We included three reviews that addressed the effectiveness of bupropion SR on smoking cessation (Table 1).121,129,145 Of the three reviews, the good-quality Hughes (2014) review121 included the most up-to-date (July 2013) and comprehensive evidence on the effectiveness of bupropion SR. As such, we chose to use this review as the basis for the primary evidence. While the inclusion and exclusion criteria for the other two reviews by Mills129 and Tran145 were generally consistent with the Hughes review (Table 2), neither of these reviews were as comprehensive or up-to-date (Appendix C Figure 2).

The Hughes (2014) review assessed the effects of antidepressant medications, including bupropion SR, on smoking cessation rates at followup at least 6 months following initiation of treatment.121 We did not include evidence on other antidepressant medications, such as nortriptyline or citalopram, from the Hughes review as they are not U.S. FDA-approved for smoking cessation. For smoking cessation outcomes, the Hughes review required RCTs to compare bupropion SR with placebo or another non-bupropion SR control, or compare different dosages of bupropion SR. The authors excluded trials in which all participants received the same bupropion SR treatment but received different behavioral support.

The Hughes review (2014)121 included 66 studies that evaluated the effects of bupropion SR on smoking cessation (Table 3). The majority of trials (77%) were conducted in North America. Twenty-nine of the included trials recruited special populations, such as individuals with comorbid health conditions (e.g., chronic obstructive pulmonary disease, schizophrenia, cardiovascular disease), adolescents, specific racial and ethnic groups (African American, Maori), or those who had previously failed to quit smoking using bupropion SR or NRT.

The main analysis in the Hughes review included 44 trials that evaluated smoking cessation after 6 months or more in those taking bupropion SR versus those taking a placebo or no pharmacotherapy. The pooled risk ratio was 1.62 (95% CI, 1.49 to 1.76; k=44; n=13,728) with little evidence of heterogeneity (I^2^=18%) (Table 4; Appendix F Figure 3). Quit rates ranged from 4 percent to 43 percent (19.7% weighted mean) among those receiving bupropion SR and from 0 percent to 33 percent (11.5% weighted mean) among those in the control groups. There was no statistically significant difference among trials that reported cessation outcomes at 6- months versus 12-months followup. The majority of included studies were based on continuous abstinence measures that were biochemically validated (Table 4). Ninety-three percent (41/44) of the trials were placebo controlled. Almost all included studies (43 of 44) randomized intervention participants to the recommended dose of bupropion SR at 300 mg daily (150 mg twice per day). Treatment duration ranged from 7 weeks to 26 weeks. Two studies compared the effectiveness of 300 mg versus 150 mg daily doses and found no differences in quit rates at 12 months.162,163

The effects of bupropion SR were found to be similar regardless of treatment or recruitment setting (i.e., community volunteer and individuals recruited from health care settings) in post hoc indirect comparisons. Similarly, no difference in cessation effects was evident when comparing trials that included intensive group-based behavioral interventions to those that provided intensive individual-level behavioral interventions for both the intervention and control groups. None of the three studies that used factorial designs to compare the effects of bupropion SR with varying levels of behavioral support found evidence that the efficacy of bupropion SR varied between lower and higher levels of behavioral support or by type of counseling approach provided (i.e., individual-based cognitive behavioral therapy versus group therapy).164-166

##### Varenicline

We included four reviews that analyzed the effect of varenicline on smoking abstinence (Table 1).120,129,145,154 All four reviews included nearly identical bodies of evidence (Appendix C Figure 3). The fair-quality review by Mills (2012)129 and the good-quality review by Cahill (2012)154 searched for literature through January 2012 and December 2011, respectively. Given the quality and comprehensiveness of the Cahill review, and the lack of detail on specific exclusions and lack of forest plots presented in the Mills review, we chose the Cahill review as the primary review. The Cahill review evaluated the effectiveness and adverse events for three nicotine receptor partial agonists (i.e., varenicline, cytisine, dianicline) for smoking cessation. We examined the effects and safety of varenicline alone because the other agents are not FDA-approved.

The Cahill (2012) review included 20 RCTs among adult smokers that evaluated the efficacy of varenicline at least 6 months after beginning treatment (Table 2). Fourteen studies were included in the main analysis comparing quit rates among those receiving varenicline versus a placebo or a no varenicline control. A meta-analysis of these 14 studies found varenicline had a statistically significant benefit on smoking cessation at 6 or more months followup compared with placebo. The pooled RR was 2.27 (95% CI, 2.02 to 2.55; I^2^=63 percent; k=14; n=6,166) (Table 4; Appendix F Figure 4) based on biochemically validated rates of continuous abstinence. Quit rates ranged from 14 percent to 47 percent (28.0% weighted mean) among those receiving varenicline and from 4 percent to 28 percent (12.0% weighted mean) among those in the control groups. The statistical heterogeneity (I^2^=63%) was reduced to zero and the effect estimate increased to 2.74 (95% CI, 2.37 to 3.18) in a sensitivity analysis that excluded four of five studies that had control quit rates above 20 percent. It is not clear; however, why one study with a control group quit rate of 22 percent remained in the sensitivity analysis. Thus, we emphasize the pooled results for all 14 studies while acknowledging the moderate statistical heterogeneity.

Treatment duration for included studies was 12 weeks in all but one trial, which had a 6 week treatment duration. The majority of studies randomized participants to the standard dose of 1 mg of varenicline taken twice per day, although one study prescribed 0.5 mg varenicline from one to four tablets per day ad lib depending on smokers' symptoms. Two studies that compared lower doses of varenicline versus placebo found statistically significant benefit of 1.35 mg daily and 0.5 mg twice daily, compared with placebo.

##### Combination Pharmacotherapy vs. Monotherapy

Combined NRT vs. single NRT. As stated above, combination NRT (i.e., the use of two types of NRT) was found to be superior to a single form of NRT in nine direct comparisons (RR 1.34 [95% CI, 1.18 to 1.51]; k=9; I^2^ =34%; n=4,664) (Table 4; Appendix F, Figure 2).

NRT plus bupropion vs. NRT. A pooled estimate of 12 studies that directly compared adding bupropion SR to NRT versus NRT alone did not suggest a significant benefit of this combination of drugs versus NRT alone (RR: 1.19 [95% CI, 0.94 to 1.51], though studies were clinically and statistically heterogeneous.121

Bupropion plus NRT vs. bupropion. A pooled analysis of four trials157,159,161,167 found a modest, significant effect favoring NRT plus bupropion SR versus bupropion SR alone (RR 1.24 [95% CI, 1.06 to 1.45]; I^2^=57%; n=1,991).140

##### Direct Comparisons of Nicotine Replacement Therapy, Bupropion, and Varenicline

All three of the primary reviews for pharmacotherapy121,140,154 included trials with direct comparisons of different tobacco cessation medications. We present the results of those direct comparisons below.

NRT vs. bupropion. Hughes121 included eight studies that directly compared NRT (different forms) with bupropion SR. The Stead review140 also evaluated five of these eight studies. Both of these reviews reported no statistically significant difference between these two pharmacologic modalities for cessation rates measured at least 6 months after followup. For example, the pooled effect size of eight trials within the Hughes review that compared any form of NRT to bupropion SR was 0.96 (95% CI, 0.85 to 1.09; I^2^=27%, k=8; n=4,086).121 The Hughes review also (2014) included two studies that compared participants that received two forms of NRT (patch and lozenge) with a control receiving bupropion SR and found slightly more benefit of the two forms of NRT.157,159

NRT vs. varenicline. Cahill and colleagues154 included two open-label RCTs168,169 that directly compared varenicline with nicotine patch. One was a small trial (n=32) conducted by Tsukahara and the other was a larger trial conducted by Aubin (n=746). Neither study found a statistically significant difference in rates of point prevalence abstinence at 24 weeks between participants receiving varenicline versus nicotine patch. The Aubin trial reported a larger benefit for varenicline over the nicotine patch, although not statistically significant, for biochemically validated continuous abstinence at 1 year.

Bupropion vs. varenicline. The review by Hughes121 included four studies170-173 that directly compared the effects of bupropion SR versus varenicline on tobacco cessation. All four studies showed more favorable effects for varenicline compared with bupropion SR, though not all were statistically significant. A pooled estimate of the four trials found a significantly lower rate of quitting with bupropion than varenicline (RR: 0.68 [95% CI, 0.56 to 0.83]; n=1,810).

##### Combined Pharmacotherapy and Behavioral Interventions

We included one good-quality review by Stead (2012b) that assessed the effect of combining pharmacotherapy and behavioral support for smoking cessation among adults (Table 1).138 This review serves as the primary review for this intervention in adults and includes searches through July, 2012. The review included studies in which control participants could be offered usual care, self-help materials or brief advice on quitting. This support, however, had to be of lower intensity than that given to intervention participants. This review excluded trials where fewer than 20 percent of intervention participants were eligible for or used pharmacotherapy. The review also excluded studies where the control group was systematically offered medications, but did not exclude studies where control participants may have obtained pharmacotherapy from other sources (Table 5).

Table 5 Inclusion Criteria of Included Existing Systematic Reviews on the Efficacy of Behavioral Tobacco Cessation Interventions Among Adults, by Type of Intervention

Review, Year Quality | Intervention | Comparison | Last Search Date | Number of Included Studies | Funding Source | Study Design^†^ | Population | Outcomes | Followup | Setting
*Stead, 2012b138 Good | Combined pharm and behavioral interventions | Usual care, self-help materials, brief advice, or less intensive behavioral support | July-12 | 41 | NHS, National Institute of Health Research | RCTs or quasi-RCTs | Nonpregnant adult smokers | Smoking abstinence | ≥6 months | Any
*Stead, 2013a142 Good | Behavioral interventions as adjuncts to pharmacotherapy | Any behavioral support of lower intensity | July-12 | 38 | NHS National Institute for Health Research | RCTs or quasi-RCTs | Nonpregnant adult smokers | Smoking abstinence | ≥6 months | Any
*Rice, 2013^136^ Good | Nurse delivered behavioral support | Varying types of "usual care" or low-intensity support | June-13 | 49 | American Heart Association; NHS Research & Development Program | RCTs | Nonpregnant adult smokers | Smoking abstinence | ≥6 months | Any
*Stead, 2013b139 Good | Physician advice | No advice, usual care, or differing levels of physician advice | Jan-13 | 42 | NHS Research and Development Program | RCTs or quasi-RCTs | Nonpregnant adult smokers | Smoking abstinence | ≥6 months | Any
Carr, 2012^108^ Good | Any tobacco cessation intervention in dental setting | Usual care, placebo, or other intervention | Nov-11 | 14 | National Institute for Dental and Craniofacial Research, US | RCTs or pseudo-RCTs | Tobacco users of any age | Tobacco abstinence | ≥6 months | Dental setting or dental provider in community
Cahill, 2010^106^ Good | Stage-based | Non-stage-based intervention of lower or equal intensity; no intervention; or usual care | Aug-10 | 41 | NR | RCTs or quasi-RCTs | Smokers of any age, race or gender | Smoking abstinence; adverse events | ≥6 months from start of treatment | Any
Hettema, 2010^119^ Fair | Motivational interviewing | Non-MI | June-08 | Total: 31 (non-pregnant: 23) | NR | RCTs | Pregnant and nonpregnant smoking adults | Smoking abstinence | Short term (≤6 months) or long term (≥6 months) | Any
Lai, 2010^124^ Good | Motivational interviewing | Brief advice; low-intensity intervention; or usual care | April-09 | 14 | NR | RCTs | Nonpregnant adult smokers | Smoking abstinence | ≥6 months | Any
Bodner, 2009^103^ Fair | Smoking cessation advice by a health professional | Usual care or no advice | NR | 30 | CIHR Institute of Musculoskeletal Health and Arthritis; Canadian Lung Association | RCTs or quasi-experime-ntal studies | Adult smokers | Smoking abstinence | ≥5 months post-intervention | Any
Mottillo, 2009^131^ Fair | Behavioral (brief advice, individual, group, and telephone counseling) | Usual care | Aug-07 | 50 | Canadian Institutes of Health Research | RCTs | Adult smokers | Smoking abstinence | 6 or 12 months | Any
*Hartmann-Boyce, 2014^118^ Good | Print-based self-help materials | No treatment or other minimal contact strategies | April-14 | 74 | NHS Research & Development Programme | RCTs or quasi-RCTs | Adult smokers | Smoking abstinence | ≥6 months | Any
*Stead, 2013c141 Good | Telephone counseling | Minimal intervention (standard self-help materials or brief advice) | May-13 | 77 | NHS Research & Development Program | RCTs or quasi-RCTs | Adult smokers | Smoking abstinence | ≥6 months | Any
*Whittaker, 2012^152^ Fair | Mobile phone-based intervention | Control (various) | May-12 | 5 | National Institute for Health Innovation, New Zealand; Cancer Council Victoria, Australia | RCTs or quasi-RCTs | Smokers of any age | Smoking abstinence | ≥6 months | Any
Tzelepis, 2011^147^ Fair | Telephone counseling | Self-help materials/no intervention | Dec-08 | 24 | Cancer Council New South Wales; University of Newcastle | RCTs | Adult smokers | Smoking abstinence | ≥6 months | Any
*Civljak, 2013^113^ Good | Internet-based | No intervention; different Internet intervention; or non-Internet intervention | April-13 | 28 | NHS Connecting for Health Evaluation Programme; NHS Research and Development Programme | RCTs or quasi-RCTs | Smokers of any age (studies in adolescents and young adults analyzed separately) | Smoking abstinence | ≥6 months (studies with shorter FU were included and reported narratively) | Any
Brown, 2013^104^ Fair | Technology based | Not clearly stated | Feb-11 | 8 | NR | RCTs, quasi-RCTs and cohort studies | Young adult (ages 18-30 years) smokers recruited from U.S. colleges or university campuses | Smoking abstinence | ≥6 months preferred, shorter followups accepted | Any
Chen, 2012^111^ Good | Computer, internet, mobile telephone, or other electronic | No intervention; standard self-help materials | Dec-09 | 60 | HTA program | RCTs or quasi-RCTs | Adult smokers | Smoking abstinence | ≥6 months | Any
Hutton, 2011^122^ Good | Web-delivered | Control (various) | Feb-10 | 21 | International Union Against Tuberculosis and Lung Disease | RCTs | Smoking adolescents, college students, and adults | Smoking abstinence | ≥1 month | Any
Myung, 2009^132^ Good | Web- or computer-based | Usual care | Aug-08 | 22 | CDC | RCTs | Adult smokers | Smoking abstinence | >3 months | Any
Shahab, 2009^137^ Fair | Internet-based (must make use of the interactive nature of the internet) | Minimal control condition (e.g. booklet or static website) or waitlist control | Dec-08 | 11 | Department of Health, England | RCTs | Adult smokers | Smoking abstinence | ≥1 month | Any
*Bize, 2012^102^ Good | Biomedical risk assessment | No biomedical risk assessment control | June-12 | 15 | NR | RCTs | Adult smokers who participated in smoking cessation programs, screening for respiratory disease, or health checkups | Smoking abstinence | ≥6 months | Any
*Ussher, 2014^148^ Fair | Exercise-based interventions | Smoking cessation program alone | May-2014 | 20 | NR | RCTs | Adult smokers wishing to quit or recent quitters | Smoking abstinence | ≥6 months | NR
*White, 2014^151^ Good | Acupuncture, acupressure, laser therapy, or electrostimulation | No intervention; sham acupuncture (i.e., acupuncture to known spots that aren't related to smoking cessation); usual care; placebo; other intervention (e.g., locked cigarette case controlled by time switch) | Oct-13 | 38 | Universities of Exeter and Plymouth, UK; National Research Centre for Complementary Medicine, Norway; NHS Research and Development National Cancer Program | RCTs | Adult tobacco smokers wishing to stop smoking | Smoking abstinence | Short-term: up to 6 weeks from the quit date Long-term: 6 to 12 months from quit date | Any
Di, 2014^114^ Good | Ear acupuncture/acupressure or auriculotherapy | Nonspecific/ inactive control or other smoking cessation intervention | Jan-13 | 25 | Guangdong Provincial Academy of Chinese Medical Sciences | RCTs or quasi-RCTs | Smokers aiming to quit | Smoking abstinence | Any | Any
Cheng, 2012^112^ Fair | Acupoint stimulation with or without NRT | Nontreatment, placebo acupuncture, placebo acupressure, or medication | Mar-11 | 20 | NR | RCTs | Not clearly defined | Smoking abstinence; smoking reduction | Earliest and last measured timepoints and at 3- and 6-month followups | Any
Tahiri, 2012^144^ Fair | Alternative smoking cessation aids (acupuncture, hypnotherapy, aversive smoking) | No alternative smoking cessation aid | Dec-10 | 14 | Canadian Institutes of Health Research | RCTs | Adult smokers | Smoking abstinence | 6 or 12 months | Not clearly stated, but clinic administered alternative smoking cessation aid implied
*Barnes, 2010^100^ Good | Hypnotherapy | No treatment or any other therapeutic intervention | July-10 | 11 | Wellcome Trust, UK; NHS Research and Development National Cancer Program | RCTs | Tobacco smokers wishing to stop smoking | Smoking abstinence | ≥6 months | NR

* Review served as basis for main finding

† Quasi-RCTS are those that use quasi-random methods of assignment including alternation, date of birth, or medical record number.

Abbreviations: AE = adverse event; CDC = Centers for Disease Control and Prevention; CIHR = Canadian Institutes of Health Research; HTA = Health Technology Assessment; NHS = National Health Service; NR = not reported; NRT = nicotine replacement therapy; Pharm = pharmacotherapy; RCT = randomized controlled trial; UK = United Kingdom; US = United States.

The Stead review (2012b) included 41 trials which enrolled 15 to 5,887 participants. Twenty-three studies had more than 100 participants in the intervention group. About half (21/41 studies) of these studies were conducted in the United States and the majority occurred in or recruited from health care settings, such as primary care clinics (7 studies), a health maintenance organization (1 study), or Veterans Administration medical centers (2 studies) and/or recruited people with specific health conditions (e.g., hospital inpatients (8 studies), surgery patients (4 studies), and those with mild airway obstruction or COPD (3 studies). While the included interventions presented a great deal of variation in the intensity and format of behavioral support, the typical intervention involved multiple contacts with a specialist cessation adviser or counsellor, with most participants using some pharmacotherapy (typically NRT) and receiving multiple contacts. The majority of trials (22/41) offered between four and eight sessions and about a quarter (11/41) offered over eight sessions. Specialized cessation counsellors or trained trial staff delivered most of the interventions. The primary care provider was the main interventionist in only three included studies (Table 6).

Table 6 Descriptive Characteristics of Included Studies Within the Main Reviews on the Efficacy of Behavioral Tobacco Cessation Interventions Among Adults, by Type of Intervention

Review, Year | Number of Included Studies | Sample Size (Range) | Demographic Characteristics | Baseline Smoking Status | Readiness to Quit/ Quit History | Intervention Characteristics | Treatment Setting/Provider Characteristics
Stead, 2012b138 | 41 | 15 to 5,887 | Average age: “low 40s to mid-50s” Sex (% female): 35 to 65; recruited only women (k=2); only men (k=1) Race: NR SES: NR, but 1 study recruited residents of low-income public housing departments Comorbidities/other substance use:; - Outpatient substance abuse treatment programs (k=2); - Mental health service settings (k=2); - AIDS clinic (k=1); - Cancer patients (k=2); - Cancer survivors (k=1); - Chinese men w/erectile dysfunction (k=1); - COPD or mild airway obstruction (k=3) | Smoking status: 12 to 31 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit:; - Motivation required (k=18); - Motivation not required but participants likely to have been interested in quitting (k=10); - Not selected by motivation (k=13); Quit history: NR consistently | Included 41 studies. Typical intervention involved multiple contacts with a specialist cessation advisor or counselor, with most participants using some pharmacotherapy and receiving multiple contacts. Some interventions involved making pharmacotherapy and behavioral components available to a large population in which takeup of treatment was low (k=1), or providing a brief intervention to all participants and offering stepped care for those willing to set a quit date (k=2), or an intervention delivered entirely by mail or prerecorded phone messages (k=1), or telephone counseling alone (k=1); all others included some face-to-face contact but additional sessions were sometimes provided by telephone. >50% of RCTs offered between 4 and 8 sessions and around 25% >8 sessions. The modal category for contact time was 91 to 300 min, with 10 RCTs offering between 31 and 90 min and 7 RCTs offering >300 min. The control group typically received brief advice and self-help materials. | Setting: High proportion of trials conducted in health care settings and/or recruited people with specific health needs Settings included:; - Hospital inpatient (k=8); - Primary care clinics (k=6); - Awaiting admission for surgery (k=4); - Dental clinics (k=2); - Mental health service settings (k=2); - AIDS clinic (k=1); - Annual occupational health checks (k=1); - Members of HMOs (k=1); - Low income public housing department (k=1); - VA medical center (k=1); Providers: Mostly specialist cessation counselors or trained trial personnel; in a small subgroup, intervention was provided by general practitioners/family physicians (k=3), dentists or dental hygienists (k=2), occupational physicians (k=1), peer group counselors (k=2), or trained lay advisors (k=1)
Stead 2013a142 | 38 | 69 to 4,614 | Average age (range): 33 to 61 Sex (% female): 12 to 100; 2 studies enrolled only females Race: NR SES: NR Comorbidities/other substance use: NR | Smoking status: >4 to 30.5 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: Majority recruited volunteers who were interested in making a quit attempt Quit history: NR consistently | - Nicotine patch (k=19); - Nicotine gum (k=6); - Sublingual tablets (k=1); - Not specified (k=1); - Bupropion SR (k=3); - Nortriptyline alone (k=1); - Varenicline alone (k=1); - NRT or bupropion SR (k=3); - Bupropion SR or nortriptyline (k=1); - NRT and bupropion SR (k=2); Intensity of behavioral support greatly varied for both intervention and control groups; in 6 studies there was no personal contact for the controls; in 16 studies the control arms had between 1 and 3 contacts (which could be face-to face or by telephone) and most of these had a total contact duration of between 4 and 30 minutes; in 14 studies there were 4 to 8 contacts scheduled for the controls, and these typically had a total contact time of 91 to 300 min | Setting:; - Primary care (k=4); - Chest clinic (k=1); - CVD outpatient clinic (k=1); - HIV clinic (k=1); - Mental health clinics (k=1); - Substance abuse clinics (k=2); - VA hospital (k=1); - HMO (k=4); - Community (k=23); Providers: NR
Rice, 2013^136^ | 49 | 40 to 12,472 | Average age (range): 33 to 61 Sex (% female): NR consistently; women only (k=3); men only (k=1) Race: NR SES: NR Comorbidities/other substance use:; - Diagnosed cardiovascular health problems (k=15); - Judged to be at high risk of developing heart disease (k=1); - Respiratory diseases (k=2); - Diabetes (k=1); - Surgical patients (k=2); - Head and neck cancer patients (k=1) | Smoking status: Variable, cigarettes per day reported for a subset of studies Nicotine dependence: NR consistently | Readiness to quit: NR consistently Quit history: NR consistently | 35/49 studies with a total of over 17,000 participants contributed to the main comparison of nursing interventions vs control (28 were classified as high intensity and 7 classified as low intensity) 7/49 examined a smoking cessation intervention as a component of multiple risk factor reduction interventions in adults with CVD. 4/49 had a smoking cessation component that was clearly defined, of high intensity, and independently measurable. 3/49 had a smoking cessation component that was not clearly specified. | Setting:; - Hospital (k=20); - Primary care (k=26); - Worksite (k=1_; - Community (k=2); Providers:; - Of the high intensity intervention studies, 12 used nurses for whom the intervention was a core component of their role.; - In 9 studies the intervention was delivered by a nurse specifically employed by the project; - Four studies intensive interventions were intended to be delivered by nurses for whom it was not a core task; - Most of the low intensity interventions were delivered by primary care or outpatient clinic nurses
Stead, 2013b139 | 42 | 60 to 3,215 | Average age: NR Sex (% female): NR; 1 trial recruited males only Race: NR SES: NR Comorbidities/other substance use: NR consistently | Smoking status: ≥1 to ≥25 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: NR consistently Quit history: NR consistently | 42 RCTs included:; - Minimal advice vs. no advice (k=17); - Intensive intervention vs. control (k=11); - Intensive intervention vs. minimal intervention (k=14); - 2 intensive interventions (k=1); - Intervention based on the 4 As model (k=1)- Advice vs. computer-tailored letters (k=2); Some studies tested variations in interventions and contributed to more than 1 comparison. The definition of what constituted 'advice' varied considerably. | Setting: Mostly family/general practice, but also government clinic, adult diabetic outpatient clinic, hospital cardiac unit, worksite, and community settings Providers: Health care personnel (e.g., medical registrar, physicians, hospital consultants)
Hartmann-Boyce, 2014^118^ | 74 | 40 to 6697 | Average age (range): 34 to 72 Sex (% female): 8 to 75 Race: NR SES: NR Comorbidities/other substance abuse:; - Cardiovascular health issues (k=1) | Smoking status: ≥5 to 31 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: Interest in quitting was not a selection criteria, however smokers recruited to trials ranged from those who had already succeeded in quitting for 48 hours to those with no interest in quitting Quit history: NR consistently | 74 trials included:; - Standard self-help materials vs. no intervention or provided standard materials as an adjunct to advice (k=34); - Targeted or tailored self-help methods vs. no targeting/tailoring or other variations of programs (k=40); The content and format of the self-help programmes were varied. The most frequently used approach was the American Lung Association Freedom from smoking in 20 days cessation manual and A lifetime of freedom from smoking maintenance manual. | Setting: NR Providers: NR
Stead, 2013c141 | 77 | 40 to 7,354 (median: 820) | Average age: “Participants were predominantly older adults with an average age typically in the 40s.” Sex (% female): Only women (k=5); only men (k=4) Race:; - Culturally tailored intervention for Chinese, Korean and Vietnamese smokers (k=1); - Intervention focused on Arabic smokers (k=1); SES: NR Comorbidities/other substance abuse:; - CVD (k=2) | Smoking status: ≥1 to 28 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit:; - Recruited smokers who wanted to make a quit attempt (k=16); - Did not state that participants were included on the basis of motivation, although relatively high proportions may have been interested in quitting (k=35); Quit history: NR consistently | 77 included studies; - Interventions for smokers who contacted a quitline/helpline (k=15); - Providing access to a helpline (k=3); - Proactive counseling not initiated by calls to quitlines (k=51); - Other (k=8) | Setting: Variable. “Most of the studies were trials of proactive calls from a counselor, or from an automated interactive voice response system.” 3 studies recruited participants in health care settings and referred them to services provided by quitlines.” Providers: Majority of interventions were administered by professional counsellors or health care providers trained to offer advice over the telephone
Whittaker, 2012^152^ | 5 | 200 to 5,800 | Average age (range): 22 to 42 Sex (% female): 45 to 63 Race: NR SES: NR Comorbidities/other substance use: NR | Smoking status: 15 to 20 (average cpd range) Nicotine dependence: Participants in most of the studies had similar degrees of nicotine dependence, with mean FTND scores of 5 in one trial and 60% of participants in another trial scoring ≤5. However, in a third trial the Hooked on Nicotine Checklist mean scores of 8 indicated a highly addicted group. | Readiness to quit: 4/5 trials recruited participants ready or interested in quitting, or willing to quit in the next month Quit history: NR consistently | 3/5 trials were based on the same intervention program, which involved participants setting a quit day within 3 weeks and then receiving an automated personalized program of regular text messages. 1/5 trial involved a web-based Quit Coach and a text messaging intervention. 1/5 trial implemented a video messaging intervention. | Setting: NA; all interventions were strictly mobile phone based Providers: NA; all interventions were strictly mobile phone based
Civlijak, 2013^113^ | 28 | <150 to ~12,000 | Average age (range): 16 to 57 Sex (% female): “more women than men” Race: NR consistently SES: NR Comorbidities/other substance use: NR | Smoking status: ≥1 to 40 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: Recruitment was largely web-based, with participants finding the sites through search engines and browsing. As a result of these methods, participants included in these trials were smokers motivated to quit, who chose the internet as a tool for smoking cessation support. Quit history: NR consistently | 28 included studies:; - Active Internet intervention vs. non-Internet arm (k=15); - Compared 2 Internet interventions (k=14); 1 study contributes to both categories A range of internet interventions were tested in the included studies, from a very low intensity intervention providing a list of websites for smoking cessation to highly intensive interventions consisting of Internet-, email- and mobile phone-delivered components. Tailored internet interventions differed in the amount of tailoring, from a bulletin board facility, a multimedia component, tailored and personalized access to very high-depth tailored stories and highly personalized message sources. | Setting: Recruited smokers from health care settings (k=5); remaining trials used web-based recruitment Providers: Not applicable since interventions were provided via the internet
Bize, 2012^102^ | 15 | 90 to 2,110 | Average age (range): 32 to 53 Sex (% female, range): 4 to 63 Race: NR SES: NR Comorbidities/other substance use: NR | Smoking status: 11.9 to 29.2 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: NR consistently Quit history: NR consistently | Of the 16 interventions:; - Exhaled CO measurements (k=4); - Combination of exhaled CO measurement and spirometry (k=4); - Spirometry alone (k=3); - Ultrasonography of carotid arteries with photographic demonstration of atherosclerotic plaques when present (k=2); - Feedback about genetic susceptibility to cancer (k=3) | Setting:; - General practice (k=5); - Outpatient clinics (k=4); - ‘Smoking clinic’ (k=2); - Health promotion clinic for army veterans (k=1); - Company (workplace) (k=1); - Research institutions (k=2); Providers:; - Physician (k=4); - Nurse (k=4); - Specific study staff member (k=6); - Trained health educator in 1 trial (k=1)
Ussher, 2014^148^ | 20 | 20 to 2,318 | Average age (range): 17 to 59 Sex (% female): only women (k=9); only men (k=1) Race: “13 studies recorded ethnic status, and all reported a predominantly white sample.” SES: NR Comorbidities/other substance use:; - Recruited post-acutemyocardial infarction patients (k=1) | Smoking status: >10 to 32 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: All studies recruited smokers wishing to quit or were recent quitters Quit history: NR consistently | In all but 2 of the studies, a multi-session cognitive behavioral smoking cessation program was provided for intervention and control conditions. In 10 studies this began prior to quit day. 1 study provided only a single session cessation program and participants were post-acute myocardial infarction patients, with the intervention being for relapse prevention. 1 study delivered a smoking cessation program via the Internet and this was only available for the nonexercise condition. 6 studies included nicotine patches as part of the smoking cessation program, 1 study used nicotine gum, and 3 promoted NRT in general. Most of the trials employed supervised, group-based cardiovascular-type exercise supplemented by a home-based program. | Setting: NR Providers: NR
White, 2014^151^ | 38 | 18 to 651 | Average age (range): NR consistently Sex (% female): NR consistently Race: NR SES: NR Comorbidities/other substance use: NR | Smoking status: NR consistently Nicotine dependence: NR consistently | Readiness to quit: NR consistently Quit history: NR consistently | 38 included studies:; - Acupuncture (k=23); - Acupressure (k=5); - Laser stimulation (k=3); - Electrostimulation (k=7); 12 studies also used continuous auricular stimulation in combination with acupuncture, acupressure or electrostimulation. | Setting: NR Providers: NR
Barnes, 2010^100^ | 11 | 20 to 286 | Average age (range): 30 to 40 Sex (% female): “more females than males” Race: NR SES: NR Comorbidities/other substance use: NR | Smoking status: 20 to 40 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: NR consistently Quit history: NR consistently | RCTs varied in the method of hypnotic induction used, number of sessions, and duration of treatments. The number of hypnotherapy sessions reported ranged from 1 to 8 sessions. The total duration of hypnosis used ranged from 30 min to 8 hours. 5 RCTs provided hypnotherapy in a group format. | Setting: NR Providers: NR

Abbreviations: AIDS = autoimmune deficiency syndrome; CO = carbon monoxide; COPD = Chronic Obstructive Pulmonary Disease; cpd = cigarettes per day; CVD = cardiovascular disease; FTND = Fagerstrom Test for Nicotine Dependence; HIV = human immunodeficiency virus; HMO = health maintenance organization; k = number of studies; min = minutes; NA = not applicable; NR = not reported; NRT = nicotine replacement therapy; RCT = randomized controlled trial; SES = socioeconomic status; SR = sustained release; VA = veterans administration.

In meta-analysis that combined 40 of the 41 trials, there was a statistically significant benefit of combined pharmacotherapy and behavioral interventions versus control on smoking cessation at 6 months followup or longer (RR 1.82 [95% CI, 1.66 to 2.00]; I^2^=40%; k=40; n=15,021) (Table 7; Appendix F Figure 5). Average quit rates in these trials ranged from 3 to 50 percent (weighted mean: 14.5%) among participants receiving pharmacotherapy and behavioral support, versus zero to 36 percent (weighted mean: 8.3%) among participants randomized to a control group. The original pooled estimate that combined all 41 studies had considerable heterogeneity (I^2^=78%). This heterogeneity was deemed to be attributable to the Lung Health Study, which showed a very strong intervention effect (RR 3.88 [95% CI: 3.35 to 4.50]). The Lung Health Study had a very intensive intervention in which participants received nicotine gum free of charge for 6 months and a group-based 12-session behavioral counseling course. Since all of the subgroup analyses presented within this review excluded the Lung Health Study, and we agree that the intervention is much different than the others being combined, we focused on pooled results excluding this trial.

Table 7 Summary of Tobacco Abstinence Results (KQ 2) From Reviews of Behavioral Counseling Tobacco Cessation Interventions Among Adults, by Type of Intervention

Review, Year | Intervention | Control | k | N | Abstinence Measures^*^ | Followup^§^ | IG Events | IG N | IG Quit Rate^†^ | CG Events | CG N | CG Quit Rate^†^ | Risk Ratio^‡^ | 95% CI | I^2^
Stead, 2012b138 | Combined pharm and behavioral interventions | Control (various) | 40 | 15,021 | 56% CA 76% BV | ≥6 months | 1,134 | 7,810 | 14.5% | 597 | 7,211 | 8.3% | 1.82 | 1.66, 2.00 | 40%
Stead, 2013a142 | Behavioral support as an adjunct to pharmacotherapy | Pharmacotherapy (any) | 39 | 15,506 | 28% CA 79% BV | ≥6 months | 1,640 | 7,659 | 21.4% | 1,438 | 7,847 | 18.3% | 1.16 | 1.09, 1.24 | 3%
Rice, 2013^136^ | Nursing interventions | Usual care or minimal intervention | 35 | 17,604 | 29% CA 77% BV | ≥6 months | 1,273 | 9,589 | 13.3% | 906 | 8,015 | 11.3% | 1.29 | 1.20, 1.39 | 50%
Stead, 2013b139 | Physician advice | No advice/usual care | 28 | 22,239 | 43% CA 36% BV | ≥6 months | 1,008 | 12,583 | 8.0% | 462 | 9,656 | 4.8% | 1.76 | 1.58, 1.96 | 40%
Hartmann-Boyce, 2014^118^ | Nontailored self-help print materials | Control (various) | 33 | 29,495 | 42% CA 55% BV | ≥6 months | 1,080 | 15,635 | 6.9% | 891 | 13,860 | 6.4% | 1.06 | 0.98, 1.16 | 23%
Hartmann-Boyce, 2014^118^ | Tailored self-help materials | Control (various) | 32 | 40,890 | 72% CA 25% BV | ≥6 months | 1,502 | 21,017 | 7.1% | 1,144 | 19,873 | 5.8% | 1.28 | 1.18, 1.37 | 32%
Stead, 2013c141 | Proactive telephone counseling in quitline callers | Control (various) | 12 | 30,182 | 75% CA 17% BV | ≥6 months | 1,980 | 18,428 | 10.7% | 895 | 11,754 | 7.6% | 1.41^‖^ | 1.20, 1.66 | NR
Stead, 2013c141 | Proactive telephone counseling (no quitline) | Control (various) | 52 | 30,246 | 33% CA 35% BV | ≥6 months | 2,031 | 15,478 | 13.1% | 1,433 | 14,768 | 9.7% | 1.27 | 1.20, 1.36 | 42%
Whittaker, 2012^152^ | Mobile phone interventions | Control (various) | 5 | 9,100 | Pooled results not presented given small number of studies and considerable heterogeneity (I^2^=79%); results reported narratively
Civljak, 2013^113^ | Internet-based interventions | No treatment or other noninternet based treatments | 23 | >45,000 | Pooled results not presented given small number of studies in subgroup analyses and considerable statistical heterogeneity; results will be reported narratively
Bize, 2012^102^ | Biomedical risk assessment | Control (various) | 15 | 8,115 | Pooled results not presented given small number of studies in each subgroup and substantial statistical heterogeneity; results reported narratively
Ussher, 2014^148^ | Exercise alone or as adjunct to smoking cessation intervention | Smoking cessation intervention alone or usual care | 20 | 5,870 | No meta-analysis conducted due to small number of studies, small sample sizes and differences in study design and intervention; results reported narratively
White, 2014^151^ | Acupuncture | Sham acupuncture | 9 | 1,892 | 33% CA 33% BV | 6-12 months | 122 | 997 | 12.2% | 97 | 895 | 10.8% | 1.10 | 0.86, 1.40 | 23%
Barnes, 2010^100^ | Hypnotherapy | Brief advice/advice | 5 | 363 | Pooled results not presented given small number of studies and clear asymmetry of the results of the included trials, indicating potential publication bias.

* Used strictest available criteria to define abstinence (i.e., continuous, sustained, or prolonged abstinence was preferred over point prevalence abstinence and biochemically validated rates were used where available). “Continuous abstinence” reflects reviews that reported outcomes as continuous (completely abstinent from quit date with 0-5 cigarettes during that time), “sustained” abstinence (not defined), or prolonged abstinence (allowing a grace period following the quit date to allow for lapses).

† Weighted average quit rate

‡ Pooled risk ratios estimated using the Mantel-Haenszel fixed-effects model, unless otherwise noted

§ Longest followup time point reported

‖ Results from sensitivity analysis using a random-effects model given substantial heterogeneity of fixed effects model (71%)

Abbreviations: BV = biochemically verified; CA = continuous abstinence; CI = confidence interval; CG = control group; IG = intervention group; k = number of studies; N = number; NR = not reported.

The pooled effect of combined interventions was higher among 31 studies that were conducted in or recruited participants from a health care setting, compared with eight trials that recruited community volunteers. The results in both settings, however, showed significant benefit (Health care: RR 2.06 [95% CI, 1.81 to 2.34] versus Community: RR 1.53 [95% CI: 1.33 to 1.76]) (Chi^2^ test for subgroup difference, p=0.00). There was little evidence that the relative effect of the intervention differed according to participant readiness-to-quit. The subgroup of trials that included participants selected for motivation had a slightly larger effect estimate than the subgroup not selected for motivation, although the confidence intervals overlapped. The review found evidence that those trials that offered more personal contact sessions tended towards larger effects. The subgroup of trials that offered eight or more sessions had the largest estimate (RR 2.09 [95% CI, 1.57 to 2.79]; I^2^=43%; k=10; n=1,474), but the confidence intervals overlapped for all four groups (i.e., 0 sessions; 1-3 sessions; 4-8 sessions; more than 8 sessions). The review also found no clear evidence that increasing the total duration of personal contact increased the effect. Post hoc meta-regression found no evidence of effect modification by provider type, level of treatment up-take, or the total minutes of personal contact. Indirect comparisons also found little evidence that the relative effect of the intervention differed according to participants motivation or readiness to quit.138

#### Behavioral Interventions Among Adults

We included 26 reviews that evaluated the effects of behavioral tobacco cessation interventions among the general adult population (Table 1 and Table 5).100,102-104,106,108,111-114,118,119,122,124,131,132, 136,137,139,141,142,144,147,148,152,174 All 26 reviews that were included in the overall “Behavioral” population-intervention category are further subcategorized into nine groupings:

1. Behavioral Supports as an Adjunct to Pharmacotherapy (1 review)142
2. Behavioral Support and Counseling, including counseling techniques such as provider advice, motivational interviewing, or stage-based support (8 reviews)103,106,108,119,124,131, 136,139
3. Print-Based Self-Help Materials (1 review)118
4. Telephone Counseling (2 reviews)141,147
5. Mobile Phone-based Interventions (1 review)152
6. Computer-based Interventions (6 reviews)104,111,113,122,132,137
7. Biomedical Risk Assessment (1 review)102
8. Exercise (1 review)148
9. Complementary and Alternative Therapies, such as acupuncture and hypnotherapy (5 reviews)100,112,114,144,151

There was considerable overlap in the included studies within groupings (i.e., within the eight reviews on behavioral support and counseling) and between intervention categories (i.e., behavioral support and counseling and telephone counseling) in terms of the included bodies of evidence (Appendix C Table 1). Within each of the nine subgroups of behavioral interventions, we identified one or more reviews that included the most comprehensive and up-to-date literature base and the highest quality to serve as the primary review. Some groups required more than one primary review to represent the breadth of relevant findings. Table 5 lists the inclusion and exclusion criteria for all 26 included reviews (plus the review by Stead [2012b]138 above) arranged by intervention group, as described above.

##### Behavioral Interventions as Adjuncts to Pharmacotherapy

Stead (2013a)142 assessed the effect of increasing the intensity of behavioral support among smokers using smoking cessation medications. Their last search for evidence was July, 2012. They included RCTs in which adult smokers in both the intervention and control conditions received pharmacotherapy for smoking cessation but they differed by the amount of behavioral support. Participants in the control condition received less intensive behavioral support than participants in the intervention condition, even limited to written information alone. This review excluded trials where both groups received behavioral support of the same frequency and duration but differed in specific content (Table 5).

The review included 38 RCTs ranging in size from 69 to over 4,500 participants (Table 6). Trial participants reported smoking an average of 5 to 35 cigarettes per day. Seventeen trials recruited participants from a health care setting, health maintenance organization, or cessation clinic, including four studies in primary care. The remaining 21 studies recruited community volunteers. All but three studies recruited individuals who were interested in quitting. Over 70 percent (27 of 38) of trials offered NRT as the only pharmacotherapy; three studies offered bupropion SR; one offered varenicline; three offered bupropion SR or NRT; and two studies provided combination therapy of both NRT and bupropion SR. The two remaining studies randomized participants to nortriptyline (not included in this review).

The pooled RR indicated a relatively small increase in smoking cessation at 6 to 12 months with more intense behavioral support among those using one of these types of pharmacotherapy (RR 1.16 [95% CI, 1.09 to 1.24]; I^2^=3%; k=38 [39 comparisons]; n=15,506) (Table 7; Appendix F Figure 6). Quit rates were relatively high in both intervention (weighted mean: 21.4%) and control groups (weighted mean: 18.3%), which is not surprising given that both groups were receiving pharmacotherapy. The effect was similar and also statistically significant for the subgroup of studies (k=27) that examined behavioral support as an adjunct to NRT, specifically. Results of the remaining trials among smokers using other non-NRT pharmacotherapies were generally not statistically significant, although a test for differences between subgroups was also not significant. While the majority of studies reported point prevalence abstinence instead of continuous abstinence, the review did not find any difference in the relative cessation effect between these two outcomes at 12 months. However, studies with point prevalence outcomes had, on average, higher quit rates in both intervention and control arms.142

The intensity of behavioral support provided to the control group varied from 0 minutes of contact to over 300 minutes of contact, including face-to-face and telephone contact, with a mode of 4 to 31 minutes. Most studies (k=22) provided less than 31 minutes. The majority of trials offered 91 to 300 minutes of contact (12 studies) or over 300 minutes (16 studies) of behavioral support to the intervention group participants. Despite this large range of intervention and control times across studies, and the requirement that intervention groups receive more intensive behavioral support intervention than control groups, the increment between groups in any given study was generally quite small. This review assigned trials to groups based on the planned total duration of contacts, as opposed to delivered, noting that in general using the actual delivered duration would not have changed the intensity category. In nine trials, while the review's authors categorized the intervention and control groups as receiving the same level of behavioral support (because of the discrete categories described above), the control groups actually received less-intense behavioral support. Indirect subgroup comparisons between those receiving fewer or more contacts failed to find evidence of a dose-response effect.142

##### Behavioral Support and Counseling Interventions

We included eight reviews that we classified as general behavioral support and counseling (Table 1).103,106,108,119,124,131,136,139 Each of these reviews had slightly different goals: four focused on behavioral support provided by physicians,139 nurses,136 health professionals in general,103 or that took place in dental settings;108 one included stage-based interventions;106 two considered studies that used motivational interviewing;119,124 and the remaining review included any behavioral intervention that used brief advice, individual counseling, group counseling, or telephone counseling.131 Most of the reviews had relatively old searches; six of the eight reviews ended their searches between 2007 and 2011 (Table 5). Because of this and the overlap in inclusion and exclusion criteria, most of the included studies within these six reviews were included in the more recent reviews by Stead139 and Rice136 as well as some of the other primary reviews listed below (Appendix C Table 1). Therefore, the two recent, good-quality Stead (2013b) and Rice (2013) reviews that focus on physician and nurse support for smoking cessation serve as the basis for our primary results here.136,139 Across all eight reviews, behavioral support tobacco cessation interventions were found to be statistically significantly favorable to control groups (e.g., usual care, minimal intervention) in encouraging smoking cessation at least 6 months after treatment started in pooled meta-analyses. We found no inconsistencies in reported results across reviews.

The primary review by Stead (2013b)139 summarized evidence on the effectiveness of physician advice in promoting smoking cessation published through January, 2013. This review included RCTs that compared physician advice to stop smoking versus no advice (or usual care), or compared different levels of physician advice to stop smoking. This review defined advice as verbal instructions from the physician with a “stop smoking” message regardless of whether or not information was provided about the harmful effects of smoking. They categorized studies as minimal interventions when advice was provided (with or without a brochure) during a single consultation lasting less than 20 minutes plus up to one followup visit. This review categorized studies as intensive when the intervention involved a greater time commitment at the initial consultation, the use of additional materials beyond a brochure, or more than one followup visit. This review included 42 trials, 26 of which (presenting 28 comparisons) contributed to their main analysis comparing advice with a no-advice or usual care control. The other 16 trials examined the effect of intensive advice versus minimal advice, compared two interventions similar in content or intensity, or compared advice to computer-tailored letters. These studies were included in separate analyses or discussed narratively in the review.

Smokers who were offered cessation advice by a physician had a statistically significant increase in the likelihood of quitting at 6 months or longer compared with smokers receiving no advice or usual care (RR 1.76 [95% CI, 1.58 to 1.96]; I^2^=40%; k=28; n=22,239) (Table 7; Appendix F Figure 7).139 There were too few trials in the main analysis (36%) to test the effect size when including only trials with complete biochemical validation. Absolute quit rates ranged from 1 percent to 23 percent among intervention participants (weighted mean: 8.0%), and from 1 percent to 14 percent among control participants (weighted mean: 4.8%). The results of the main meta-analyses were not sensitive to exclusion of trials at high risk of bias for any item. When stratified by intervention intensity, both brief advice and intensive advice showed statistically significant increases in quit rates when compared with no advice controls. There was no evidence of an interaction effect between strata (p=0.31). Direct comparisons, however, between intensive and minimal advice in 15 trials suggested a statistically significant advantage of more intensive advice (RR 1.37 [95% CI: 1.20 to 1.56]; I^2^=32%; k=15; n=9,775). Subgroup analyses within this group of 15 trials suggested that this effect might be small or nonexistent among smokers not selected as having smoking-related disease (10 studies), but the effect might be larger when the intervention is provided to smokers in high-risk groups (based on only 5 trials).

Indirect comparison between subgroups of studies within the main analysis suggested that interventions that included additional followup visits had a slightly larger effect estimate (RR 2.27 [95% CI, 1.87 to 2.75]; I^2^=27%; k=6; n=4,510), compared with no advice than interventions delivered at a single visit versus no advice (RR 1.55 [95% CI: 1.35 to 1.79]; I^2^=35%; k=18; n=14,675). Five additional included trials directly compared the addition of further followup to a minimal intervention, but were not included in the main analysis of advice versus no advice. None of these five trials individually detected significant differences between groups.

The other primary review, Rice (2013),136 searched for RCTs of smoking cessation interventions delivered by nurses through June, 2013 (Table 1 and Table 5). Similar to the review of physician advice,139 a nursing intervention included the provision of advice, counseling, and/or other strategies to help people stop smoking provided by a nurse. This review used the same definition of what constituted ‘advice’ as the Stead (2013b) review. These reviews, however defined intervention intensity slightly differently in that the Rice review defined low-intensity interventions as those that provided advice with or without a brochure during a single consultation lasting 10 minutes or less (as opposed to 20 minutes for the physician advice review) with up to one followup visit. The review defined high-intensity interventions as those where the initial contact lasted more than 10 minutes (again, as opposed to more than 20 minutes for physician advice). These high-intensity interventions also distributed additional materials, used additional strategies, and typically included more than one followup visit.

The Rice review (2013) included 49 trials. Twenty-six of these trials recruited participants from primary care, outpatient clinics, or through home health nurse visits. Twenty-two of these studies included high-risk patients, such as those with diagnosed cardiovascular or respiratory diseases, surgical patients, and head and neck cancer patients (Table 6). Seven of the studies examined a smoking cessation intervention that was a component of multiple risk-factor reduction interventions conducted among individuals with cardiovascular disease. Thirty-five of these 49 trials contributed to the main analysis that compared a nursing intervention to a usual-care or minimal intervention control.136 The remaining comparisons were made between two nursing interventions that involved different components, a different number of contacts (11 studies), or were excluded from meta-analyses given incomplete data.

The estimated pooled RR comparing smoking cessation support provided by a nurse with usual care or minimal intervention was 1.29 (95% CI, 1.20 to 1.39; I^2^=50%; k=35; n=17,604) (Table 7; Appendix F Figure 8).136 The reviewers noted that a series of sensitivity analyses that used a different model for meta-analysis that excluded studies that did not include biochemical validation of self-reported quitting, limited the analysis to studies judged to be at low risk of bias for selection bias, and excluded studies with less than 12 months of followup did not alter the estimated effect greatly, although the confidence intervals often widened due to smaller numbers of trials. There was no evidence of different effects among interventions classified as low- versus high-intensity through visual inspection or statistical interaction testing (Appendix F Figure 8).

##### Print-Based Self-Help Materials

A single review, the Hartmann-Boyce review (2014), assessed the effectiveness of different forms of print-based self-help materials compared with no treatment or other minimal intervention strategies.118 The review evaluated 74 RCTs (last search April, 2014) of self-help interventions. These interventions were defined as any materials or programs that smokers use to help them quit smoking that was not also substantively supported by health professionals, counselors, or a group. While the review primarily covered print-based materials, these interventions could include self-help provided via audio or videotape. Interventions only providing brochures on the health effects of smoking were not included because they were usually employed as a control condition compared with more substantial written materials. Interventions were categorized as self-help alone if they included a single session of minimal face-to-face contact in order to share the self-help materials whereas interventions were categorized as brief advice plus self-help if a face-to-face meeting included a discussion of the intervention content. The review excluded interventions that provided more than one advice session in addition to the self-help materials. Additionally, they excluded interventions delivered via the internet and mobile phone, as well as those that included telephone counseling or hotlines as adjuncts to self-help materials because these interventions were covered in separate recently published reviews (which are also included in this review of reviews).

Thirty-four of the included studies evaluated standard [underlined: nontailored] self-help materials alone or as an adjunct to advice compared with no materials or advice alone. Trials within this group varied in other ways that could potentially impact results, such as the amount of face-to-face advice or counseling provided to both the intervention and control groups. A pooled analysis of trials that compared nontailored self-help materials with no self-help found no evidence of an effect (RR 1.06 [95% CI, 0.98 to 1.16], I^2^=23%; k=33; n=29,495), regardless of level of contact and support common to both groups (Table 7). There was, however, evidence of a significant benefit of [underlined: tailored] self-help materials versus standard or no materials (RR 1.28 [95% CI, 1.18 to 1.37]; I^2^=32%; k=32; n=40,890) (Table 7). This effect differed by subgroup depending on the level of face-to-face contact both groups received and whether any materials were given to the control group. For instance, no benefit was detected in the subset of 10 trials in which the intervention group received tailored self-help materials and the control group received standard materials, but groups were matched for number of face-to-face contacts. In contrast, intervention participants receiving tailored self-help materials had significantly higher quit rates than control participants receiving no materials at all. Given this body of evidence, it is difficult to conclude a greater effect for tailored self-help materials than nontailored without direct within-study comparisons.

##### Telephone Counseling and Support

We included two reviews that evaluated the effects of telephone support to assist smokers in quitting that focused on the effect of proactive (i.e., recruiter-initiated contact) and reactive (i.e., smoker-initiated contact) telephone support via quit- or help-lines or other settings (Table 1 and Table 5).141,147 All 24 trials included in the Tzelepis review were included in the more up-to-date Stead review (2013c). As such, we used the Stead review as primary evidence for this topic.

The Stead review (2013c) included 77 trials that evaluated the provision of proactive or reactive telephone counseling to assist smoking cessation among smokers of any age, including three trials conducted among pregnant women.141 Trials ranged in size from 40 participants to over 7,000 (median: 820) and 78 percent took place in North America (Table 6). This review grouped trials into three broad categories based on the interventions: (1) interventions among smokers who contacted a helpline (15 studies), (2) interventions of proactive telephone counseling not initiated by calls to quitlines (51 studies), and (3) interventions that provided access to a helpline (3 studies). This review considered the eight trials that did not fall within these predefined categories individually. Within the three broad categories, trials were further subdivided based on the level and type of support provided to intervention participants (e.g., further proactive contact by a counselor among callers to a helpline, telephone counseling intensity [frequency, duration]) and control condition (e.g., minimal intervention, brief intervention/counseling) and based on the recruitment method or motivation of participants (i.e., participants with an interest in quitting or nonselective).

Among 12 trials that compared helpline callers receiving multisession telephone counseling with helpline callers who received self-help materials or a single session of telephone counseling, the pooled analysis showed a significant benefit of the additional telephone counseling on smoking cessation after at least 6 months followup (RR 1.41 [95% CI, 1.20 to 1.66]; I^2^ not reported; k=12; n=30,182) based on a random-effects meta-analysis (Table 7). The pooled result based on the original fixed-effects model indicated substantial heterogeneity (I^2^=71%) (Appendix F Figure 9). Quit rates ranged from 5 percent to 17 percent in the intervention groups and from 1 percent to 14 percent in the control groups. Three additional trials evaluated interventions that were limited to the initial call to the helpline and were not included in this pooled analysis.

Fifty-one studies (presenting 52 comparisons) that compared an intervention involving proactive telephone counselling that was not initiated by calls to helplines with a control condition also showed evidence of a moderate benefit at 6 months or longer followup (RR 1.27 [95% CI, 1.20 to 1.36]; I^2^=42%; k=52; n=30,246) (Table 7). Only about one-third of cessation outcomes within this group were based on continuous abstinence measures or were biochemically validated. Heterogeneity was not explained or reduced based on the intensity of support common to the intervention and control groups or by removing the trials among adolescents or pregnant women. Subsets of trials limited to specific groups of studies found significant benefit for the more intensive condition (Appendix F Figure 10), including: where the control group received only self-help materials or brief advice; where the intervention group received face-to-face contact prior to telephone support; or those where telephone counseling was an adjunct to the use or offering of NRT. Overall, however, there was mixed evidence of a dose-response effect based on the intensity of the intervention within the 51 trials of proactive telephone counseling. There was no evidence of such an effect in a meta-regression based on the number of intended calls to intervention participants. Subgroup analysis did, however, find that interventions that included two or fewer calls produced no significant pooled effect (RR 1.07 [95% CI, 0.91 to 1.26]), whereas those that offered between three and six (RR 1.32 [95% CI, 1.23 to 1.42]) or seven or more calls (RR1.29 [95% CI, 1.11 to 1.50]) found significant benefit. Within the broader review, the relative effects of the three trials that provided access to a helpline showed mixed results.141

##### Mobile Phone-Based Interventions

One review by Whittaker (2012) identified five RCTs (n=9,100) that included an evaluation of a mobile phone-based intervention (Table 5 and Table 6).152 This review excluded trials that used mobile phones as an adjunct to face-to-face or Internet-based programs or where the effects of the mobile phone intervention components could not be separated from the effects of a multicomponent intervention. The review reported considerable heterogeneity (I^2^=79%) in a meta-analysis of the five trials based on a Mantel-Haenszel fixed effects model. We do not present the pooled results here owing to the small number of trials, analysis methods, and considerable heterogeneity. Three of the five included trials were based on the same general program in which smokers who wanted to quit and owned a mobile phone were recruited via advertising.175-177 Individuals randomized to the intervention group received automated tailored text messages that included quitting advice and motivational messages to encourage abstinence. Participants received daily messages leading up to their chosen quit day, an intensive month of five to six messages per day after their quit day, followed by a maintenance phase of one message every 2 weeks for a total of 6 months. Two of the three studies detected significant evidence of an effect of the intervention on smoking cessation.175,177 The largest trial that was deemed to be at low risk of bias, for example, detected significant evidence of an effect based on biochemically verified continuous abstinence at 6 months (RR 2.14 [95% CI, 1.74 to 2.63], n=5,792).177 Within this trial, intervention participants received five text messages per day for the first 5 weeks and then three messages per week for the next 26 weeks. The intervention messages were tailored based on demographic and behavioral characteristics reported at baseline. Participants could also communicate with one another via text for peer support. Another RCT recruited participants through a quitline or email invitation and randomized them to one of five conditions: (1) automated tailored internet-based cessation program only, (2) text message program only, (3) both internet and text message programs, (4) choice of the internet and/or text message program, or (5) minimal treatment control.178 The text message intervention provided advice and motivational messages according to participants' stage of quitting and reported problems encountered in trying to quit. The frequency of text messages varied according to reported stage of quitting and problems encountered. This trial suggested a benefit from the intervention that was not statistically significant. The final trial sent intervention participants text messages which included a web address that led them to short video clips (less than 30 seconds).179 The intervention included daily messages delivered up until the chosen quit day, then two messages per day after the quit date that decreased in frequency over the course of the 6-month intervention. Participants within this trial were considered highly addicted according to the Hooked on Nicotine Checklist. This study found no evidence of an intervention benefit. Control participants in all five trials received ‘usual care’ or minimal contact.

##### Computer-Based Interventions

Six of the included reviews evaluated the effectiveness of computer- or internet-based tobacco interventions on smoking cessation (Table 1).104,111,113,122,132,137 All of these reviews varied somewhat in their inclusion and exclusion criteria (Table 5). For instance, one review focused specifically on internet-based interventions targeting young adults104 and another review included internet-based interventions that had to make use of the interactive nature of the internet.137 Reviews varied in their required length of followup from more than 1 month to more than 6 months. Despite these differences, in general, the reviews included very similar bodies of evidence, with the exception of the Health Technology Assessment by Chen and colleagues which included a broader evidence base.111 The Chen (2012) review included any smoking cessation program that used computer, internet, mobile phone or other electronic aids to generate tailored materials, present or deliver information, facilitate communication, or increase recruitment. Most of the Chen included studies were included in our other primary reviews or represented trials with too short followup (e.g., 2 days, 3 months) and so were not considered in any of our primary reviews (Appendix C Table 1). Given the quality, comprehensiveness and inclusion of the Civljak review,113 it serves as the primary review.

Civljak (2013) included 28 RCTs, representing over 45,000 participants, that evaluated an internet-based intervention.113 Trials ranged in size from 171 to 11,969 participants. This review excluded trials that used the internet solely for recruitment or to remind participants of appointments for treatment and not for delivery of smoking cessation treatment (Table 6). Twenty one of the 28 studies recruited participants via the internet or other advertisements. As such, smokers in most of these trials were motivated to quit and chose to access the internet as a cessation tool. The included studies tested a variety of interventions, including very low-intensity interventions that provided a list of websites for smoking cessation and high-intensity interventions that comprised internet-, email-, and mobile phone-delivered components. The Civljak review originally grouped the trials into four categories based on the intervention and control conditions (i.e., internet intervention versus nonactive control; internet intervention versus active control; addition of internet as an adjunct to an existing behavioral intervention; one internet intervention versus another internet intervention). Given the substantial-to-considerable statistical heterogeneity found in pooled analyses, they conducted post hoc subgroup analyses to inform regrouping trials according to the type of intervention (i.e., interactive and/or tailored internet plus other behavioral components; interactive and/or tailored internet only; or interactive but not tailored internet) and control (i.e., nonactive control [printed self-help or usual care]; active noninternet control [more intensive than self-help such as phone counseling]; or another internet intervention). Given the small number of studies within each comparison, we present the results of Civljak narratively and have created a descriptive forest plot to display the results of each individual trial (Appendix F Figure 11). Three studies found a statistically significant benefit for interventions that combined an interactive and tailored internet-based smoking cessation component with telephone counseling or email contact versus self-help materials. Three additional studies all found favorable effects of an interactive and tailored intervention alone compared with a nonactive control. Only one of these effects was statistically significant and all were considered to be of high risk of bias. None of the studies that compared interactive and/or tailored internet interventions with or without other behavioral or pharmacotherapy components with active controls found statistically significant differences. For instance, the study by Swan and colleagues included three intervention groups (IG): (IG1) up to 5 proactive telephone-based counseling calls; (IG2) interactive, tailored online intervention; and (IG3) a combination of arms 1 and 2. This study found nonsignificant effects when comparing IG1 with IG2 and when comparing IG3 with IG1.^180^ Three studies with at least 6-month cessation outcomes compared an interactive and/or tailored intervention with an internet intervention that was neither tailored nor interactive. None of the three found a statistically significant benefit of the interactive and/or tailored intervention. Thus, findings for the benefit of interactive and/or tailored interventions compared with less specific interventions were mixed.

##### Biomedical Risk Assessment

We identified one good-quality review, Bize (2012), that evaluated the efficacy of biomedical risk assessment (with or without other behavioral counseling) to aid in smoking cessation.102 Biomedical risk assessment interventions included a physical measurement to increase motivation to quit smoking, such as exhaled carbon monoxide (CO), spirometry, atherosclerotic plaque imaging or genetic testing. This review identified 15 trials (presenting 16 different interventions) that met inclusion criteria. These trials had a total of 8,115 participants (90 to 2,110 participants per study). While the clinical heterogeneity of the interventions and populations generally precluded pooled analyses, this review included a meta-analyses for two different comparisons (CO assessment and spirometry in primary care). We do not present the pooled results here because of the small number of studies pooled for each comparison (2 studies). The forest plot generated by Bize is presented to illustrate individual study results rather than to present pooled effect estimates (Appendix F Figure 12).

Of the 16 interventions included in the Bize review, four tested the effect of exhaled CO measurements, four tested the combination of exhaled CO measurement and spirometry, three tested the effect of spirometry alone, two tested the effect of undergoing an ultrasonography of carotid arteries with photographic demonstration of atherosclerotic plaques when present, and three tested feedback about genetic susceptibility to cancer (Table 6). Among the 15 studies, only two trials detected statistically significant benefit of biomedical risk assessment. The trial by Parkes and colleagues found a significant benefit on biochemically validated point prevalence abstinence at 12 months from a spirometry intervention where participants were given immediate feedback and an explanation of their results in the form of ‘lung age’ compared with their actual age. This was compared with control participants who were given their spirometry results via a letter and no mention of their lung age.181 The trial by Bovet and colleagues reported a relatively large effect with a wide confidence interval suggesting no benefit to large benefit comparing an intervention group that received ultrasonography of carotid and femoral arteries and counseling (n=74) with a control group who received counseling only (n=79).182 Smokers in the intervention group who were found to have one or more plaques identified were given photographs of their plaques with an explanation on the general significance of plaques and their impact on health. These results were based on 7-day point prevalence abstinence at 6 months. The lack of an effect in other studies could be due to an ineffective intervention, overall or in the population recruited, or to limited power, since most studies were relatively small.

##### Exercise

We included one fair-quality review, the Ussher (2014) review, that evaluated whether supervised or unsupervised exercise-based interventions alone, or combined with smoking cessation interventions, were more effective than a smoking cessation intervention alone.148 This review included 20 trials that met their inclusion criteria (Table 5). While sample sizes ranged from 20 – 2,318 participants, nearly half (8/20 trials) had fewer than 30 participants in each treatment group. Additionally, nine trials were limited to women and one was limited to men (Table 6). In all but two trials, participants in both the intervention and control groups received multi-session cognitive behavioral counseling. Seven trials included NRT as part of the smoking cessation intervention and four trials promoted the use of medications. The review reported that none of the included trials showed a significant benefit of exercise on smoking abstinence at 6 months or longer followup, although 13 of the 20 studies showed nonsignificantly higher rates of abstinence among the exercise plus smoking cessation intervention conditions, compared with the smoking cessation intervention conditions. The review's authors note several limitations of the included trials, including the fact that most trials were not sufficiently powered to detect differences between groups.

##### Complementary and Alternative Therapies

We included five reviews that examined the effectiveness of complementary and alternative therapies on smoking cessation – including three reviews on acupuncture or acupressure,112,114,151 one review on hypnotherapy,100 and one encompassing all alternative therapies144 (Table 1). The most up-to-date good-quality review, the White review (2014), served as the primary review for acupuncture-based approaches.151 We used the Barnes review (2010) as the primary review for hypnotherapy.100 While the three other reviews included similar bodies of evidence, they were not as recent as our primary reviews and were of a lesser quality (Appendix C Table 1). The White review included 38 RCTs that compared the effects of acupuncture (23 studies), acupressure (five studies), laser therapy (three studies), and electrostimulation (seven studies) versus no or sham intervention for smoking cessation at short-term (six weeks or less) and long-term (6-12 months) followup (Table 6).151 This review reported a positive effect for acupuncture compared with sham acupuncture on short-term cessation (RR: 1.22 [95% CI, 1.08 to 1.38]; I^2^=46%; k=16; n=2,588) but failed to find a pooled effect on longer term outcomes (RR: 1.10; [95% CI, 0.86 to 1.40]; I^2^=23%; k=9; n=1,892) (Table 7). Similarly, there was no evidence of a benefit of acupressure, continuous auricular stimulation, or electrostimulation versus sham interventions on long-term cessation.

The Barnes review assessed the evidence surrounding the effectiveness of hypnotherapy for smoking cessation and included 11 trials indexed through July, 2010.^100^ Sample sizes of the included studies ranged from 20 participants to 286 participants. Given the clinical heterogeneity of intervention and control conditions in the body of evidence, this review grouped the studies into comparisons according to the control conditions (i.e., wait list/no intervention; brief intervention; counseling intervention; rapid/focused smoking; drug; placebo drug; or other treatment). The studies varied greatly in the method of hypnotic induction and the number and duration of hypnotherapy sessions they used. In general, this review found no evidence of a difference in smoking cessation at 6 months or greater followup among trials that compared hypnotherapy versus no intervention or other smoking cessation interventions.

#### Tobacco Cessation Interventions Among Specific Adult Subpopulations (Not Including Pregnant Women or Those With Mental Health Conditions)

Within the 54 included reviews, seven reviews synthesized evidence on pharmacotherapy and/or behavioral tobacco cessation interventions among specific subpopulations of adults: one review concentrated on smokeless tobacco users,115 four reviews focused on cessation interventions for racial and ethnic minority groups,109,123,126,134 one only included results for young adults,150 and one focused on interventions among older adult smokers153 (Table 1 and Table 8). We summarize the results of each review for specific subpopulations. None of these reviews were considered primary reviews.

Table 8 Inclusion Criteria of Reviews on the Efficacy and Safety of Pharmacotherapy Tobacco Cessation Interventions Among Specific Adult Subpopulations, by Alphabetical Order

Review, Year Quality | Intervention | Comparison | Last Search Date | Number of Included Studies | Funding Source | Study Design^†^ | Population | Outcomes | Followup | Setting
Carson, 2012^109^ Fair | Pharm, cognitive and behavioral therapies, alternative therapies, public policy, and combination therapy | Usual care, minimal or no intervention, placebo | April-11 | 4 | NR | RCTs or quasi-RCTs | Young people and adults of any age and either sex, who were Indigenous to their country and were active smokers participating in a smoking cessation study | Smoking abstinence | ≥6 months | Any
Ebbert, 2011^115^ Good | Pharm or behavioral | Usual care, placebo, or less intensive intervention | Oct-10 | 25 | NR | RCTs or pseudo-RCTs | Smokeless tobacco users | Tobacco abstinence | ≥6 months | Any
Johnston, 2013^123^ Fair | Behavioral | Usual care | May-12 | 5 | National Health and Medical Research Council of Australia; Health Research Council of New Zealand; James Russell Lewis Trust, New Zealand | RCTs, CCTs | Nonindigenous and indigenous adult smokers from Australia, New Zealand, United States, or Canada | Smoking abstinence | Not clearly stated | NR
Liu, 2013^126^ Fair | Behavioral (culturally adapted interventions) | Usual care or nonadapted intervention | April-13 | 28 | Medical Research Council, UK | RCTs, CCTs | Children and nonpregnant adult smokers of African-, Chinese- or South Asian-origin | Smoking abstinence | Not clearly stated | Not clearly stated but generally community-based
Nierkens, 2013^134^ Good | Behavioral (culturally adapted interventions) | Same intervention without the cultural adaptation | April-10 | 5 | Department of Public Health of the Academic Medical Center/University of Amsterdam | RCTs or non-RCTs | Adult ethnic minority population living in a high-income society | Smoking abstinence | ≥1 month | Not clearly stated
Villanti, 2010^150^ Fair | Pharm or behavioral | No intervention, delayed intervention after the last date of followup, information or education on smoking cessation, and general tobacco education or general health education | Aug-09 | 14 | Doctoral training program by the Department of Health, Behavior and Society, Johns Hopkins Bloomberg School of Public Health, and the Maryland Cigarette Restitution Fund Research Grant to the Johns Hopkins Medical Institutions | Individual or group RCTs, controlled trials, quasi-experimental studies, and cohort studies | Smoking young adults (aged 18-24 years); light and intermittent smokers included | Smoking abstinence | >1 month | Not clearly stated but included colleges/universities
Zbikowski, 2012^153^ Fair | Behavioral and pharm | Not clearly stated | June-11 | 13 | NR | Clinical trials, randomized trials, and CCTs | Smokers aged ≥50 years | Smoking abstinence | Not clearly stated | Any

† Quasi-RCTS are those that use quasi-random methods of assignment including alternation, date of birth, or medical record number.

Abbreviations: CCT = case-control trial; NR = not reported; pharm = pharmacotherapy; RCT = randomized controlled trial; UK = United Kingdom.

The good-quality Ebbert review (2011) included 25 RCTs (presenting 27 comparisons) that examined the effectiveness of pharmacotherapy (11 trials) or behavioral tobacco cessation interventions (14 trials) among users of smokeless tobacco products (e.g., moist snuff, chewing tobacco, Swedish snus, Asian Indian smokeless tobacco products such as gutkha and pan masala) with evidence included through October, 2010. Eleven trials compared a specific pharmacotherapy with a placebo for the effect on all-tobacco or smokeless tobacco abstinence. Two small trials of bupropion SR did not find an effect on continuous all-tobacco abstinence at 6 months. Similarly, there was no effect of NRT including gum, patch and lozenge on smokeless tobacco abstinence (3 studies) on all-tobacco abstinence (5 studies). One study of 431 Swedish snus users reported a statistically significant benefit of varenicline for 12 weeks on biochemically validated continuous all-tobacco abstinence at 6 months, versus placebo (odds ratio [OR] 1.6 [95% CI, 1.08 to 2.36]). Among the 14 behavioral intervention trials, the review found high heterogeneity including by how participants were recruited, the motivation to quit among the sample, and the additional intervention components, such as the inclusion or not of an oral examination or telephone support. Thus, the trials were not amenable to pooling and had mixed results individually. Seven studies showed statistically significant effects, five showed nonsignificant trends toward a benefit, and two studies presented odds ratios just below one and relatively narrow confidence intervals.

Four reviews109,123,126,134 focused on tobacco cessation interventions among racial and ethnic minorities (Table 8). Two similar reviews, the Liu review (2013)126 and Nierkens review (2013),134 examined the effectiveness of U.S.-based smoking cessation interventions that explicitly included cultural adaptations for ethnic minority smokers. The Liu review (k=28, last search April, 2013) reported mixed evidence regarding the effectiveness of adapted versus nonadapted interventions on smoking outcomes, whereas the Nierkens review (k=5, last search April, 2010) reported statistically significant benefits of culturally adapted interventions on smoking cessation in four out of five included studies. Both reviews concluded there was greater acceptability of the culturally adapted interventions, but that more evidence was needed on the effectiveness on smoking cessation, including the benefits for deep- versus surface-structure adaptations. The Carson review (2012) and Johnston review (2013) both specifically examined the effectiveness of interventions for smoking cessation in Indigenous populations.109,123 All but one of the included studies in both reviews, however, were relevant only to indigenous people in New Zealand (Maori) and Australia (aboriginal peoples). The Carson review included one cluster-randomized study183 targeting urban health clinics that served American Indians. This study found statistically nonsignificant effects of a culturally-tailored staff training intervention on point prevalence smoking abstinence at 6 months.

Subpopulations based on age were the focus of the Villanti review (2010)150 and Zbikowski review (2012),153 which examined the effect of pharmacotherapy and behavioral interventions among younger (18-24 years) and older (50 years or older) adults, respectively. The Villanti review included 14 studies that evaluated behavioral cessation interventions targeting young adults who were moderate-to-high smokers. While the review located no studies of pharmacotherapies in young adults, the last search date for this review was August 2009. Of the 14 included studies, only two had signifıcant results at 4–6 months. One of the studies included 20 weekly visits to a website that provided personalized smoking cessation messages and weekly emails from peer coaches and was also included in the primary computer-based interventions review by Civljak. The other successful intervention included self-help booklets plus telephone counseling provided to those calling a quitline. This study was also included in the Stead (2013c) telephone counseling review. The Zbikowski review reported that nine out of 13 included studies reported statistically significant effects of behavioral and/or pharmacotherapy interventions on smoking cessation at 6 months or more followup among adults aged 50 and older. The review concluded that more intensive interventions and interventions with combined approaches (pharmacotherapy and followup counseling) achieve the best outcomes. The quit rates from their included studies and the relative effectiveness of the specific interventions are consistent with the evidence on smoking cessation in the general adult population.

#### Electronic Nicotine Delivery System Interventions Among Adults

Based on a search for primary evidence and a review of 25 full-text articles (Appendix B Figure 2), we identified two RCTs that evaluated the effectiveness of using e-cigarettes to help current conventional smokers stop or reduce smoking (Table 9). In the largest fair-quality trial, conducted in New Zealand, Bullen and colleagues randomized 657 smokers interested in quitting to one of three interventions: 16 milligram (mg) nicotine e-cigarette, 21 mg nicotine patch, or placebo e-cigarette.105 The method for receiving the respective interventions differed: those randomized to one of the e-cigarette arms were directly mailed the e-cigarette, a spare battery and charger, cartridges, and simple instructions on how to use the e-cigarette whereas those randomized to receive a patch were mailed cards and vouchers to redeem a patch from community pharmacies. All participants were also offered telephone-based support via a quitline which called them directly; participants who declined or did not call back were still able to access other quitline support such as text-messages. At 6 months, there were no significant differences in biochemically verified continuous smoking abstinence between groups. Tobacco smoking cessation was generally low in all three groups: 7.3 percent with e-cigarettes, 5.8 percent with nicotine patches, and 4.1 percent with placebo e-cigarettes. Adherence to treatment was significantly higher in the nicotine e-cigarette and placebo e-cigarette groups compared with the patches (p<0.0001) at each follow-up assessment. In addition, 29 percent of non-quitters still used e-cigarettes at 6 months, although it was unknown whether they were using nicotine or non-nicotine cartridges. There was also differential loss-to-followup between groups with only 73 percent of those assigned to the patch retained at 6 months versus 83 percent and 78 percent of those randomized to the nicotine and placebo e-cigarette groups with followup data at 6 months, respectively.

Table 9 Efficacy and Safety of the Use of Electronic Nicotine Delivery Systems for Smoking Cessation

Study | Study Design Country | Sample Size, n | Population | Intervention | Control | Tobacco Cessation Outcomes | Other Outcomes | Adverse Events
Bullen, 2013^105^ | RCT New Zealand | Total: 657 IG: 289 CG1: 295 CG2: 73 | Age ≥18 years, had smoked ≥10 cigarettes per day for at least the past year, wanted to stop smoking | IG: Elusion e-cig (16 mg nicotine) + voluntary quitline behavioral support Duration: From 1 week before until 12 weeks after chosen quit date | CG1: NRT patch (21 mg nicotine per 24 hours) CG2: placebo e-cigs + voluntary quitline behavioral support | Continuous abstinence at 6 months post quit date (allowing ≤5 cigarettes); biochemically verified: IG: 7.3% CG1: 5.8% CG2: 4.1% *No statistically significant differences between groups 1- and 3-month cessation rates also did not differ | Median time to relapse: IG: 35 days (95% CI: 15, 56) CG1: 14 days (95% CI: 8,18)* CG2: 12 days (95% CI: 5, 34) *P<0.0001 Mean (SE) cigarette consumption at 6 months among those smoking ≥1 cigarette in past 7 days: IG: 9.7 (0.4) CG1: 7.7 (0.4) P=0.002 | No serious events in any groups were related to product use
Caponnetto, 2013^107^ EffiCiency and safety of an eLectronic cigAreTte (ECLAT) | RCT Italy | Total: 300 IG1: 100 IG2: 100 CG: 100 | Ages 18–70 years, had smoked ≥10 cigarettes per day for at least the past 5 years, not currently attempting to quit smoking or wishing to do so in the next 30 days | Categoria 401 e-cig IG1: 12 weeks of 7.2 mg nicotine cartridges used ad libitum IG2: 6 weeks of 7.2 mg nicotine cartridges and 6 weeks of 5.4 mg nicotine cartridges used ad libitum Baseline visit and 8 followup visits (2-, 4-, 6-, 8-, 10-, 12-, 24-, 52-weeks) | Categoria 401 e-cig CG: 12 weeks of no-nicotine cartridges used ad libitum | Abstinence (not even a puff) since previous study visit; biochemically verified: 24 weeks IG1: 12.0% IG2: 10.0% CG: 5.0% Difference NR 52 weeks IG1: 13.0% IG2: 9.0% CG: 4.0% *Significant difference between IG1 and IG2 (11.0%) and CG (4.0%) (p=0.04) | Self-reported number of cig/day: Significant reduction in median value in all 3 groups at each time point; no between-group differences at 12, 24, or 52 weeks | No difference in frequency of adverse events among study groups at each time point

Abbreviations: CG = control group; CI = confidence interval; cig = cigarette; e-cig = electronic cigarette; IG = intervention group; mg = milligrams; n = number; NRT = nicotine replacement therapy; RCT = randomized controlled trial; SE = standard error.

In another fair-quality RCT conducted in Italy by Caponnetto and colleagues, 300 conventional smokers who were not intending to quit were randomized to receive one of three e-cigarette nicotine cartridge doses for the Categoria brand model 401 e-cigarette: 7.2 mg nicotine for 12 weeks; 7.2 mg nicotine for 6 weeks followed by 5.4 mg nicotine for 6 weeks; or cartridges with no nicotine. The appearance of the cartridges were identical to maximize blinding; although it is unclear whether allocation was concealed. After the 12-week intervention phase participants were free to purchase e-cigarettes on their own. At 52 weeks, biochemically verified quit rates were borderline statistically significantly different (p=0.04) between participants in both nicotine groups (11%) and those receiving no nicotine cartridges (4%). There was no between-group difference in the median number of cigarettes smoked per day at any followup time point.107 The study did not report whether there was blinding of outcome assessors. In addition, there was substantial loss to followup with 36 percent of those randomized to one of the nicotine-containing cartridges and 45 percent of those receiving non-nicotine cartridges without 12-month followup data.

### Key Question 3 What Adverse Events Are Associated With Tobacco Cessation Interventions?

#### Pharmacotherapy Interventions Among Adults

We included seven reviews that reported adverse events related to pharmacotherapy interventions for smoking cessation in general adult populations (Table 1 and Table 2).120,121,128, 130,135,145,154 Of the six reviews that evaluated the efficacy of pharmacotherapy, two did not systematically review harms of the interventions.129,140 Mills published two separate reviews: one specifically on cardiovascular (CV) adverse events related to NRT, bupropion SR, or varenicline (Mills, 2010)130 and one on any adverse events related to NRT (Mills, 2014).128 One additional review, the Prochaska review (2012), focused specifically on the risk of CV events associated with varenicline.135 We discuss the results for all reviews that reported harms for each form of pharmacotherapy individually.

##### Nicotine Replacement Therapy

The most recent review of harms, the Mills review (2014), included all RCTs reporting CV adverse events within trials evaluating NRT, bupropion SR, or varenicline for tobacco cessation (Table 2).130 The review categorized CV events into two categories: (1) any CV event which included any clinical diagnoses of a CV event including minor events such as palpitations, bradycardia, and arrhythmia) and (2) major adverse CV events as defined by the FDA as a combined outcome of cardiovascular death, nonfatal myocardial infarction, and nonfatal stroke. For NRT among non-high-risk adults, pooled results suggested a statistically significant increased risk of any CV event among those randomized to NRT compared with placebo (RR 1.81 [95% CI, 1.35 to 2.43]; I^2^=0%; k=21; 11,647) (Table 10). When restricted to major adverse CV events, pooled results did not clearly establish harm (RR 1.38 [95% CI, 0.58 to 3.26]; I^2^=0%). The confidence interval was quite wide, however, and incorporated potential benefit as well as significant harm. As such, this issue deserves further study. A sensitivity analysis found that the treatment effects were driven predominately by more minor CV events, including tachycardia and arrhythmia, and occurred primarily in studies with longer followup periods. The direction of effects was similar among trials of high-risk patients (three studies), although neither outcome (all CV events or major CV events) reached statistical significance.

Table 10 Adverse Event Results (KQ 3) of Pharmacotherapy Smoking Cessation Interventions Among Adults

Adverse event | Comparison | Number of RCTs | Number of Participants | IG Events | IG N | CG Events | CG N | Effect Estimate | 95% CI | I^2^
All CV adverse events130 | NRT vs. placebo | 21 | 11,647 | 202 | 6,329 | 83 | 5,318 | RR: 1.81 | 1.35, 2.43 | 0%
Major CV adverse events130 | NRT vs. placebo | 21 | 11,647 | 12 | 6,329 | 7 | 5,318 | RR: 1.38 | 0.58, 3.26 | 0%
Mortality128 | NRT vs. placebo/usual care | 8 | 2,765 | 11 | 1,387 | 16 | 1,378 | OR: 0.74 | 0.33, 1.67 | 0%
All CV adverse events130 | Bupropion SR vs. placebo | 27 | 10,402 | 50 | 5,947 | 42 | 4,455 | RR: 1.03 | 0.71, 1.50 | 0%
Major CV adverse events130 | Bupropion SR vs. placebo | 27 | 10,402 | 15 | 5,947 | 25 | 4,455 | RR: 0.57 | 0.31, 1.04 | 0%
Serious adverse events121 | Bupropion SR vs. placebo/no bupropion SR control | 33 | 9,631 | 114 | 5,328 | 80 | 4,303 | RR: 1.30 | 1.00, 1.69 | 0%
All CV adverse events130 | Varenicline vs. placebo | 18 | 9,072 | 63 | 5,469 | 41 | 3,603 | RR: 1.24 | 0.85, 1.81 | 0%
Major CV adverse events130 | Varenicline vs. placebo | 18 | 9,072 | 22 | 5,469 | 13 | 3,603 | RR: 1.44 | 0.73, 2.83 | 0%
Major CV adverse events135 | Varenicline vs. placebo | 22^*^ | 9,232 | 34 | 5,431 | 18 | 3,801 | RD: 0.27^†^ | -0.10, 0.63 | 0%
Nonfatal serious adverse events154,‡ | Varenicline vs. placebo | 17 | 7,725 | 126 | 4,274 | 76 | 3,451 | RR: 1.36 | 1.03, 1.81 | 0%

* Most of the included trials included individuals with current (2 studies) or past (11 studies) cardiovascular disease

† For comparison, the risk ratio based on 14 trials with at least one event was 1.40 (95% CI, 0.82 to 2.39; I^2^=0%; n=7,636)

‡ Medical occurrence that was life-threatening; required inpatient hospitalization or prolongation of existing hospitalization; or resulted in persistent or significant disability or incapacity. Does not distinguish between adverse events that can be attributed to and those unrelated to treatment and includes those occurring during the treatment and followup periods.

Abbreviations: CI = confidence interval; CG = control group; CV = cardiovascular; IG = intervention group; N = number; NRT = nicotine replacement therapy; OR = Odds ratio (based on DerSimonian-Laird random effects model); RCT = randomized controlled trial; RD = Risk difference; RR = Risk ratio; SR = sustained release; vs = versus.

The second Mills review (2010) examined the relative rate and prevalence of physical and mental adverse events, including life-threatening adverse events, within 92 RCTs comparing NRT with a non-NRT control (e.g., placebo, usual care) and 28 observational studies (Table 2).128 The review pooled RCTs reporting similar adverse event outcomes and estimated odds ratios (as opposed to risk ratios as presented in most other included reviews) for the risk of each event related to NRT. Pooled results found an increased risk of NRT versus non-NRT control for heart palpitations and chest pains; nausea and vomiting (particularly among non-NRT patch users); gastrointestinal complaints; and insomnia. There was no statistically significant increased risk of headache, dizziness, anxiety or depression, or mortality. An increase in skin irritations was specifically related to use of the NRT patch. Mouth and throat soreness, mouth ulcers, and hiccoughs were related to use of oral NRT. Eight studies reported on mortality and did not find a significant association between NRT and controls (OR 0.74 [95% CI, 0.33 to 1.67]; I^2^=0%; n=2,765) (Table 10). While the Mills review (2010) reported that 25 RCTs reported serious adverse events and indicate that none found a significant increase in serious adverse events with NRT, they do not present the data. As such, we cannot draw definitive conclusions.

##### Bupropion

The Mills (2014) review suggested no significant increased risk of any CV event for bupropion SR versus placebo (RR 1.03 [95% CI, 0.71 to 1.50], I^2^=0%; k=27; n=10,402) (Table 10). The confidence interval of the pooled estimate was wide and consistent with a mildly beneficial or mildly harmful effect. While the results for major CV events were imprecise due to small numbers of events, they were consistent with a possible protective effect or very minor harms (RR 0.57 [95% CI, 0.31 to 1.04]; I^2^=0%; k=27; n=10,402) (Table 10).130 When restricted to the eight trials of high-risk patients, the results were in the same direction as non-high-risk adults, but were not statistically significant.130

The Hughes review (2014) examined serious adverse events reported in 33 trials of bupropion SR versus placebo or no pharmacotherapy control.121 This review included studies that were not included in their efficacy analysis because of short followup (i.e., less than 6 months). Serious adverse events were defined per the FDA as any event that was life-threatening, resulted in hospitalization, death, disability, or permanent damage, or required intervention to prevent one of the above outcomes reported during or within 30 days of drug treatment. This review found a nonstatistically significant increased risk in the rate of serious adverse events while on treatment among those randomized to bupropion SR versus control (RR 1.30 [95% CI, 1.00 to 1.69], I^2^=0%; k=33; n=9,631), with serious adverse event rates of 2.1 percent for bupropion SR users and 1.9 percent for placebo users or non-bupropion SR participants (Table 10). The review found no difference between groups in terms of psychiatric serious events (RR 0.60 [95% CI, 0.28 to 1.28]; k=19; data not shown) or cardiovascular serious events (RR 1.16 [95% CI, 0.65 to 2.06]; k=25; data not shown). The review reported 10 cases of seizures within seven trials that comprised between 100 and 502 individuals receiving bupropion SR (over 13,000 total participants). The review reports this event rate is similar to the rate of 1:1,000 seen in observational evidence and found in product safety data.

##### Varenicline

Within the Mills (2014) review, among 18 RCTs comparing varenicline with placebo, there was no evidence of an increased risk of any CV adverse events (RR 1.24 [95% CI, 0.85 to 1.81], I^2^=0%; k=18; n=9,072) or major CV adverse events among adults (RR 1.44 [95% CI, 0.73 to 2.83]; I^2^=0%; k=18; n=9,072) (Table 10).130 The Prochaska review (2012) included 22 double-blind placebo-controlled trials and found a pooled absolute rate of cardiovascular serious adverse events of 0.63 percent (34/5431) for the varenicline group and 0.47 percent (18/3801) for the placebo group. The risk difference and relative risk, however, were not statistically significant.135 The pooled risk difference was 0.27 percent (95% CI, -0.10 to 0.63; I^2^=0%) (Table 10). This review also included relative estimates of risk based on studies with at least one event for comparison and reported a risk ratio of 1.40 (95% CI, 0.82 to 2.39; I^2^=0%). Most of the 22 included trials included individuals with current (2 studies) or past (11 studies) CV disease. Six of the 22 included trials were not included in the Mills 2014 review and, as such, these reviews represent somewhat different bodies of evidence.

In addition to synthesizing the evidence on the effectiveness of varenicline, the Cahill review also recorded any adverse effects of varenicline treatment.154 Nonfatal serious adverse events were reported in 19 of the 20 included trials and a meta-analysis of 17 of these trials (excluding two trials that were not placebo controlled) found an increased risk of one or more serious adverse event among those receiving varenicline, compared with placebo, excluding events that occurred post-treatment (RR 1.36 [95% CI: 1.03 to 1.81]; I^2^=0%; k=17; n=7,725) (Table 10). This estimate was based on simple counts across the trials that reported one or more adverse event from participants and does not distinguish between events attributed to or those unrelated to treatment, or between those occurring during the treatment and followup periods. There were no treatment-related deaths in any of the interventions groups during treatment or followup.

Post-marketing surveillance has led to additional safety concerns related to depressed mood, suicide ideation, and suicide behavior concerning both bupropion SR and varenicline. For varenicline, experts have also raised drug safety concerns related to cardiovascular events. We present FDA-issued communication regarding both medications in the Discussion chapter.

##### Combined Pharmacotherapy and Behavioral Interventions

The one included review on combined pharmacotherapy and behavioral interventions did not report any adverse events related to the interventions.138

#### Behavioral Interventions Among Adults

We examined all 26 included reviews to determine if they measured adverse events related to the interventions. Only two of the 26 included reviews, the Di review and the Barnes review, reported adverse events related to the interventions and both evaluated complementary and alternative therapies.100,114 The Di review summarized adverse events reported in 13 out of 25 included trials that evaluated the effects of ear-acupuncture, ear-acupressure, and auriculotherapy for smoking cessation. Eight studies reported 115 minor adverse events associated with the intervention (two additional studies did not specify the number of events and another two reported no adverse events). The most reported adverse events from ear acupuncture included sore ears, tenderness, and sensitivity around residual needles, bruising, facial swelling, headache, dizziness, nausea, giddiness, vomiting, euphoria, and insomnia. Adverse events related to ear acupressure included skin allergy to adhesive tape, itchy or sore ear, and discomfort due to ear beads. The remaining study reported that one participant withdrew due to discomfort.114 The Barnes review looked for reported adverse events among participants taking part in hypnotherapy interventions and found that none of the 11 included studies reported adverse events.100

#### Electronic Nicotine Delivery System Interventions Among Adults

Two RCTs that we included as primary evidence that evaluated the effectiveness of ENDS to aid in quitting smoking conventional cigarettes reported that there were no serious adverse events in either the intervention or control groups related to product use105 and no differences in the frequency of adverse events among study groups (Table 9).107 The study by Bullen and colleagues found that there was a nonstatistically significant difference in the incidence rate ratio (IRR) for adverse events between these groups (IRR 1.05 [95% CI, 0.82 to 1.34], p=0.7), despite a higher number and proportion of serious adverse events occurring in the nicotine e-cigarette group (27 serious events, 19.7%) than in the nicotine patch group (14 events, 11.8%). The authors deemed none of the adverse events to be related to product use in any of the treatment groups. The study by Caponnetto and colleagues similarly found no difference in the frequency of adverse events among study groups at 12 and 52 weeks. No serious events occurred during the study.107

## Pregnant Women: Results of Included Reviews

Of the 54 eligible reviews identified for our review of reviews, we included eight that evaluated smoking cessation interventions among pregnant women (Table 1 and Table 11).92,110,116,119,125, 127,133,143 Of these eight reviews, three reviewed both pharmacotherapy and behavioral interventions,125,127,143 whereas two assessed pharmacotherapy92,133 and three behavioral interventions alone.110,116,119 Five reported perinatal health outcomes.92,110,125,127,133

Table 11 Inclusion Criteria of Included Existing Systematic Reviews on the Efficacy and Adverse Events of Tobacco Cessation Interventions Among Pregnant Women, by Alphabetical Order

Review, Year Quality | Intervention | Comparison | Last Search Date | Number of Included Studies | Funding Source | Study Design^†^ | Population | Outcomes | Followup | Setting
*Chamberlain, 2013^110^ Good | Behavioral counseling | Usual care; less intensive interventions; alternative interventions | Mar-13 | 86 | WHO, Australian Government Department of Health and Aging, National Health Service (UK), EPPI-Center | RCTs, cluster-randomized trials, randomized cross-over trials, quasi-RCTs | Pregnant smokers or pregnant women who have recently quit smoking; women who are currently smoking or have recently quit and are seeking a pre-pregnancy consultation; or health professionals in trials of implementation strategies to support pregnant women to stop smoking | Smoking abstinence; perinatal outcomes | Not clearly stated | Any
*Coleman, 2012^92^ Good | Pharm | Placebo; behavioral support or cognitive behavior therapy | Mar-12 | 6 | British Heart Foundation, Cancer Research UK, Economic and Social Research Council, Medical Research Council and the Department of Health, under the auspices of the UK Clinical Research Collaboration | RCTs | Pregnant smokers | Smoking abstinence; perinatal outcomes; AEs | NR | Any
Filion, 2011^116^ Fair | Behavioral counseling | Usual care | June-10 | 8 | Canadian Institutes of Health Research | RCTs | Pregnant smokers | Smoking abstinence | ≥6 months | Any
Hettema, 2010^119^ Fair | Motivational interviewing | Non-MI | June-08 | Total: 31 (Pregnant: 8) | NR | RCTs | Pregnant and nonpregnant smoking adults | Smoking abstinence | Short-term (≤6 months) or long term (≥6 months); end of pregnancy | Any
Likis, 2014s125 Good | Pharm or behavioral | Different intervention, usual care, placebo | Jan-13 | 59 | AHRQ | RCTs or prospective cohorts (harms only) | Pregnant or postpartum who smoke or quit smoking during index pregnancy | Smoking abstinence; relapse; infant/child outcomes; AEs | Any | Clinician-initiated or intersects with clinical care
Lumley, 2009^127^ Good | Pharm or behavioral | Usual care | June-08 | 72 | Australian Commonwealth Department of Health and Aging; 3 centres Collaboration (supported by the Victorian Department of Human Services) | RCTs and quasi-RCTs | Pregnant smokers in any care setting; women seeking a pre-pregnancy consultation; health professionals | Smoking abstinence; smoking reduction; maternal outcomes; infant outcomes; breastfeeding | Not clearly stated | Any
Myung, 2012^133^ Good | Pharm | Placebo; no intervention; counseling | June-11 | 7 | No funding was received | RCTs, quasi-RCTs, retrospective or prospective controlled studies | Pregnant smokers | Smoking abstinence; perinatal outcomes; AEs | Criterion not clearly stated, but range in the included studies was 12 to ~26 weeks | Any
Su, 2013^143^ Fair | Behavioral, pharm, or incentive-based interventions | Not clearly stated, but placebo, routine care, counseling discussed | Dec-12 | 32 | NR | RCTs, CCTs | Pregnant women smokers (focus on nonspontaneous quitters); interested in following women who quit during pregnancy through the postpartum period | Smoking abstinence | 4 weeks after birth and up to 1 year postpartum to monitor the characteristics of relapse over time | Not clearly stated

* Review served as basis for main finding

† Quasi-RCTS are those that use quasi-random methods of assignment including alternation, date of birth, or medical record number.

Abbreviations: AE = adverse events; AHRQ = Agency for Healthcare Research and Quality; CCT = case-control trial; NR = not reported; Pharm = pharmacotherapy; RCT = randomized controlled trial; UK = United Kingdom; WHO = World Health Organization.

### Key Question 1 Do Tobacco Cessation Interventions Improve Mortality, Morbidity, and Other Health Outcomes in Pregnant Women?

#### Pharmacotherapy Interventions Among Pregnant Women

The most recent and comprehensive review on pharmacotherapy for pregnant women is the Coleman review (2012). This good-quality review included six RCTs with last search through March, 2012.^92^ All of the interventions included in this review randomized participants to NRT. No trials of bupropion SR or varenicline among pregnant smokers were identified (Table 12). The Myung review (2012) was a slightly more recently published review133 that included only one additional quasi-RCT NRT trial (Appendix C Figure 4). This trial did not include a placebo control and was excluded from the Coleman review because there was nonrandom self-selection of participants to NRT, multiple intervention components, and problems with study design that did not permit valid inferences on the effect of NRT alone. The Myung review also was not as comprehensive in reporting as the Coleman review.

Table 12 Descriptive Characteristics of Included Studies Within the Main Reviews on the Efficacy and Safety of Tobacco Cessation Interventions Among Pregnant Women

Review, Year | Number of Included Studies | Sample Size (Range) | Demographic Characteristics | Baseline Smoking Status | Readiness to Quit/ Quit History | Intervention Characteristics | Treatment Setting/Provider Characteristics
Coleman, 2012^92^ | 6 | Range: 30 to 1,050 | Average age: NR Race: NR SES: NR Comorbidities/other substance use: NR | Smoking status: Range ≥1 to ≥15 (average cpd range) Nicotine dependence: NR consistently Partner smoking status: NR consistently Spontaneous quitting: NR consistently | Readiness to quit: 2 RCTs recruited participants who “agreed to set a quit date” or “who wanted to quit smoking” Quit history: NR consistently | All included RCTs evaluated NRT:; - Placebo controlled (k=4); - NRT plus behavioral support with behavioral support alone (k=2) | Setting: NR Providers: NR, although 1 trial reported using “research midwives”
Chamberlain, 2013^110^ | 86 | NR | Average age: most trials included women age >16 years, with only 2 trials targeting young women age <20 years and 1 trial including women age >15 years Race: 7 RCTs included mainly women belonging to an ethnic minority population: 2 were conducted in aboriginal communities and Alaskan native women; 1 RCT included >40% Maori women SES: 47 RCTs included women categorized as having low SES Comorbidities/other substance use:; - RCTs targeted women with psychosocial risk factors (k=4); - RCTs conducted in women requiring methadone treatment (k=2) | Smoking status: NR Nicotine dependence: NR consistently Partner smoking: Baseline NR; 4 studies examined associations with partner smoking and abstinence in late pregnancy Spontaneous quitting: NR consistently | Readiness to quit: NR consistently Quit history: 1,740 women reported “spontaneously quitting” when they became pregnant | Included 77 RCTs; - Counseling (k=48); - Health education (k=7); - Feedback (k=7); - Incentives (k=4); - Social support (k=10); - Other (k=1); 1 RCT was aimed exclusively at women who had spontaneously quit smoking, and 11 trials included a relapse prevention component for women who had spontaneously quit. 13 of the counselling interventions involved telephone counselling and in 5 of these RCTs all counselling was provided via phone and 1 had only brief additional face to-face contact. 26 RCTs included self-help manuals as part of the intervention. 6 RCTs used video alone; 5 RCTs included computers; 1 RCT used audiotapes and 1 used text messages. | Setting: Most trials were conducted in public hospitals or community antenatal clinics Providers: In 26 RCTs the intervention was provided by routine pregnancy care providers; 43 trials used research project staff or automated technology

Abbreviations: cpd = cigarettes per day; k = number of studies; NR = not reported; NRT = nicotine replacement therapy; pharm = pharmacotherapy; RCT = randomized controlled trial; SES = socioeconomic status.

Given the small number of trials included in these reviews, the lack of trials of bupropion SR and varenicline, and the time since their last search dates, we conducted a search for primary evidence to bridge the Coleman review (see Methods chapter for details) to the present. We applied the inclusion criteria used in the Coleman review for our study selection. This primary search identified nine full-text studies to review for inclusion and eligibility (Appendix B Figure 3). After full-text review, one fair-quality placebo-controlled trial of NRT met the inclusion criteria.101 Adding this trial to those included in the Coleman review left us with seven trials on the effects of pharmacotherapies among pregnant women included in our review of reviews (Table 13).

Table 13 Descriptive Characteristics of Included Trials of Pharmacotherapy Interventions Among Pregnant Women

Review, Year | Study Design | N Randomized | Country | Demographic Characteristics | Baseline Smoking Status | Readiness to Quit/ Quit History | Intervention Details | Outcomes of Interest
Berlin, 2014^101^ | RCT | 402 | France | Average age: 29.3 years^*^ Race: NR SES: Annual household income (Euro), % <12,000: 32.6^†^ 12,000–30,000: 50.0^†^ 30,000–100,000: 16.7^†^ >100,000: 0.7^†^ % Nulliparous: 27.9^†^ | Smoking status: 10.5 (median cpd) Nicotine dependence: NR | Readiness to quit: Participants were required to have scored ≥5 on a motivational scale (range 0-10) Quit history: Previous quit attempts (≥1 week): 1^*^ | Nicotine patch (10-15 mg/day) vs. placebo patch Participants were between 9 and 20 weeks pregnant and smoked ≥ 5 cpd. | Smoking abstinence, infant birth weight, head circumference, IUGR, serious adverse events
Coleman, 2012^184^ | RCT | 1,050 | UK | Average age: 26.3 years^†^ Race: % White: 97.0^†^ SES: Mean age at leaving full-time education: 16.3 years^†^ % Nulliparous: 0-1: 68.5 | Smoking status: 14 (median cpd) † Nicotine dependence: NR | Readiness to quit: NR Quit history: NR | Behavioral counseling (1 face-to-face and 3 telephone sessions) plus nicotine patch (15 mg/16 hrs) vs. placebo patch plus behavioral counseling alone Participants were between 12 and 24 weeks pregnant and smoked ≥5 cpd. | Smoking abstinence; miscarriage; stillbirth; infant birth weight; preterm birth serious adverse events
Hotham 2006^187^ | Non-placebo parallel-design RCT | 40 | Australia | Average age: 29.3 years^†^ Race: NR SES: NR % Nulliparous: NR | Smoking status: 19.8^†^ (average cpd) Nicotine dependence: NR | Readiness to quit: NR Quit history: NR | Behavioral counseling (5 min session at BL and <2 min sessions at followup visits) plus nicotine patch (15 mg/16 hrs for a maximum of 12 weeks) vs. behavioral counseling alone Participants were between 12 and 28 weeks pregnant and smoked ≥15 cpd. | Smoking abstinence; adverse reaction to patch
Kapur 2001^186^ | RCT | 30 | Canada | Average age: NR Race: NR SES: NA % Nulliparous: NR | Smoking status: NR Nicotine dependence: NR | Readiness to quit: participants required to “want to quit” upon entry Quit history: NR | Behavioral counseling (1 video followed by weekly telephone sessions) plus nicotine patch (15 mg/18 hrs for 8 wks; 10 mg/18 hrs for 2 wks; 5 mg/18 hrs for 2 wks) vs. placebo patch plus behavioral counseling alone Participants were between 12 and 24 weeks pregnant and smoked ≥15 cpd. | Smoking abstinence
Oncken 2008^188^ | RCT | 194 | US | Average age: 25.1 years^†^ Race, %: Hispanic: 54.1^†^ Non-Hispanic white: 35.1^†^ Non-Hispanic black: 7.7^†^ Other: 3.1^†^ SES, %: Less than HS: 50^†^ HS: 33^†^ More than HS: 17^†^ % Nulliparous: 16.5^†^ | Smoking status: 9.5 (average cpd) Nicotine dependence: NR | Readiness to quit: NR Quit history: Previous quit attempts, mean: 2.79 | Behavioral counseling (8 face-to-face sessions) plus nicotine gum (2 mg) vs. placebo gum plus behavioral counseling alone Eligible participants were ≤26 weeks pregnant and smoked ≥1 cpd | Smoking abstinence; mean birth weight; gestational age; head circumference; neonatal length of stay
Pollak 2007^189^ | Non-placebo parallel-design RCT | 181 | US | Average age: 27 years Race: % White: 69 % Black: 24 % Other: 8 SES, %: Less than HS: 28 HS/GED: 31 Vocational school: 7 Some college: 31 College graduate or higher: 5 % Nulliparous: 16 | Smoking status: 11 (average cpd) Nicotine dependence: NR | Readiness to quit: Stage of readiness, %: Pre-contemplation: 1 Contemplation: 7 Preparation: 92 Quit history: Had a 24 hr quit attempt, %: 58 | Behavioral counseling (5 face-to-face and 1 telephone session) plus the choice of NRT from patch (7-21 mg/16 hrs depending on cpd), gum (2 mg per each cpd), or lozenge (2 mg per each cpd) vs. behavioral counseling alone Participants were between 13 and 25 weeks pregnant and smoked ≥5 cpd. | Smoking abstinence; mean birth weight; serious adverse events
Wisborg 2000^185^ | RCT | 250 | Denmark | Average age: 28.4 years^†^ Race: NR SES: Years of schooling: <10: 18.4^†^ ≥10: 66.8^†^ Missing: 14.8^†^ % Nulliparous: 42.8^†^ | Smoking status: 13.8^†^ (average cpd) Nicotine dependence: NR | Readiness to quit: NR Quit history: Previous attempts to quit, % 0-2: 68.8^†^ 3-15: 31.2^†^ | Nicotine patch (15 mg/16 hrs for 8 weeks, 10 mg/16 hrs for 3 weeks) vs. placebo patch Participants were women who smoked ≥10 cigarettes after the first trimester. | Smoking abstinence; mean birth weight; preterm birth

* Median

† Calculated

Abbreviations: BL = baseline; cpd = cigarettes per day; GED = general education development; hrs = hours; HS = high school; IUGR = intrauterine growth restriction; N = number of participants; NR = not reported; NRT = nicotine replacement therapy; mg = milligrams; min = minutes; RCT = randomized controlled trial; SES = socioeconomic status; UK = United Kingdom; US = United States; vs = versus; yrs = years.

Within the Coleman review (2012), four of the six RCTs were placebo controlled, as was the additional trial we identified in our primary bridge search.101 The most common intervention included the use of the NRT patch (four placebo-controlled trials101,184-186 and one nonplacebo controlled trial187). Only two trials used other NRT types—one used gum NRT and placebo gum NRT,188 and one offered a choice of gum, lozenge, or patch and was not placebo controlled.189 These trials commonly enrolled women during their second trimester, although one trial enrolled women any time before 27 weeks gestation.188 The largest study (n=1,050) was the Smoking, Nicotine, and Pregnancy trial (SNAP), which was a multisite RCT of NRT patches conducted in the U.K.184,190 (The lead author of the primary review for pharmacotherapy in our review of reviews [Coleman] was also the lead author of this trial.) The second largest, and the most recent NRT trial among pregnant women was a multisite trial conducted in France that randomized 402 women to nicotine patches or placebo nicotine patches.101

To evaluate health outcomes in pregnant women and neonates, the Coleman review considered RCT studies with control conditions of either no-NRT or placebo. Including the additional study identified in our search, the number of studies available for analyses of each health outcome was low (k ≤ 4), and did not support quantitative pooling. As a consequence, our review of health outcomes is qualitative. We present forest plots of this data for illustrative purposes only.

Four placebo-controlled trials reported on preterm birth (delivery at <37 weeks gestation).101,184, 185,188 All but the most recent study estimated effects in the direction of a reduced risk for preterm birth with NRT, including the smallest trial, which had a significant result (RR 0.41 [95% CI, 0.18 to 0.94]).188 This trial was a parallel design RCT allocating 194 currently pregnant smoking women to either 2 mg gum NRT or placebo NRT gum at or before 26 weeks of pregnancy. The remaining three trials had larger samples and estimated nonstatistically significant effects closer to null, ranging from RR 0.85 to 1.03 (Appendix F Figure 13). These same trials reported birth weight outcomes, with two finding significantly higher birth weights among women allocated to the NRT arm.185,188 The largest trials, conducted by Coleman184 and Berlin,101 however, did not find evidence of a birth weight benefit (Appendix F Figure 14).

Results for stillbirth were inconsistent and the samples and event rates were too small for valid inference. Two of four trials reported slightly more stillbirths in the NRT group, but these trials were underpowered for estimation of the risk of such a rare event (<1%).184,188 The most recent trial, conducted by Berlin, was also not statistically significant and close to null, but the effect was in the direction of a potential benefit.101

None of the included systematic reviews provided evidence on long-term effects of the use of NRT during pregnancy.184,190 The SNAP trial of NRT during pregnancy included in the Coleman review, however, did recently report two-year followup data.190 In this trial, just under one-third of participants in each arm completed the 2 year questionnaire. The family physicians of survey nonrespondents were also surveyed. Both study trial arms reported that 88 percent of participants or clinicians completed followup at 2 years, with similar rates of withdrawal and nonresponse between arms over the time period. Comparison group characteristics were similar in the original and followup cohort, including a slightly higher caesarean section rate in the NRT compared with placebo group. This study's authors reported composite variables based on an a priori statistical analysis plan. The main outcomes were survival with no impairment (i.e., developmental, neuromotor, sensory) and respiratory problems (i.e., respiratory symptoms, asthma diagnosis, admissions to hospital for respiratory problem). Among respondents with 2 year followup data in the NRT arm (n=445) and placebo arm (n=446), survival with no impairment was significantly higher among those allocated NRT (73% versus 65%; OR 1.41 [95% CI, 1.05 to 1.87]). There was no significant difference in rates of definite developmental impairment (11% NRT, 14% placebo; OR 0.71 [95% CI, 0.48 to 1.06]) between the groups. Multiple imputation intention-to-treat analysis results were nearly identical. For respiratory problems, a five percent observed difference between the arms (30% NRT versus 25% placebo) was not statistically significant (OR 1.30 [95% CI 0.97 to 1.74]).190

#### Behavioral Interventions Among Pregnant Women

We identified six reviews assessing behavioral interventions for smoking cessation during pregnancy.110,116,119,125,127,143 From these reviews, we chose to use the good-quality Chamberlain review (2013) as the primary review for this topic because it was the most recent and comprehensive.110 The other reviews of behavioral interventions included fewer studies and their searches were not as recent (Table 11; Appendix C Table 2).

The Chamberlain review included 86 RCTs and reported intervention effects on health outcomes or tobacco cessation in late pregnancy (Table 12). Healthy pregnant women >16 years old were the most common study population, and a majority of studies included women identified as having low socioeconomic status. Most of the included trials recruited women at their first prenatal visit, as long as it occurred before the 3^rd^ trimester. This recruitment strategy ensured these women had enough time to engage in the intervention. Interventions that began in the postpartum period were excluded from the review, but continuing cessation outcomes postpartum were reported in many of the included intervention studies.

Seventy-seven of the 86 trials contributed to the main meta-analysis. The most common intervention was behavioral counseling (k=48). Less common intervention types included feedback (k=7), health education (k=7), incentives (k=4), and social support (k=10) (Table 12). Thirty-three of the 77 intervention trials offered multiple interventions (e.g., NRT or self-help video given to both groups with additional intensive counseling given only to intervention group), whereas 31 offered a single intervention. An additional 12 trials used a tailored approach where different intervention components were offered based on an assessment of women's needs and preferences. Usual care was the comparison condition for the majority of trials (k=44), which was generally described as being provided information about the risk of smoking during pregnancy and advice to quit. Thirty-one of the remaining trials used a comparison defined as a ‘less intensive’ intervention, and two used compared the intervention to an ‘alternative’ intervention (e.g., cognitive behavioral counseling versus traditional health education). This behavioral intervention review excluded trials comparing efficacy of pharmacotherapy with equal levels of behavioral support.

Some of the intervention trials in the Chamberlain review reported one or more perinatal health outcome. Nineteen trials reported birth weight data. Other, less-commonly reported data included low birth weight (<2500 g) (k=14), preterm birth (<37 weeks gestation) (k=14), stillbirths (k=7), neonatal death (k=4), neonatal intensive care unit (NICU) admissions (k=4), and very low birth weight (VLBW) (<1500 g) (k=3). This review included a sufficient number of studies, with sufficiently low heterogeneity, to obtain results of meta-analysis for mean birth weight, low birth weight, preterm birth, and stillbirth (Table 14).

Table 14 Summary of Perinatal Health Outcome Results (KQ 1) of Behavioral Tobacco Cessation Interventions Among Pregnant Women Within Chamberlain Review110

Outcome | Intervention | Control | k | N | Abstinence measures^*^ | Followup^§^ | IG events | IG N | CG events | CG N | Risk Ratio^‡^or mean difference | 95% CI | I^2^
Mean birthweight | All behavioral interventions^‖^ | Usual care or control | 19 | 9,859 | 21% PPA 68% BV | Late pregnancy, including during hospitalization for delivery | NA | 4,948 | NA | 4,911 | 40.78 | 18.45, 63.10 | 0%
Mean birthweight | Counseling | Usual care or control | 12 | 5,392 | 17% PPA 67% BV | Late pregnancy, including during hospitalization for delivery | NA | 2,619 | NA | 2,773 | 39.93 | 9.12, 70.74 | 0%
Low birth weight (<2500 g) | All behavioral interventions^‖^ | Usual care or control | 14 | 8,562 | 14% PPA 79% BV | Late pregnancy, including during hospitalization for delivery | 304 | 4,298 | 381 | 4,264 | 0.82 | 0.71, 0.94 | 0%
Low birth weight (<2500 g) | Counseling | Usual care or control | 8 | 4,339 | 13% PPA 88% BV | Late pregnancy, including during hospitalization for delivery | 151 | 2,090 | 200 | 2,249 | 0.83 | 0.68, 1.01 | 0%
Preterm birth (< 37 weeks) | All behavioral interventions^‖^ | Usual care or control | 14 | 7,852 | 29% PPA 79% BV | Late pregnancy, including during hospitalization for delivery | 251 | 3,992 | 307 | 3,860 | 0.82 | 0.70, 0.96 | 0%
Preterm birth (< 37 weeks) | Counseling | Usual care or control | 8 | 3,447 | 25% PPA 89% BV | Late pregnancy, including during hospitalization for delivery | 99 | 1,672 | 117 | 1,775 | 0.93 | 0.71, 1.20 | 0%
Stillbirth | All behavioral interventions^‖^ | Usual care or control | 7 | 5,414 | 0% PPA 57% BV | Late pregnancy, including during hospitalization for delivery | 38 | 2,676 | 31 | 2,738 | 1.22 | 0.76, 1.95 | 0%
Stillbirth | Counseling | Usual care or control | 5 | 2,454 | 0% PPA 80% BV | Late pregnancy, including during hospitalization for delivery | 16 | 1,197 | 14 | 1,257 | 1.14 | 0.55, 2.33 | 0%

* Used point prevalence abstinence in late pregnancy for primary outcomes, and biochemically validated rates where available

† Weighted average quit rate

‡ Pooled risk ratios estimated using the Mantel-Haenszel random-effects model

§ Longest followup time point reported

‖ Behavioral interventions include counseling, health education, feedback, incentives, and social support

Abbreviations: BV = biochemically verified; CG = control group; CI = confidence interval; IG = intervention group; k = number of studies; N = number; NA = not applicable; PPA = point prevalence abstinence.

When all 19 studies that reported mean birth weight (including all types of behavioral interventions, with control conditions including usual care or control conditions) were combined, modestly higher mean birth weight favoring the intervention arm was evident (40.78 grams [95% CI, 18.45 to 63.10], I^2^=0%) (Appendix F Figure 15). The magnitude and significance of the effect was similar when limited to counseling interventions (39.93 grams [95% CI, 9.12 to 70.74], I^2^=0%). The magnitude of the mean difference between groups was modest, and there was some inconsistency in the direction of effects across studies. Evidence of beneficial health outcomes were observed in the pooled analyses across all interventions and comparators for preterm birth and low birth weight (k=14). Pooled effect estimates were similar for these outcomes, with an 18 percent risk reduction for preterm birth before 37 weeks (RR 0.82 [95% CI, 0.70 to 0.96], I^2^=0%) (Appendix F Figure 16) and a very similar statistically significant estimate for low birth weight (Appendix F Figure 17). When restricted to counseling interventions (k=8), while results suggested similar benefits, they were not statistically significant.

Among the seven trials reporting stillbirth, there were no significant differences between study groups and very low event rates and small estimated effect sizes limited precision of estimates. Overall, however, there were slightly more stillbirths recorded in the intervention group compared with the control group (Appendix F Figure 18). Three trials of counseling and one trial of a feedback intervention reported on neonatal death, but events were too rare to inform valid conclusions. Similarly, two trials of counseling and two trials of incentive interventions reported on NICU admissions, with half of the trials reporting approximately 25 percent more admissions in the control, compared with treatment arms, and two trials with nearly similar admission numbers between arms (treatment 14/189, placebo 12/189 and treatment 14/30, placebo 13/21 placebo). Two counseling intervention trials and one feedback trial reported on VLBW. While few cases were reported (< 2%), similar rates of VLBW were reported between arms showing slightly more events occurred in the treatment arm in one of the counseling intervention trials.

### Key Question 2 Do Tobacco Cessation Interventions Achieve Tobacco Abstinence in Pregnant Women?

#### Pharmacotherapy Interventions Among Pregnant Women

Meta-analysis of the five placebo-controlled efficacy trials (n = 1,922) showed a nonstatistically significant pooled effect of NRT on biochemically validated smoking cessation at followup (RR 1.24 [95% CI 0.95 to 1.64]), with low heterogeneity (I^2^ = 0%) (Table 15; Appendix F Figure 19). Four of the five studies in this meta-analysis were included in the Coleman (2012) review. We identified the remaining trial through our primary search. Quit rates in these trials ranged from 5 percent to 24 percent in the intervention groups and 0 percent to 15 percent in the control groups (weighted mean 10.8% versus 8.5%). Ignoring one small trial (n=30),186 the results of the trials were relatively consistent, with effect estimates ranging from 1.08 to 1.27 across placebo-controlled trials in 1,892 women. The review also reported very low rates of adherence to the intervention; particularly in the trials with well-described reporting on compliance, adherence rates less than 25 percent were observed. Including two additional, nonplacebo controlled trials increased the estimate of the pooled effect, but did not alter the statistical nonsignificance of the finding.

Table 15 Summary of Tobacco Abstinence Results (KQ 2) From Reviews of Tobacco Cessation Interventions Among Pregnant Women

Review, Year | Intervention | Control | k | N | Abstinence measures^*^ | Followup^‡^ | IG events | IG N | IG Quit Rate^†^ | CG events | CG N | CG Quit Rate^†^ | Risk Ratio^§^ | 95% CI | I^2^
Coleman, 2012^92^ | NRT, all forms║ | Placebo | 4 | 1,520 | 25% CA 100% BV | Late pregnancy, including during hospitalization for delivery | 93 | 762 | 12.2% | 71 | 758 | 9.4% | 1.27 | 0.95, 1.69 | 0%
Coleman, 2012^92^ + study identified in bridge search | NRT, all forms^¶^ | Placebo | 5^#^ | 1,922 | 40% CA 100% BV | Late pregnancy, including during hospitalization for delivery | 104 | 965 | 10.8% | 81 | 957 | 8.5% | 1.24 | 0.95, 1.64 | 0%
Chamberlain, 2013^110^ | Any behavioral interventions^**^ | Usual care or control | 70 | 21,948 | 0% CA 79% BV | Late pregnancy, including during hospitalization for delivery | 1,691 | 11,111 | 15.2% | 1,213 | 10,837 | 11.2% | 1.45 | 1.27, 1.64 | 60%
Chamberlain, 2013^110^ | Counseling | Usual care or control | 45 | 17,681 | 0% CA 82% BV | Late pregnancy, including during hospitalization for delivery | 1,283 | 8,830 | 14.5% | 992 | 8,851 | 11.2% | 1.37 | 1.17, 1.59 | 64%
Chamberlain, 2013^110^ | Social support | Usual care or control | 10 | 1,683 | 0% CA 70% BV | Late pregnancy, including during hospitalization for delivery | 168 | 845 | 19.9% | 128 | 838 | 15.3% | 1.29 | 0.97, 1.73 | 36%

* Used strictest available criteria to define abstinence (i.e., continuous, sustained, or prolonged abstinence was preferred over point prevalence abstinence and biochemically validated rates were used where available)

† Weighted average quit rate

‡ Longest followup time point reported

§ Pooled risk ratios estimated using the Mantel-Haenszel random-effects model

║ 3/4 trials used nicotine patches

¶ 4/5 trials used nicotine patches

# Includes 4 trials identified in the Coleman review and one additional trial included from our bridge search

** Behavioral interventions include counseling, health education, feedback, incentives, and social support

Abbreviations: BV = biochemically verified; CA = continuous abstinence; CG = control group; CI = confidence interval; IG = intervention group; k = number of studies; N = number; NRT = nicotine replacement therapy.

With regard to continuation of cessation after pregnancy related to NRT use during gestation, the followup study by Cooper and colleagues190 found conservatively estimated continuous smoking abstinence rates to be very low—3 percent among NRT users and 2 percent among placebo participants at 2 years, with no statistical difference between groups. Cessation was ascertained by clinician survey for over half of the trial participants at 2 years. Nonrespondents were assumed to be smokers and included in the denominator. While there were not significant differences between groups earlier in the post-partum period (6 months and 1 year), a significant effect was observed at one year (4% NRT versus 2% placebo) with further adjustment (site, baseline salivary cotinine, partner smoking status, and years completed education).

#### Behavioral Interventions Among Pregnant Women

The Chamberlain review (2013) identified 60 RCTs and 10 cluster-randomized trials that reported smoking cessation outcomes in late pregnancy, which could include up until hospitalization for delivery (n=21,948). This review included all intervention types, including counseling, health education, feedback, incentives, and social support. Pooled analyses of all behavioral interventions (k=70), regardless of type, including self-reported outcomes, indicated a significant effect of any behavioral intervention on cessation in late pregnancy (RR 1.45 [95% CI, 1.27 to 1.64]), with moderate-to-substantial heterogeneity of estimated effects (I^2^=60%) (Table 15; Appendix F Figure 20). While an overall Chi^2^ test for subgroup differences found no difference by the type of intervention (p=0.33), the number of studies varied considerably by intervention type. The results where similar when restricted to trials providing counseling interventions specifically (k=45) (RR 1.37 [95% CI 1.17 to 1.59]; I^2^=64%). There was no evidence of a statistically significant effect of social support interventions from analysis of 10 trials that were included in the review (RR 1.29 [95% CI 0.97 to 1.73]). Additionally, the results for some of the less common intervention types were suggestive—pooled effect estimates for financial incentives (k=4) and feedback (k=5) interventions were in a positive direction and included individual studies with statistically significant benefit. Overall test for interaction did not indicate statistical differences among subsets of studies compared according to the number of intervention components.

Biochemical validation of abstinence was conducted in 49 of the trials that reported smoking cessation. The review reported, however, that there was no significant between-group heterogeneity according to whether or not there was biochemical verification (Qb = (1) = 0.06, p=0.80). Nonetheless, observed effect sizes were generally smaller in pooled analyses limited to studies with biochemically validated outcomes.110 When comparing counseling with usual care and confirming cessation through biochemical validation (k=18), the relative risk for late-pregnancy cessation was 1.25 (95% CI, 1.03 to 1.50) and heterogeneity was lower (I^2^=35%).

### Key Question 3 What Adverse Events Are Associated With Tobacco Cessation Interventions?

#### Pharmacotherapy Interventions Among Pregnant Women

As reported in the review of KQ1, we found no evidence of perinatal harms for pharmacotherapy interventions among pregnant women. There were, however, too few studies for pooled analyses, and the available trials were underpowered for assessing rare harms with statistical confidence. As reported above, significant effects of NRT on health outcomes included positive effects identified in individual studies, including higher birth weight in two trials185,188 and reduced risk of preterm birth in one.188 The largest trial184 (n=1,050) reported a significantly higher rate of cesarean section in the NRT group (20% NRT versus 15% placebo; OR 1.45 [95% CI, 1.05 to 2.01]). The most recent trial, which we identified through our primary search, reported higher rates of cesarean section in the NRT group, but these rates were not statistically different (26% NRT versus 22% placebo; OR 1.21 [95% CI, 0.76 to 1.91]; n=402).101

Miscarriage rates were not statistically different (RR 1.24 [95% CI, 0.37 to 4.17], I^2^=0%) in the three studies included in pooled analyses in the primary review (n = 1,407). One trial did not adequately describe treatment allocation for seven miscarriages and, as such, was excluded from the analysis. A conservative analysis assuming all miscarriages occurred in the NRT group, however, did not result in a statistically significant difference.

Two large NRT patch trials101,184 reported detailed maternal and fetal adverse events. These trials reported that the most common adverse event was skin reaction at the patch site, with higher rates in the active NRT patches—nearly 9 percent of NRT users in the Coleman RCT discontinued treatment due to the reaction. The higher rate of Cesarean section in the NRT group was the only serious adverse event difference identified in the Coleman RCT, whose authors cautioned that the low event rates for all adverse events considered do not permit valid conclusions on the safety of NRT during pregnancy. The Berlin trial did not find a significant difference in any fetal outcomes and the Cesarean section rate did not differ by study arm, although there were slightly more cases in the NRT group. Despite having insufficient power to assess the statistical significance of the observed 4 percent difference in having one or more serious maternal adverse event (NRT 12%, placebo 8%), the Berlin trial reported a significant 0.02 mm Hg per day rise in diastolic blood pressure over time in the trial among NRT compared with placebo allocated participants (p=.01). This outcome was not previously reported in trials of NRT in pregnancy.

While stillbirth rates were not significantly different between groups, these events were very rare. In the three studies reporting this outcome,184,188,189 eight stillbirths occurred in the 733 NRT arm and three occurred in the 669 placebo or no-NRT arm. More events would be necessary for statistical certainty about this outcome and for neonatal death. Three trials reported neonatal death,184,188,189 where one death was observed in the NRT arms and five in the placebo arms of the three trials (n = 1,386).

#### Behavioral Interventions Among Pregnant Women

The Chamberlain review110 noted potential adverse effects of behavioral interventions, including the possibility of a paradoxical effect (i.e. increased smoking), which was observed in the intervention groups of four studies. The review posited that this could occur if exposure to anti-smoking messages motivates resistance to cessation in some participants. This review reported other possible adverse events, including nicotine withdrawal, stigma, and social costs related to peer or partner support, though no trials specifically reported these adverse events as a result of the intervention.

## Individuals With Mental Health Conditions: Results of Included Reviews

Of the 54 reviews identified as part of our review of reviews, four assessed pharmacological and behavioral interventions for smoking cessation among individuals with mental health conditions. Of these, two reviews focused on individuals with current or past depression117,149 and two reviews included people with schizophrenia or schizoaffective disorder (Table 1).99,146

The good-quality Van der Meer (2013) review provides the primary evidence for depression. This review had a last search date through April, 2013.^149^ The review included RCTs conducted among adult smokers with current or past depression that reported at least 6 month followup on cessation outcomes, the majority of which were biochemically validated. A broad definition of depression was employed and ranged from symptoms to diagnosed major depression (current or past). Studies were included regardless of whether depression was identified at study enrollment as a planned design element, or if the study was a subgroup of a trial identified post-hoc (Table 16). We also used a review by Gierish (2010) for identification of adverse events as a supplement.99

Table 16 Inclusion Criteria of Included Existing Systematic Reviews on the Efficacy and Adverse Events of Tobacco Cessation Interventions Among Adults With Mental Health Disorders, by Alphabetical Order

Review, Year Quality | Intervention | Comparison | Last Search Date | Number of Included Studies | Funding Source | Study Design^†^ | Population | Outcomes | Followup | Setting
Banham, 2010^99^ | Behavioral or pharm intervention designed to address smoking behavior and nicotine dependence, whether the aim was smoking cessation or reduction | Other interventions, placebo, or usual care | Jan-08 | 8 | NR | RCTs | Adults with any form of severe and enduring mental ill health (severe mental illness was defined as any nonorganic disorder with psychotic features that results in a substantial disability, including schizophrenia, schizoaffective disorder, bipolar disorder or delusional disorder) | Smoking status; smoking reduction | NR | Inpatient or outpatient settings
Gierisch, 2010^117^ Good | Antidepressants, NRT, brief smoking cessation counseling, behavioral counseling, or behavioral mood management treatment | Usual care or placebo | Mar-10 | 16 | Department of Veterans Affairs, Veterans Health Administration, Office of Research and Development | RCTs | Adult smokers with diagnosed depression | Smoking abstinence; AEs | ≥3 months | Outpatient (e.g., mental health clinics, primary care) or delivered through remote communication technologies (e.g., telephone, Web)
*Tsoi, 2013^146^ Good | Pharm or behavioral | Another intervention, placebo or usual care | Oct-12 | 34 | NHS National Institute for Health Research | RCTs or quasi- | Adult smokers with schizophrenia or schizoaffective disorder | Smoking abstinence; changes in mental state | ≥6 months | Inpatient units, the community, or outpatient psychiatric treatment sites
*van der Meer, 2013^149^ Good | Pharm or psychosocial intervention, or combination | Usual care or placebo | April-13 | 49 | NR | RCTs | Adult smokers with current or past depression | Smoking abstinence | ≥6 months | Any

* Review served as basis for main finding

† Quasi-RCTS are those that use quasi-random methods of assignment including alternation, date of birth, or medical record number.

Abbreviations: AE = adverse event; NHS = National Health Service; NR = not reported; pharm = pharmacotherapy; RCT = randomized controlled trial.

The good-quality review Tsoi review (2013) was the basis of our findings for people with schizophrenia.146 This review searched for evidence through October, 2012. The review included trials of smoking cessation interventions with at least 6 month followup that were conducted among adult smokers with a current diagnosis of schizophrenia or schizoaffective disorder regardless of their intention to stop smoking. This review did not include trials of individuals with substance misuse disorders. Trials including people with other psychiatric diagnoses where not included in this review unless data for those with schizophrenia or schizoaffective disorder could be isolated. The Banham (2010) review was also examined to identify health outcomes and adverse events.81

### Key Question 1 Do Tobacco Cessation Interventions Improve Mortality, Morbidity, and Other Health Outcomes in Smokers With Mental Health Conditions?

#### Individuals With Depression

The Van der Meer (2013) and Gierisch (2010) reviews did not identify any trials reporting health outcomes related to smoking cessation interventions among smokers with current or past depression.117,149

#### Individuals With Schizophrenia or Schizoaffective Disorder

The Tsoi (2013) review included trials of bupropion SR versus placebo that reported mental-state outcomes, including positive and negative symptoms at the end of treatment, as well as depressive symptoms at the end of treatment. This review reported that there was no evidence that smoking cessation treatment with bupropion SR worsened mental health among study participants, but these findings are not robust since the reporting of outcomes varied among trials. Two trials reported change in positive symptoms, for example, while three trials reported changes in negative symptoms and an additional three trials reported change in depressive symptoms. There was no effect for any of these outcomes within individual studies or in an pooled analysis that included the few studies that reported these outcomes. Similarly, while there was little evidence available for trials of varenicline, no trials reported declines or improvements in mental state outcomes.146 Likewise, the Tsoi review reported no health outcomes related to behavioral interventions for smoking cessation among patients with schizophrenia or schizoaffective disorder, although it appears that there were measures of mental health status included in most of the trials. The Banham (2010) review reported that there was no change in mental health outcomes (measured using validated tools) in one trial that compared participants assigned to a group American Lung Association intervention compared with participants assigned to a specialized group therapy intervention for smoking cessation among people with schizophrenia or schizoaffective disorder.81

### Key Question 2 Do Tobacco Cessation Interventions Achieve Tobacco Abstinence in Smokers With Mental Health Conditions?

#### Individuals With Depression

Among smokers with current depression, the Van der Meer review (2013) identified eight trials that tested the efficacy of antidepressants compared with placebo for smoking cessation, all using biochemical validation. Five of these trials tested bupropion SR in smokers with mild depression, two tested fluoxetine, and one tested paroxetine (the latter three studies are not discussed here because our review is limited to trials of drugs explicitly approved by the FDA for smoking cessation) (Table 17).149 Four of the five trials of bupropion SR tested the antidepressant alone compared with placebo, and one trial tested bupropion SR versus placebo with NRT as an adjunct in both arms among smokers with current depression. None of the trials had sufficient power to statistically distinguish observed differences however. The largest trial (n=161) reported fewer people with 6 months abstinence in the intervention group compared with placebo. The remaining four trials (each with n<100) reported higher rates of cessation in the intervention group. Among smokers with past depression, four trials (with five comparisons) tested bupropion SR versus placebo (one comparison tested bupropion SR + NRT versus placebo + NRT). The trial that compared NRT as an adjunct in bupropion SR and placebo comparison groups had a statistically significant effect (RR 5.46 [95% CI 1.71 to 17.40], n=87). While the other four trials were not statistically significant, all except one trial reported higher rates of abstinence in the intervention arm. Given the limited trial evidence available, effects of other pharmacotherapies for smokers with current or past depression were unclear. Five trials compared rates of 6-month abstinence from NRT versus placebo among currently depressed (k=1) and previously depressed (k=4) smokers. While all comparisons were generally positive, none had sufficient power to allow for statistical inference.149

Table 17 Descriptive Characteristics of Included Studies Within the Main Reviews on the Efficacy and Safety of Tobacco Cessation Interventions Among Adults With Mental Health Disorders

Review, Year | Number of Included Studies | Sample Size (Range) | Demographic Characteristics | Baseline Smoking Status | Readiness to Quit/ Quit History | Intervention Characteristics | Treatment Setting/Provider Characteristics
van der Meer, 2013^149^ | 49 | 14 to 5,046 | Average age (range): 24 to 57 Sex (% female): 7.8 to 100 Race: NR SES: NR Comorbidities/other substance abuse: Patients with substance abuse disorders were generally excluded from the studies in this review, with the exception of 1 study conducted at substance abuse treatment sites | Smoking status: 7.9 to 32.3 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: NR consistently Quit history: NR consistently | 49 RCTs included; - Investigating smoking cessation interventions with specific mood management components for handling depression (k=33); - Investigating antidepressants vs placebo (k=16) | Setting: Trials conducted in community, university, and clinical settings including hospitals Providers: NR
Tsoi, 2013^146^ | 34 | 9 to 298 | Average age (range): 34 to 49 Sex (% female): NR; “predominantly male” Race: NR consistently SES: NR Comorbidities/other substance use: Although the review did not exclude patients with schizophrenia or schizoaffective disorder who had other substance misuse disorder or additional psychiatric disorders, a significant number of the included studies explicitly excluded participants with any active substance misuse other than nicotine. | Smoking status: 7 to 41 (average cpd range) Nicotine dependence: NR consistently | Readiness to quit: 16 RCTs stated that participants had expressed interest in quitting or reducing smoking Quit history: NR consistently | 34 RCTs included; - Interventions focused on smoking cessation, reduction, or relapse prevention (k=26); - Had a primary aim other than the one above (k=8); There was a range of interventions. Of the studies comparing pharmacotherapy with placebo, the most common interventions were bupropion SR (k=8), nicotine patch (k=3) and varenicline (k=2). 2 RCTs compared the combination of bupropion SR and patch, with patch and placebo; 2 RCTs compared the efficacy of different dosages of patch for smoking cessation. Some of the drug therapy studies provided psychosocial interventions to all participants. These psychosocial interventions included group cognitive behavioral therapy k=4), group therapy for motivational enhancement, psychoeducation and relapse prevention (k=1); group behavioral therapy (k=2); smoking cessation educational classes along with discussions with health educators (k=1); group psychoeducation (k=1); group therapy using the ACS Fresh Start Program (k=1) and individual smoking cessation counseling (k=2). The duration of drug treatment varied from 7 hours to 6 months. 5 RCTs predominantly examined the effect of behavioral interventions ranging from a single session of motivational interviewing to specialized group therapy of various designs. 1 RCT used repetitive transcranial magnetic stimulation to investigate whether this was effective for smoking cessation. 3 RCTs investigated the combined effect of pharmacological and psychosocial interventions. | Setting: “Most trials recruited participants from the community.” Providers: NR

Abbreviations: ACS = American Cancer Society; cpd = cigarettes per day; k = number of studies; NR = not reported; RCT = randomized controlled trial; SES = socioeconomic status; SR = sustained release; vs = versus.

In terms of behavioral interventions, Van der Meer (2013) identified 49 RCTs that reported cessation outcomes; 33 of them included a mood management component, primarily cognitive behavioral therapy (group or individual), specifically for depression.149 Among smokers with current depression, adding a mood management component to the standard intervention was beneficial for quitting smoking at 6 months in a pooled analysis of 11 trials (RR 1.47 [95% CI 1.13 to 1.92]; I^2^= 0%, n=1,844). Sensitivity analyses in trials of individuals with current depression did not identify factors suggesting group differences based either on trial design or type of support. This conclusion, however was based on a limited number of studies available for comparing subgroup effects across trials. The evidence for a benefit of similar magnitude was also present in smokers with past depression (RR 1.41 [95% CI 1.13 to 1.77]; I^2^=23% k = 13, n = 1,496). Studies of other types of behavioral interventions (not including a mood management component) were too heterogeneous to combine in the main analysis and subgroup meta-analysis of these other types of behavioral interventions among smokers with past or current depression was not possible, given limited trial evidence.

#### Individuals With Schizophrenia or Schizoaffective Disorder

The Tsoi (2013) review included five trials of bupropion SR reporting 6-month followup data on smoking cessation.146 All trials reported more quit events in the intervention arm, and a significant pooled estimate of effect was reported (RR 2.78 [95% CI 1.02 to 7.58], I^2^=0%), but precision is limited because the number of events (18) and overall number of trial participants were very low (n=214).

Of the two trials comparing varenicline with placebo, only one reported 6 month abstinence (n=128). This trial had unclear risk of bias across most quality criteria and was sponsored by the drug company that produces varenicline. Additionally, this trial's results were not statistically significant, despite a five-fold difference in cessation rates.

There were no studies designed to assess the independent effect of NRT with placebo or non-NRT control. Two studies evaluated NRT of differing doses and other studies combined NRT with other interventions. One trial (n=169) combined a counseling intervention with nicotine patches in comparison to usual care, but cessation results were not statistically significantly different at 6-month followup. Another trial compared the effect of contingent reinforcement using financial incentives (with and without the nicotine patch) to a minimal intervention. There were 80 patients in this trial available for subgroup analysis of those with schizophrenia or schizoaffective disorder, and only one-third wished to stop smoking. At followup, beyond 6-months, abstinence was higher in the group receiving the nicotine patch alongside monetary incentives (50%) compared with the incentives without NRT (28%) and the minimal intervention (10%). Biochemically validated abstinence, however, did not differ between arms at followup.

The Tsoi review identified three additional trials that tested behavioral interventions.146 One compared an American Lung Association program with specialized cessation group therapy for schizophrenia patients (both arms received the nicotine patch). The specialized group-therapy arm had higher reported rates of smoking cessation at 6-months (17.6% versus 10.7%, p<0.03). A second trial of behavioral interventions compared two different behavioral counseling approaches that provided nicotine patches to both study arms and found no significant difference in cessation at 6- or 12-months. A third trial compared active repetitive transcranial magnetic stimulation (a noninvasive procedure that can induce changes in brain cortical function with the potential to reduce tobacco craving) with sham repetitive transcranial magnetic stimulation. This trial, however, reported no difference in cessation outcomes at 10 weeks. They did not report outcomes at longer followup time points.

### Key Question 3 What Adverse Events Are Associated With Tobacco Cessation Interventions?

#### Individuals With Depression

The Van der Meer review (2013) did not report on adverse events for the included trials.149 The remaining systematic review conducted among patients with depression was a less recent, fair-quality review, but provided data on adverse events.117 Eleven of the 16 included trials in the Giersch review did not report data on adverse events, and only three of the 16 trials provided detailed information on adverse events. The adverse events reported for a trial of bupropion SR that was included in the Van der Meer review included headache, insomnia, dry mouth, and increased anxiety and for a trial of NRT also included in the Van der Meer review, a small proportion of participants reported heart palpitations, nausea, vomiting, dizziness, difficulty breathing, tongue blisters, damage to dental work, and sore jaw. Overall, these reviews did not identify any severe, life-threatening adverse events attributed to pharmacological smoking cessation interventions among people with depression, although data are quite incomplete. There were no adverse events related to behavioral interventions among individuals with depression reported in any of the included reviews.

#### Individuals With Schizophrenia or Schizoaffective Disorder

The reported adverse events in bupropion SR trials conducted among individuals with schizophrenia were generally not serious. These events included dry mouth, feeling jittery, light-headedness, and frequent night waking.191 While one patient in the bupropion SR arm of a trial had a seizure, the individual had a preexisting condition determined to precipitate the seizure. No seizures were reported in the other trials.146 Three of 59 participants in one trial experienced a psychotic break during the trial: one was in the bupropion SR arm and two were in the placebo arm. The trial of varenicline that reported 6-month outcomes had 13 serious adverse events (among 10 trial participants). Nine of these events occurred in the intervention group and one occurred in the placebo group (accidental death during post-treatment followup). The authors attributed two serious suicide-attempt hospitalizations to varenicline use. No adverse events from behavioral interventions were reported for those with schizophrenia or schizoaffective disorder.99,146