# Methods

## Scope of Review

We relied primarily on a review of reviews method for this update. This was the most appropriate approach considering the large number of behavioral and pharmacologic tobacco cessation interventions and the availability of multiple existing systematic reviews on this subject for both adults and pregnant women. In general, a review of reviews focuses on a broad condition or problem for which there are two or more potential interventions. This approach highlights existing systematic reviews that address these potential interventions and their results.79-81 To conduct this review of reviews we: 1) searched for reviews; 2) selected reviews; 3) assessed the quality of reviews; 4) determined the use of reviews; 5) abstracted review details and findings; and 6) synthesized findings across reviews.81 A typical Analytic Framework, Key Questions (KQs), and inclusion/exclusion criteria are outlined as they relate to the objectives of the review of reviews. We did not search for, or screen, original research (with the exceptions noted below), replicate quality rating or data abstraction of original studies, or replicate review-specific analyses (including meta-analyses). We decided a priori to conduct a de novo search for primary evidence related to the effectiveness and safety of ENDS. In addition, before initiating our review, we established that we would consider a search for primary research for specific interventions and/or questions if no recent fair- or good-quality reviews were identified for the topic.

## Key Questions and Analytic Framework

With input from the USPSTF, we developed an Analytic Framework (Figure 2) and three KQs using the USPSTF's methods to guide the literature search, data abstraction, and data synthesis for this topic.82 The proposed Analytic Framework and KQs were posted on the USPSTF's website for public comment for 4 weeks. We revised the Analytic Framework and KQs based on public comment. The USPSTF provided final approved. We examined the following KQs:

1. Do tobacco cessation interventions improve mortality, morbidity, and other health outcomes in current adult tobacco users, including pregnant women and individuals with mental health conditions?
2. Do tobacco cessation interventions achieve tobacco abstinence in current adult tobacco users, including pregnant women and individuals with mental health conditions?
3. What adverse events are associated with tobacco cessation interventions?

Figure 2 Analytic Framework: Behavioral Counseling and Pharmacotherapy Interventions for Tobacco Cessation Among Adults and Pregnant Women

Figure 2 is an analytic framework that depicts three key questions described in the Methods section. In general, it illustrates the overarching question of whether tobacco cessation interventions improve mortality, morbidity, and other health outcomes in current adult tobacco users, including pregnant women and individuals with mental health conditions. The analytic framework also illustrates the intermediate step and key questions of whether tobacco cessation interventions achieve tobacco abstinence in current adult tobacco users, including pregnant women and individuals with mental health conditions, and what adverse events are associated with tobacco cessation interventions.

## Data Sources and Searches

We searched the following databases for relevant reviews through August 1, 2014: PubMed, PsycInfo, the Database of Abstracts of Reviews of Effects, the Cochrane Database of Systematic Reviews (CDSR), and the Centre for Reviews and Dissemination Health Technology Assessment (Appendix B). In addition to these database searches, we searched the websites of the following organizations: the Agency of Healthcare Research and Quality (AHRQ), British Medical Journal Clinical Evidence (through August 7, 2013), the Canadian Agency for Drugs and Technologies in Health, CDC's Guide to Community Preventive Services, the Institute of Medicine, the National Institute for Health and Clinical Excellence, the NHS Health Technology Assessment Programme, and the Surgeon General. We restricted our searches to articles in the English-language published since January 2009. We also examined the reference lists of all of our included reviews to identify other studies for inclusion. We supplemented our searches with suggestions from experts and reviews identified through news and table-of-contents alerts from sources such as ScienceDirect (Elsevier, Maryland Heights, MO) and Tobacco Control. We also searched for potentially relevant in-process or planned reviews as indicated by review protocols through AHRQ, CDSR, the Centre for Reviews and Dissemination PROSPERO register, and the journal Systematic Reviews.

In addition to the search for reviews, we conducted two separate searches for primary evidence. The first search focused on studies addressing ENDS. We conducted searches in the following databases: CDSR, Cochrane Central Register of Controlled Trials (CENTRAL), PubMed, and Scopus from January, 2008 through May 13, 2014 (Appendix B). Given the rapidly emerging research on ENDS, we also subscribed to and received weekly email alerts from PubMed on newly published articles related to ENDS through March 1, 2015. Finally, we reviewed the reference lists of nine related systematic or narrative reviews to identify studies for potential inclusion.83-91

The second search was for primary evidence related to pharmacotherapy tobacco cessation interventions among pregnant women. While we identified five relevant reviews on this subject (described in our Results section), the small number of included studies in each existing review and the imprecision of the effect estimate warranted an updated search and synthesis of more recent evidence. As such, we conducted searches for primary evidence on pharmacotherapy among pregnant women in Medline, CENTRAL, PubMed, PsycInfo from January, 2012 through August 15, 2014 (Appendix B). Finally, we searched ClinicalTrials.gov for ongoing pharmacotherapy tobacco cessation trials among pregnant women that were listed as “recruiting,” “active, not recruiting,” “not yet recruiting,” “completed,” or “terminated” to identify any studies underway that might be of relevance for ongoing evaluation.

We imported the literature from these searches directly into version 12 of Reference Manager® (Thomson Reuters, New York, NY), a bibliographic management database.

## Study Selection

We developed criteria for inclusion and exclusion of existing systematic reviews based on our understanding of the literature and the existing PHS Guideline (Appendix B Table 1). Generally, we included studies if they were systematic reviews, with or without meta-analysis, that: (1) examined the effectiveness of tobacco cessation interventions for adults or pregnant women and were linked to primary care or took place in a general adult population; and (2) were published in English, from January 2009 to present. We excluded nonsystematic narrative and discussion reviews. We also excluded reviews that focused on tobacco harm-reduction or relapse prevention interventions or nonfirst-line FDA approved cessation medications. We excluded reviews that only or primarily evaluated interventions among children and adolescents and broader public health strategies. We only included the most recent version of updated reviews. We kept detailed records of all included and excluded reviews, including the reason for their exclusion.

We outlined separate inclusion and exclusion criteria when considering primary evidence related to pharmacotherapy interventions among pregnant women and for ENDS. For pharmacotherapy interventions among pregnant women, we used the criteria outlined by Coleman and colleagues.92 Accordingly, we included randomized controlled trials (RCTs) with designs that permitted assessment of the independent effects of any type of NRT or any other first-line pharmacotherapy on smoking cessation. Included trials also had to provide very similar (or identical) levels of behavioral support to participants in the treatment and control groups. We excluded quasi-randomized, cross-over, within-participant, and observational designs. We required that studies take place in developed countries as defined as “very high” on the 2013 human development index of the United Nations (http://hdr.undp.org/en/statistics), which is consistent with the broader review literature.

For primary evidence related to the efficacy (KQ1-KQ2) and safety (KQ3) of ENDS, we included RCTs in which smokers were randomized to ENDS or a control condition, such as a placebo device or a no-intervention condition. We excluded all observational designs. We only included studies if they reported a health outcome (KQ1) or a measure of smoking abstinence (KQ2) at least 6 months after baseline assessment or adverse events (KQ3) at any point after treatment started. We excluded studies that only reported intermediate smoking outcomes (e.g., desire to smoke, withdrawal symptoms, or quantity of conventional cigarettes smoked). Again, we required that studies take place in developed countries consistent with the broader review literature.

Two reviewers independently screened all records identified in the searches on the basis of their titles and abstracts, using the inclusion/exclusion criteria as a guide. Subsequently, two reviewers assessed the full text of potentially relevant systematic reviews and primary studies using a standard form outlining the eligibility criteria. We resolved disagreements through discussion.

## Quality Assessment and Data Abstraction

We used a slightly modified version of the AMSTAR (Assessment of Multiple Systematic Reviews) tool to quality rate included systematic reviews for this review of reviews.93,94 The original AMSTAR tool contains 11 evaluation criteria, such as whether study selection and data abstraction are conducted by at least two reviewers, whether publication bias was assessed, and whether conflicts of interest were reported. To adapt the AMSTAR tool to fit USPSTF procedures, we deleted one item that assessed whether the status of the publication was used as an inclusion criterion because of low inter-rater agreement and difficulty with scoring.94 We also split two of the items into separate questions to more accurately account for the extent of duplicate study selection and duplicate data extraction, and the sources of potential conflicts of interest (i.e., both the systematic review and included studies) (Appendix B Table 2).

For primary evidence, we used standard criteria developed by the USPSTF to assess the quality of included evidence.82 We examined potential risks of bias, including randomization and measurement procedures (including blinding and consistency between groups); comparability of the groups at baseline; overall and group-specific attrition; intervention fidelity and participant adherence; and the appropriateness of the statistical procedures, including methods for handling missing data.

We applied the typical USPSTF quality scores (i.e., good-quality, fair-quality, or poor-quality) for both reviews and primary evidence after reviewing the number and seriousness of the threats to validity. Reviews assigned a good-quality rating affirmatively addressed all or most AMSTAR evaluation criteria whereas those rated as fair-quality did not meet a number of standards that may have affected the review's comprehensiveness, reproducibility, and conclusions (e.g., no dual study selection, did not account for individual study-level quality assessment in formulating conclusions, did not disclose potential conflicts of interest of included studies or review authors). Those rated as poor-quality contained a serious flaw or flaws that likely biased or invalidated the results. We excluded all poor-quality systematic reviews and primary trials. At least two independent reviewers assessed the quality of the included systematic reviews and primary evidence. We resolved discrepancies through discussion.

We abstracted descriptive data about each review into detailed abstraction tables. One reviewer completed primary data abstraction and a secondary reviewer checked all data for accuracy and completeness. Data collection included general characteristics of the review (e.g., author, year assessed up-to-date); clinical characteristics of included studies (e.g., age and clinical characteristics of population, type of intervention, outcomes reported); methodological features (e.g., design of primary studies included in review, search strategy, language and publication restrictions, methods for quality assessment of primary studies); and results (e.g., number of primary studies included, review findings). We abstracted and described data from primary studies directly in the report narrative.

## Data Synthesis and Analysis

Given the number of fair- and good-quality reviews that met our eligibility criteria, we developed a method to identify one or more reviews within each population and intervention subgroup that represented the most current and applicable evidence to serve as the basis for the main findings (called “primary” reviews, hereafter). First, we categorized all included reviews according to the overall discrete population of interest (i.e., adults, pregnant women, or patients with mental health conditions) and type of tobacco cessation intervention (i.e., pharmacotherapy, behavioral, and/or combination). Within each group, we listed the reviews in chronological order by the last search date with the most recent search listed first (some reviews were listed more than once in the table if they addressed multiple populations or intervention types). Next, we compared the included studies within each review to evaluate the comprehensiveness of each review and noted concordance and discordance in the included primary literature (Appendix C). When we encountered highly discordant bodies of evidence, we sought explanation for the difference by examining the inclusion and exclusion criteria for each review. For example, if the most recent review for a given category did not appear to be the most comprehensive review in terms of the number of included studies, we examined to what extent the inclusion criteria (e.g., allowable study designs, outcomes of interest) may have influenced the discrepancy in included studies. We also looked at individual included studies as necessary to ensure that the potential primary reviews did not omit important studies. Finally, we reviewed the inclusion and exclusion criteria and data analysis procedures of each review to determine the most applicable evidence. Box 1 describes the full set of criteria we applied to identify the primary review for each population and intervention. We reviewed the remaining reviews (“secondary” reviews) for complementary or discordant findings. These reviews are referenced throughout our report. In general, the results across reviews within each population and intervention grouping were consistent with one another and thus, we do not elaborate on these consistencies within the results.

Box 1 Criteria for Choosing the Primary Existing Systematic Reviews

1. The search is more up-to-date than other reviews for the same population/intervention group.
2. The included studies apply inclusion/exclusion criteria that offer the most relevant and credible evidence (i.e., based on included study designs, populations, setting, followup > 6 months, and outcomes).
3. There are relatively more (or equal) included studies of the ideal study design compared with other reviews for the same population/intervention.
4. Appropriately conducted pooled results are presented, with or without meta-regression or subgroup analysis.
5. The quality of the review is more favorable than other reviews for the same population/intervention.

We descriptively summarized the characteristics of the primary evidence reviews into evidence tables. We did not reanalyze any of the individual study evidence. We used the pooled analyses and existing point estimates presented in the included reviews as appropriate. For reviews that included meta-analyses, we conducted comparisons of the pooled estimates of efficacy for each intervention versus comparator and took the definition of abstinence (continuous, point prevalence) and the length of followup into consideration. When extracting pooled estimates from the reviews, we considered the statistical validity of the meta-analytic results available. Following current developments in methods for pooling data in general, we do not report pooled estimates for fewer than five studies because necessary adjustments for observed or unobserved heterogeneity is inestimable or likely to be biased.95,96 Pooling 10 or fewer studies warrants some caution in interpretation, as there are documented biases in the DerSimonian-Laird (DL) estimates most commonly used to account for random error. In this range, we interpreted pooled estimates while considering the proximity of the confidence interval to the null value (when available) and recognizing that a DL estimated confidence interval could underestimate variance. For all pooled estimates, we reported the I^2^ to evaluate statistical heterogeneity based on Cochrane Collaboration thresholds, with ranges from 30 percent to 60 percent possibly representing moderate heterogeneity, from 50 percent to 90 percent possibly representing substantial heterogeneity, and above 75 percent representing considerable heterogeneity.97 In cases of considerable statistical or qualitative heterogeneity of effect estimates, we presented forest plots to summarize and describe the data or narratively described the results, but caution readers in drawing conclusions from pooled estimates based on few trials. We also presented subgroup results related to the intensity or type of intervention, when available, and when the review identified other factors that influenced the effectiveness of interventions. Overall, we evaluated the appropriateness of meta-analytic procedures and used our technical judgment to interpret pooled analyses accounting for limitations or concerns from heterogeneity, statistical approaches, or other factors. We obtained permission to republish review forest plots or in the absence of review-generated forest plots, created our own based on the data presented in the review. We provided narrative results for reviews that did not include meta-analyses.

The primary outcome for KQ2 was smoking cessation at 6 months or longer followup using the strictest definition of abstinence available in each review. We abstracted results at both 6- and 12-months followup if the reviews presented both. In most cases, the reviews reported the “longest followup” result and required at least 6 months followup. The preferred outcome in most reviews was continuous abstinence (i.e., completely abstinent from quit date to followup allowing for up to five cigarettes) or prolonged abstinence (i.e., typically allows a ‘grace period’ following the quit date to allow for lapses) over point prevalence abstinence (i.e., abstinent at a particular point in time such as 7 days or 30 days before followup and thus includes a mix of recent and continuous quitters).98 Biochemical verification of self-reported abstinence was not required in most reviews, but validated outcomes were used where reported. Within the reviews, the 7-day point prevalence abstinence was typically preferred when more than one point prevalence abstinence rate was reported; 30-day abstinence was classified as point prevalence abstinence rather than continuous abstinence. All included reviews used analyses based on intention-to-treat principles in which participants lost to followup who could not be classified definitively as nonsmokers were counted as smokers, when reported.98

## Expert Review and Public Comment

A draft of the Analytic Framework, KQs, and inclusion/exclusion criteria was posted on the USPSTF's website for public comment from November 7 to December 4, 2013. We received comments from eight public commenters and partner organizations. These comments led to no changes to the research plan that changed the scope of the review or our approach to synthesizing the evidence. Minor clarifying text, however, was added based on public comments. A final research plan was posted on the USPSTF's website on February 6, 2014. The full draft report was reviewed by experts and Federal partners from September 26 through October 17, 2014. We compiled and addressed (where appropriate) the comments received from invited reviewers. Additionally, a draft of the full report was posted on the USPSTF's Web site from May 5 through June 1, 2015. A few comments were received during this public comment period; there were no changes made to the report based on these comments.

## USPSTF Involvement

We worked with three USPSTF liaisons at key points throughout this review, particularly when determining the scope and methods for this review and developing the Analytic Framework and KQs. The USPSTF liaisons approved the final Analytic Framework, KQs, and inclusion and exclusion criteria after revisions reflecting the public comment period. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.