# Introduction

## Scope and Purpose

In 2009, the U.S. Preventive Services Task Force (USPSTF) reaffirmed their 2003 recommendation that clinicians ask all adults about tobacco use and provide tobacco cessation interventions for those who use tobacco products (Grade A recommendation).1 The original USPSTF recommendation (2003) and reaffirmation (2009) were based on the 2000 and 2008 updates of the Public Health Service (PHS) Clinical Practice Guideline “Treating Tobacco Use and Dependence”.2,3 Because there are no plans to update the PHS report, we undertook the current review to provide an updated synthesis of the evidence to assist the USPSTF in updating their 2009 recommendation. This review of reviews systematically evaluates the evidence for the benefits and harms of pharmacological and behavioral tobacco cessation interventions in adults, including pregnant women and those with mental illness. Given the increase in awareness, positive perceptions, and use of electronic nicotine delivery systems (ENDS), our review also synthesizes the primary trial evidence on the efficacy and safety related to this technology as a means for quitting conventional smoking.

## Condition Definition

Tobacco is consumed in many forms including with cigarettes, pipes, cigars, cigarillos, little cigars, bidis (tobacco wrapped in tendu or temburni leaves), kreteks (clove cigarettes), smokeless tobacco (including chew, snuff including snus, and dissolvable tobacco in the form of strips, sticks, or lozenges), and smoking tobacco through a hookah or waterpipe. ENDS are devices that do not burn or use tobacco leaves. Instead, these devices deliver nicotine-containing aerosol that the user inhales by heating a solution that contains nicotine.4 While there are ENDS that do not mimic cigarettes – such as electronic hookahs, electronic pipes, and electronic cigars – electronic cigarettes (e-cigarettes) are the most prevalent type of ENDS. We use the term ENDS when referring to the broader technology and the term e-cigarette when referencing and describing this technology specifically. A further description of ENDS, including the regulatory environment surrounding these products, is provided below.

Tobacco dependence is considered a chronic disease that requires specific treatment.5,6 Tobacco-use disorder is defined as tobacco used to the detriment of a person's health or social functioning that includes the excessive use of tobacco products, including tobacco or nicotine dependence.7 When an addicted user tries to quit, he or she typically experiences withdrawal symptoms that include irritability, attention difficulties, sleep disturbances, depression, increased appetite, and powerful cravings for tobacco. These symptoms may begin a few hours after the last cigarette and can quickly drive people back to tobacco use.8 A number of behavioral factors (e.g., feel, smell, sight, social associations) can make withdrawal symptoms more acute.9

In this report, the term “tobacco use” indicates use of any tobacco product (not nicotine-delivery) and the term “smoking” refers to cigarette smoking alone.

## Burden and Prevalence of Tobacco Use

Tobacco use is the leading preventable cause of disease, disability, and death in the United States. According to the 2014 Surgeon General's Report, cigarette smoking and exposure to tobacco smoke results in more than 480,000 premature deaths annually in the United States.10 Tobacco use is associated with various forms of cancer, cardiovascular disease, respiratory disease, and reproductive disorders. Fifty years after the 1964 Surgeon General's report was published, research continues to identify diseases caused by cigarette smoking, including diabetes mellitus, rheumatoid arthritis, colorectal cancer, erectile dysfunction, tuberculosis, and congenital defects.10 In addition to causing multiple diseases, cigarette smoking can cause inflammation and impair immune function.10 Smoking during pregnancy is known to be causally related to higher risks of miscarriage, stillbirth, preterm birth, fetal growth restriction, placental abruption, certain congenital anomalies, and impaired lung function in childhood and beyond.8,10-12 The role of nicotine as an important mediating agent in the relationship between tobacco smoking and poor pregnancy and perinatal health outcomes is increasingly evident, given observed associations even for smokeless tobacco use with stillbirth and preterm birth.8,10,12

In 2013, an estimated 17.8 percent (42.1 million) of U.S. adults were current cigarette smokers.13 Over 76 percent (32.4 million) of these individuals smoked every day and 23.1 percent (9.7 million) smoked some days.13 From 2005 to 2013, overall smoking prevalence declined from 20.9 to 17.8 percent.13

Significant disparities in cigarette smoking exist by age, sex, race/ethnicity, education, income level, and mental health status.13 Adults aged 25 to 44 years have the highest rate of current cigarette smoking (20.1%), compared with adults aged 65 years or older (8.8%). Smoking prevalence is also significantly higher among men (20.5%) than women (15.3%). By race and ethnicity, smoking prevalence is highest among those reporting multiple races (26.8%), followed by American Indians/Alaska Natives (26.1%), non-Hispanic whites (19.4%), non-Hispanic blacks (18.3%), Hispanics (12.1%), and Asians (9.6%) Smoking prevalence also varies by education and income levels. By education, the rate of cigarette smoking is highest among adults with a graduate education development certificate (41.4%) and lowest among those with a graduate (5.6%) or undergraduate (9.1%) degree. Rates are also highest among people living below the poverty level (29.2%) compared with those living at or above this level (16.2%).13

Rates of smoking are higher among adults with mental illness than among adults without mental illness.14,15 In 2011, approximately 27.0 percent of individuals with a mental health disorder or substance use disorder were current smokers.14 Among those with mental illness, the prevalence of smoking varies by specific diagnoses. In 2007, current smoking prevalence was highest for persons with schizophrenia (59.1%) and lowest for persons self-reporting phobias or fears (34.3%).16 Approximately 46.4% of persons with bipolar disorder, 38.1% of persons with serious psychological distress, 37.2% of persons with attention deficit disorder or hyperactivity, and 35.4% of persons with dementia were current smokers.16 The average number of cigarettes smoked in the past month was also higher among adults with any mental illness in the past year than among those who did not have any mental illness (331 versus 310 cigarettes).17

Among pregnant women aged 15 to 44 years, one in six smoked cigarettes during the previous month. The prevalence of current cigarette use was lower among pregnant women (15.9%) than women who were not pregnant (24.6%) (Figure 1). This pattern was also observed among women aged 18 to 25 years (20.9% versus 28.2% for pregnant and non-pregnant women, respectively) and among women aged 26 to 44 years (12.5% versus 25.2%, respectively).18

Figure 1 Past Month Cigarette Use Among Women Ages 15 to 44 Years, by Pregnancy Status: Combined Years 2002–2003 to 2011–2012

+ Difference between this estimate and the 2011-2012 estimate is statistically significant at the .05 level.

Source: 2012 National Survey on Drug Use and Health

Figure 1 is a line graph that displays cigarette use in the past month among women aged 15 to 44 years by pregnancy status from 2002-2003 to 2011-2012.

## Etiology and Natural History

Initiation of smoking typically begins in early adolescence at the average age of 15.4 years.8 Data suggest that smoking prevalence in adolescents increases over time, peaks during young adulthood, and then declines as individuals age. This trajectory may vary, however, given differences in age at initiation of smoking, time to progress to daily smoking, and dependence symptoms. About one-third of individuals who have ever tried smoking become daily smokers.8

Tobacco dependence is a chronic condition and the majority of users make multiple quit attempts before achieving lasting success.3 According to the National Health Interview Survey, 68.9 percent of current adult daily smokers reported they were interested in quitting smoking and 42.7 percent made a quit attempt during the past year.10 An estimated 6.2 percent of current adult smokers had recently quit, 48.3 percent had been advised by a health care professional to quit smoking, and 31.7 percent had used medications and/or counseling when they made their quit attempt.19 About 95 percent of people who try to stop smoking without a pharmacologic aid will continue to smoke or relapse within 1 year of the quit attempt.8

Research shows that the appearance of withdrawal symptoms early during the quit attempt is negatively associated with the ability to remain abstinent and avoid relapse.8 On average, a second lapse occurs with 24 hours of the first lapse, and lapse to relapse occurs 3 to 5 weeks after the cessation attempt.8 Factors influencing the path to relapse include past experiences with nicotine, confidence in the ability to quit smoking, severity of tobacco dependence, educational status, and situational indicators (e.g., partner smoking status, cigarette availability).8

## Effect of Tobacco Cessation on Health Outcomes

The ultimate basis for recommending any preventive intervention is evidence that it would result in reduced morbidity and mortality. Such evidence is often missing or limited from intervention studies and intermediate outcomes must be used. This review focuses on smoking cessation as the main outcome as there is a substantial body of research indicating that smoking cessation results in important health benefits. These findings are summarized in this section.

Tobacco smoking increases mortality two- to three-fold.20,21 Observational studies show that ex-smokers experience a gradual fall in this excess mortality (mortality can be increased in short-term quitters (< 5 years) because developing a smoking-related disease increases smoking cessation).20 Quitting smoking before age 35 is associated with a mortality rate similar to that of never smokers.21 While this benefit is decreased for older smokers who quit, it remains substantial. Jha and colleagues, for example, found that smokers who quit after age 50 still reduce their excess mortality risk by two-thirds.21 Likewise, in a meta-analysis of 17 studies of smokers over age 60, Gellert and colleagues also found substantial mortality benefit at all ages, including 80 and over, and increasing benefit with longer duration of abstinence.22

Causal inference from these observational data are supported by the Lung Health Study, which was a randomized controlled trial of an intensive smoking cessation intervention in patients with mild to moderate chronic obstructive pulmonary disease (COPD) compared with usual care (N=5,887).23 The smoking cessation rate at 5 years in this study was 21.7 percent in the intervention group and 5.4 percent in usual care. After 14.5 years of followup the all-cause mortality rate was significantly lower in the intervention group (8.8 versus 10.4 per 1,000 person-years, p = 0.03). This difference would likely have been greater if more smokers in the intervention group had quit (49% never quit). The results of one other long-term followup study are also consistent with a causal effect of smoking cessation on mortality and morbidity. Rose and colleagues conducted a randomized controlled trial of physician smoking cessation advice in 1,445 high-risk men.24 At 1 year, 51 percent of the intervention group reported not smoking compared with 10 percent in the control group. After 20 years, the rates of death, fatal coronary heart disease (CHD), and lung cancer all favored the intervention group, although none achieved statistical significance. For example, the all-cause mortality rate ratio in the intervention group compared with control was 0.93 (95% confidence interval [CI], 0.80 to1.09).25 As with the Lung Health Study, these differences would likely have been larger if more men in the intervention group had quit; in addition, the smoking rate steadily declined in the control group over the first 10 years of followup, narrowing the intervention effect.

Tobacco smoking is a definitive risk factor for lung cancer with men who smoke having a 22-fold increased risk, and women who smoke having a 12-fold increased risk of acquiring the disease.20 Smoking cessation, however, can greatly reduce this risk. Ten years after quitting, for example, the risk of developing lung cancer falls by half to two-thirds.20 The most common smoking-related disease is CHD and here the benefit of quitting accumulates more rapidly, with a 50 percent decrease after 1 year and a return to nearly the same rate as never-smokers after 15 years.20 Stroke risk also decreases after quitting, as evidenced by Kawachi and colleagues' findings in women that excess risks among former smokers largely disappeared from 2 to 4 years after quitting.26 Likewise, Wannamethee and colleagues observed a halving of the risk of stroke after quitting tobacco use in men, although the risk remained marginally elevated, compared with never smokers.27 Cessation is also associated with improvements in depression, anxiety, stress, psychological quality of life, and positive affect compared with continuing to smoke.28 The effect is equal or larger among those with mental health disorders compared with those without.28

Smoking during pregnancy retards fetal growth by about 200 grams, doubles the risk of delivering a low birth weight baby, and increases fetal death by 25 to 50 percent.20 Quitting smoking before or during the first 3 to 4 months of pregnancy eliminates this excess risk attributable to smoking.20

While almost all of the data linking smoking cessation to improved morbidity and mortality are observational, the breadth and consistency of the evidence over some 6 decades provides strong assurance that to the extent that counseling and treatment in primary care are effective in producing smoking cessation they will produce improved morbidity and mortality at a magnitude exceeding that of almost any other medical therapy.

## Tobacco Cessation Interventions

Various pharmacological and behavioral methods designed to assist adults and pregnant women stop smoking are available. Behavioral interventions and pharmacotherapy are believed to have complementary modes of action and independently improve the chances of maintaining long-term abstinence.3

### Pharmacotherapy Tobacco Cessation Interventions

Seven U.S. Food and Drug Administration (FDA)-approved over-the-counter (OTC) and prescription medications for treating tobacco dependence are now available.29 These include three OTC nicotine replacement products (transdermal nicotine patches, nicotine lozenges, and nicotine gum), two prescription-only nicotine replacement products (nicotine inhaler or nasal spray [Nicotrol®]); and prescription-only bupropion hydrochloride sustained release (Zyban® or generic) (bupropion SR, hereafter) and varenicline tartrate (Chantix®) – that do not contain nicotine. Although Wellbutrin SR® is not indicated for smoking cessation treatment, it contains the same active ingredient as Zyban®. These individual medications can also be used in combination in an attempt to improve quit rates. Recent changes by the FDA allow labeling statements for OTC NRT products to be modified whereby deleting the warning that states that users should “not use the NRT product if they continue to smoke, chew tobacco, use snuff, or use [a different NRT product] or other nicotine containing product”.30 Manufacturers of OTC NRT products have been encouraged to submit labeling supplements to the FDA to reflect this change.30 Other medications are used clinically to treat tobacco dependence, including clonidine (antihypertensive) and nortriptyline (antidepressant), but these are not FDA approved for smoking cessation.29,31

### Behavioral Tobacco Cessation Interventions

Specific behavioral interventions include, but are not limited to: self-help materials (e.g., written materials, videos, audiotapes, computer), phone-based interventions, quitlines, brief provider-delivered interventions (e.g., advice from a physician or nurse), intensive counseling delivered on an individual basis or in a group including motivational interviewing, mobile phone and text messaging interventions, biomedical risk assessment, and combinations of these approaches. These interventions teach individuals to recognize high-risk situations and develop coping strategies to deal with them. Complementary and alternative therapies, such as acupuncture, acupressure, laser therapy, electrostimulation, hypnotherapy, and the consumption of herbals (e.g., St. John's Wort) have also been used as tobacco cessation aids alone or as adjuncts to other treatments.

### Electronic Nicotine Delivery Systems

ENDS, including e-cigarettes, are battery-powered devices that contain a cartridge filled with nicotine and other additives. Over 400 e-cigarette brands exist with a wide range of designs.32 Most ENDS aim to simulate the visual, sensory, and behavioral aspects of smoking tobacco cigarettes.33 Common e-cigarette components include an electronic heating element, a battery, and a cartridge that houses a liquid solution (i.e., e-liquid, juice) of propylene glycol and/or glycerol (glycerin), with various levels of nicotine (including no nicotine).34 Other components of the solution include water, ethanol, and various additives that vary in presence and amount between brands.34 E-cigarettes are available in disposable or rechargeable versions. While disposable versions must be discarded after the liquid is gone, rechargeable versions, including those with “tank systems,” may be used indefinitely because the battery can be recharged with a computer USB port or wall outlet. In this case, the user replaces the cartridge as often as they would like. Cartridges are available in a broad range of flavors (e.g., tobacco, strawberry, chocolate) and are usually labeled with their nicotine content. Depending on the brand, each cartridge is designed to produce about 250-400 puffs, which is equivalent to 1-2 packs of tobacco cigarettes. Because e-cigarettes are developed by a variety of manufacturers, the contents vary widely and in some cases are not consistent with product labeling.34-37

Currently, only ENDS that are promoted for therapeutic purposes (i.e., for cessation use) are regulated by the FDA.38 Companies who wish to make such claims must apply to the FDA's Center for Drug Evaluation and Research. To date, we are aware of no manufacturers that have submitted approval packages for this purpose. On April 24, 2014, the FDA announced that it would enact rules to extend its authority to cover ENDS, deeming them to be subject to regulation as tobacco products.39 Under the proposed rules, which were open for public comment through August 8, 2014, manufacturers would be required to disclose their products' ingredients, report harmful and potentially harmful components, and all regulated products would have to carry health warnings. Any claims that the products had lower health risks or other health benefits could be made only after FDA review and approval. In addition, sale of electronic cigarettes to anyone under age 18 years would be prohibited. The proposed rules would not ban advertising or internet sales of the products, nor the use of flavoring, all of which are believed to attract young nonsmokers. As of present, the proposed rules have not been enacted; we presume that public comments are under review by the FDA.40

Awareness and current use of ENDS have increased over recent years among current and former smokers as well as never smokers. In the United States, awareness of e-cigarettes among adults increased from 40.9 percent in 2010 to 79.7 percent in 2013, concurrent with a rise in current use (1.3% to 1.9% from 2010 and 2011 to 2012 and 2013, p < 0.05).41,42 The use of e-cigarettes was particularly prevalent among current cigarette smokers, with over one-third (36.5%) reporting they had ever used e-cigarettes and 9.4 percent concurrently using e-cigarettes and conventional cigarettes in 2013. This compares with only 9.6 percent and 1.3 percent of former smokers who reported ever and current use of e-cigarettes, respectively.41 Results of the International Tobacco Control Four-Country Survey found that current use of e-cigarettes did not differ among adults in the United States, Canada, the United Kingdom, or Australia. While e-cigarette use did not vary, awareness was significantly different across countries, with adults in the United States reporting the highest awareness (73.4%).43 One study found that smokers with mental health conditions are more likely to have tried e-cigarettes (14.8%) and to be current users of e-cigarettes (3.1%) than those without mental health conditions (6.6% and 1.0%, respectively).44

The rapid increase in the advertising, sales, and use of ENDS has evoked a vigorous debate in the tobacco control community about the public health impact of ENDS, how to best regulate them, and their role in tobacco cessation.45-60 Proponents of ENDS argue that because e-cigarettes offer both nicotine replacement and behavioral and sensory aspects similar to conventional cigarettes without the inhalation of tobacco smoke, they represent an ideal candidate as a cessation or harm reduction tool.61-63 Significant questions remain, however, regarding ENDS' impact on individual and population health, including concerns related to the initiation of nicotine addiction in adolescents, the potential for progression to conventional tobacco use among non-tobacco users, long-term dual use among current smokers, relapse among former smokers, and the inclusion of harmful or potentially harmful ingredients.10,59,64-66 In addition, nicotine exposure can have adverse effects on reproductive health and adolescent brain development.10

## Current Clinical Practice in the United States

Primary care clinicians are in the unique position of having recurring opportunities to address smoking cessation efforts with their patients who smoke. Studies have shown that approximately 70 percent of smokers see a physician annually, which provides an ideal chance to discuss health behaviors and potential interventions.67,68 Despite USPSTF recommendations that clinicians identify, counsel, and treat smokers, reported data suggest that physicians do not consistently adhere to this recommendation.

In 2012, the Centers for Disease Control and Prevention (CDC) reported the findings of an audit of the National Ambulatory Medical Care Survey and the National Health Interview Survey through 2005-2009. This audit sought to evaluate the progress made towards meeting the Healthy People 2020 objectives related to tobacco use screening and counseling among adults.68 The CDC reported that during this 3-year period, current tobacco users made 340 million visits (17.6% of total visits) to office-based physicians. During these visits, only 20.9 percent reported receiving tobacco counseling from their provider and 7.6 percent reported receiving a prescription medication for treating tobacco dependence. Close to half-a-billion visits (62.7% of all visits) were found to include tobacco screening.

The rates of counseling and treatment were found to vary depending on patients' age, race, insurance status, physician status, and physician specialty. Overall, patients classified as non-Hispanic whites were more likely to receive counseling than Hispanic patients (64.1 versus 57.8%). Among current tobacco users, younger patients (aged 25 to 44 years) reported receiving less counseling (17.9%) than patients aged 45 to 64 years (22.7%).68 This is unfortunate because younger patients have more failed quit attempts than older patients and, additionally, quitting prior to the age of 50 substantially decreases smoking-related health outcomes.68,69 Patients with workers' compensation, and those whose insurance status was unknown were less likely to receive counseling than those with private insurance, self-payers, Medicaid, and Medicare patients. Patients were more likely to receive counseling from their primary care physician (26.9%) than from other health care providers (15.5%) and internal medicine and cardiovascular disease physicians were more likely to provide tobacco cessation counseling (32.5% and 35.4%) than family or obstetrics/gynecology physicians (23.5 and 19.7%). Psychiatrists ordered tobacco cessation prescriptions more than any other specialty (17.7%).68

Other published studies have reported similar rates of tobacco cessation interventions by physicians. A 2005 audit of electronic medical records of 522 Boston-area smokers, for example, found that 62 percent were asked about their smoking status by their physician, 27 percent were advised to quit, and only 20 percent received any assistance in quitting (including counseling or referral to support programs).70 A 2007 random sample telephone survey of Medicaid-enrolled smokers and recent quitters (n=563) found that 87 percent were asked about their smoking status, 65 percent were advised to quit, and only 24 percent received assistance with quitting.71 These findings are analogous to the rates provided in a recent systematic review of tobacco cessation interventions, which reported that 40 to 70 percent of smokers recounted receiving cessation advice and less than 20 percent received assistance with quitting.72 Barriers to providing tobacco-related interventions reported by physicians include a lack of counseling skills, knowledge, motivation, and time, as well as insufficient reimbursement, patient motivation, and system support.73-75

There are limited data available on the screening or counseling practices related to ENDS among primary care clinicians. The first study to measure physicians' attitudes towards the use of e-cigarettes as cessation devices was conducted in 2013 among a sample of 787 North Carolina physicians (response rate=31%). The study found that two thirds of the physicians indicated that e-cigarettes are a helpful aid for smoking cessation and 35 percent recommended them to their patients.76 Almost 65 percent of the physicians believed that e-cigarettes lower the risk of cancer for patients who use them instead of smoking cigarettes, and 13 percent incorrectly believed that e-cigarettes have been approved by the FDA for smoking cessation.76 A 2012 survey of members of the American College of Obstetricians and Gynecologists (ACOG) found that 53 percent of respondents reported screening pregnant women for chewing tobacco, snuff/snus, e-cigarettes, and dissolvables all or some of the time. While approximately 14 percent of those surveyed reported that e-cigarettes have no adverse health effects, only 5 percent felt fully informed on the safety of these products.77

## Recommendations of Others

The 2009 USPSTF recommendation and 2008 PHS Guideline are endorsed by, or are generally consistent with the recommendations of other national and international organizations, including those from the American Medical Association, the American Dental Association, the American Nurses Association, ACOG, and the Institute of Medicine. In addition, the Community Preventive Services Task Force recommends worksite-based incentives and competitions when these efforts are combined with other individual support interventions, increasing the unit price of tobacco products, mass-reach health communication interventions, quitline interventions, and smoke-free policies to encourage tobacco cessation among adults.78

The World Health Organization recently released recommendations for the prevention of tobacco use during pregnancy in 2013.^12^ The recommendations were based on a review of reviews, and ratings of the quality of the evidence. A strong recommendation for advice and psychosocial interventions for pregnant women who are smokers was given. The panel recommended against the use of bupropion or varenicline for smoking cessation based on very low quality evidence, but could not make a recommendation for or against NRT use during pregnancy. Accordingly, a strong recommendation for further research on pharmacotherapy for smoking cessation during pregnancy was made.

## Previous USPSTF Recommendations

In 2003, the USPSTF reviewed the evidence for tobacco cessation interventions in adults and pregnant women contained in the 2000 U.S. Public Health Service (PHS) clinical practice guideline “Treating Tobacco Use and Dependence”2 and found that the benefits of these interventions substantially outweighed the harms. In 2008, the USPSTF reviewed new evidence in the updated PHS guideline3 and determined that the net benefits of screening and tobacco cessation interventions in adults and pregnant women remain well established. The USPSTF found no new substantial evidence that could change its conclusions and, therefore, reaffirmed its previous recommendations.

Thus, in 2003 and 2009, the USPSTF recommended: 1) that clinicians ask all adults about tobacco use and provide tobacco cessation interventions for those who use tobacco products (A recommendation) and 2) that clinicians ask all pregnant women about tobacco and provide augmented, pregnancy-tailored counseling for those who smoke (A recommendation).1 The clinical summary of the 2009 USPSTF recommendations can be found in Appendix A.