# Ongoing Studies

Appendix G Table 1 Ongoing or Recently Completed Studies: Pharmacotherapy in Pregnant Women

Study, Year Initiated CT Identifier | Design | Aim | Location | Number of participants | Intervention description | Relevant outcomes | Current status
El-Mohandes, 2006 NCT00341432 | RCT | To compare the effectiveness of counseling plus use of a nicotine patch with counseling alone for helping pregnant women quit smoking | United States | Estimated enrollment: 300 | Counseling plus the nicotine patch vs. counseling alone | Smoking abstinence | Completed April 2011
GlaxoSmithKline, 2012 NCT01597661 | Retrospective case control | To investigate the link between exposure to buproprion in the 1^st^ trimester and resulting cardiac birth defects using data from the Slone Epidemiology Center Birth Defects Study. | United States | Estimated enrollment: NR | Exposure to buproprion during the 1^st^ trimester vs. no exposure | Cardiac birth defects | Completed August 2012
Koren, 2008 NCT00744913 | RCT | To assess the effectiveness of NRT plus counselling treatment in aiding smoking cessation among pregnant women. | United States | Estimated enrollment: NR | Nicoderm patch (14 mg/day or 21 mg/day) plus counseling vs. counseling alone. | Smoking abstinence | Withdrawn
Myers, 2003 NCT00224419 | RCT | to evaluate the effectiveness of providing over-the-counter NRT, choice of gum, lozenge or patch to promote prepartum smoking cessation. | United States | Estimated enrollment: 181 | Cognitive behavioral counseling plus NRT (patch [14 or 21 mg], lozenge [2 mg], or gum [2 mg]) vs. counseling alone. | Smoking abstinence | Terminated
Nanovskaya, 2011 NCT01390246 | RCT | To evaluate the preliminary safety and efficacy of bupropion in combination with behavioral counseling for smoking cessation during pregnancy. | United States | Estimated enrollment: 150 | Bupropion (150 mg twice a day) for 12 weeks plus behavioral counseling (35 min counseling sessions at each of the first 2 visits and 10 minutes at subsequent visits) vs. placebo plus the same behavioral counseling schedule | Smoking abstinence; adverse effects; perinatal/neonatal outcomes | Recruiting Estimated completion: April 2015
Oncken, 2002 NCT00115687 | RCT | To evaluate the safety and effectiveness of 2 mg nicotine gum in promoting smoking cessation during pregnancy | United States | Estimated enrollment: 250 | Nicotine gum (2 mg) vs. placebo | Smoking abstinence; adverse effects; perinatal/neonatal outcomes | Terminated
Oncken, 2010 NCT01656733 | RCT | To evaluate the effectiveness of the nicotine inhaler in combination with counseling in helping pregnant women quit smoking. | United States | Estimated enrollment: 360 | Nicotrol Inhaler (1-12 cartridges per day), for 6 weeks plus behavioral counseling vs. a placebo inhaler plus behavioral counseling. | Smoking abstinence; adverse effects; perinatal/neonatal outcomes | Recruiting Estimated completion: November 2015
Placebo-controlled Trial of Bupropion for Smoking Cessation in Pregnant Women (BIBS), 2014 NCT02188459 | RCT | To evaluate the efficacy of bupropion in assisting pregnant smokers to quit smoking. | United States | Estimated enrollment: 360 | Bupropion (300 mg/day) vs. placebo | Smoking abstinence; adverse effects; perinatal/neonatal outcomes | Not yet recruiting Estimated completion: January 2020
Study of Nicotine Patch in Pregnancy (SNIPP), 2007 NCT00507975 | RCT | To assess the effectiveness of the nicotine patch comparatively to a placebo patch in pregnant women on birth weight and maternal smoking abstinence. | France | Estimated enrollment: 404 | Nicotine patch (dose NR) vs. placebo | Smoking abstinence; adverse effects; perinatal/neonatal outcomes | Completed November 2012
Stotts, 2011 NCT01286402 | RCT | To gather preliminary effectiveness and safety data on the use of bupropion for smoking cessation in pregnant women attending a community prenatal clinic. | United States | Estimated enrollment: 50 | Buproprion (150 mg/day for the 1st 3 days; 300 mg/day for the remainder of the 8 weeks) vs. placebo | Smoking abstinence; adverse effects; perinatal/neonatal outcomes | Ongoing, not recruiting Estimated completion: April 2014
Varenicline Pregnancy Cohort Study, 2007 NCT01290445 | Prospective cohort | To examine whether varenicline use during pregnancy is associated with an increased risk of major congenital malformations in infants above that associated with smoking during pregnancy. | Denmark and Sweden | Estimated enrollment: 904,585 | Infants exposed in utero to varenicline vs. infants exposed to cigarette smoke in utero vs. infants not exposed to varenicline or cigarette smoke in utero | Prevalence of major congenital malformation, prevalence of other perinatal/neonatal outcomes | Enrolling by invitation

Appendix G Table 2 Ongoing or Recently Completed Studies: Electronic Nicotine Delivery Systems (ENDS)

Study, Year initiated | Identifier Principal Investigator | Design | Aim | Location | Number of participants | Intervention description | Relevant outcomes | Current status
High Cessation Rates in Smokers Using Personal Vaporizers (VAPECIG) | NCT02124200 (ClinicalTrials.gov) Riccardo Polosa (University degli Studi di Catania) | Prospective 6-month pilot study | To evaluate changes in smoking habits of regular smokers unwilling to quit who were asked to switch to a second generation device focusing on smoking reduction and smoking abstinence | Italy | Estimated enrollment: 40 | Electronic cigarette (eGo CE4 9 mg nicotine) | Sustained 50% reduction in the number of cigarette/day at week 24 from baseline; sustained 80% reduction in the number of cigarettes/day and sustained smoking abstinence at week 24 | Study start date: January 2013 Estimated study completion date: November 2013 Last verification: June 2014
Smoking Cessation in Women with Gynecological Conditions | NCT01989923 (ClinicalTrials.gov) Laura A Beebe, PhD (University of Oklahoma) | RCT | To compare two smoking cessation methods: traditional NRT and ENDS in patients with gynecological conditions (i.e., cervical dysplasia, cervical cancer, and lower genital tract dysplasia and cancer) | United States | Estimated enrollment: 30 | 1. NRT: 24-hour nicotine patches (either 21 mg or 14 mg patches); 2. Electronic cigarette: One “blu cig”; number of cartridges determined by asking each patient the number of packs currently smoked per day and multiplying 1.5 times the number of packs smoked per day | Reduction of number of cigarettes smoked per day; point prevalence abstinence at 7 and 30 days; smoking abstinence rates | Study start date: June 2013 Estimated study completion date: March 2014 Last verification: November 2013
Electronic Cigarettes or Nicotine Inhaler for Smoking Cessation | NCT02004171 (ClinicalTrials.gov) Barney Vaughan, MD (New York State Psychiatric Institute/Columbia University) | RCT | To evaluate the effectiveness of electronic cigarettes in smokers who are trying to quit smoking compared with a standard therapy, the nicotine inhaler | United States | Estimated enrollment: 40 | 1. Experimental: Electronic cigarette; 24 mg cartridge; 1-2 cartridges daily; 2. Active comparator: Nicotine inhaler; 10 mg cartridge; max 16 cartridges daily | Number of cigarettes smoked over 24 hours; adverse effects | Study start date: December 2013 Estimated study completion date: June 2014 Last verification: December 2013
A Randomized, Parallel Group, Multi-Center Study to Evaluate the Safety Profile of the ITG e-Vapor Product (EVP) G1 Product | NCT02029196 (ClinicalTrials.gov) Jim Bush, MD (Covance Clinical Research Unit, UK) | RCT | To evaluate the safety and tolerability of an e-vapor product | United Kingdom | Estimated enrollment: 420 | 1. Experimental: e-vapor product (EVP); 2. Active comparator: Conventional cigarette | Clinical measures (i.e., vital signs, electrocardiogram, lung function testing, and other clinical laboratory parameters) | Study start date: December 2013 Estimated study completion date: June 2014 Last verification: January 2014
Spain-UK-Czech E-cigarette Study (SUKCES) | NCT01842828 (ClinicalTrials.gov) Peter Hajek, PhD (Queen Mary University of London) | RCT | To test the effect of adding electronic cigarettes to standard care on long-term validated outcomes | London, Madrid, Prague | Estimated enrollment: 350 | 1. Standard care; 2. Active comparator: Standard care plus electronic cigarettes | Carbon monoxide-validated abstinence rates at 24 weeks post-TQD | Study start date: December 2013 Estimated study completion date: June 2015 Last verification: March 2014
Antismoking Effects of Electronic Cigarettes in Subjects with Schizophrenia and Their Potential Influence on Cognitive Functioning (SCARIS) | NCT01979796 (ClinicalTrials.gov) Eugenio Aguglia Pasquale Caponnetto Giuseppe Minutolo Riccardo Polosa (University degli Studi di Catania) | RCT | To evaluate the effects of electronic cigarettes in smokers with schizophrenia | Italy | Estimated enrollment: 153 | 1. Experimental: Electronic cigarette 24 mg nicotine; 2. Sham comparator: Electronic cigarette 0 mg nicotine; 3. Placebo comparator: Nicotine free inhalator | Smoking abstinence rates | Study start date: September 2014 Estimated study completion date: September 2015 Last verification: November 2013
Smoking Cessation and Reduction in Depression (SCARID) | NCT02124187 (ClinicalTrials.gov) Eugenio Aguglia Pasquale Caponnetto Giuseppe Minutolo Maria Salvina Signorelli Riccardo Polosa (University degli Studi di Catania) | RCT | To investigate the efficacy and safety of electronic cigarettes in depressed smokers not intending to quit | Italy | Estimated enrollment: 129 | 1. Experimental: Electronic cigarette 24 mg nicotine for 12 weeks; 2. Sham comparator: Electronic cigarette 0 mg nicotine for 12 weeks; 3. Placebo comparator: Nicotine free inhalator for 12 weeks | Smoking abstinence rates | Study start date: February 2015 Estimated study completion date: February 2016 Last verification: April 2014
A Multi-Center Study to Evaluate the Safety of Use of Electronic Vapor Products (EVP) for Two Years | NCT02143310 (ClinicalTrials.gov) Jim Bush, MD (Covance Clinical Research Unit, UK) | Interventional study with single group assignment | To evaluate the safety and tolerability of an e-vapor product over two years | United Kingdom | Estimated enrollment: 420 | 1. Experimental: e-vapor product (EVP) | Changes from baseline clinical measures (i.e., vital signs, electrocardiogram, lung function testing, and other clinical laboratory parameters) | Study start date: May 2014 Estimated study completion date: May 2016 Last verification: May 2014
The Efficacy and Safety of Electronic Cigarettes: a 5-year Follow-up Study | NCT01785537 (ClinicalTrials.gov) Lamberto Manzoli, MD, MPH (University of Chieti) | Prospective cohort | To evaluate the long-term efficacy and safety (in terms of smoking-related serious diseases requiring hospitalization) of e-cigarette smoking, comparing its health effect s with those of traditional cigarette smoking and mixed electronic and traditional cigarette smoking | Italy | Estimated enrollment: 1050 | 1. Traditional cigarette smokers only; 2. Electronic cigarette users only; 3. Mixed | Smoking abstinence rates; change from baseline in the number of traditional cigarettes smoked; change in the average self-reported number of traditional cigarettes smoked per day | Study start date: October 2013 Estimated study completion date: December 2018 Last verification: November 2013
Can using nicotine as a long-term substitute enhance smoking cessation over using it only as a cessation aid? | ACTRN 12612001210864 (Australian New Zealand Clinical Trials Registry) Coral Gartner (The University of Queensland) | RCT | To examine the effectiveness of short-term use of NRT vs. short- or long-term use of NRT vs. short- or long-term use of NRT or ENDS for smoking cessation in cigarette smokers | Australia | Estimated enrollment: 1600 | Combination of varying levels of self-help materials, NRT, advice, or electronic nicotine delivery systems | Continuous abstinence measures; 7-day point prevalence abstinence measures | Not yet recruiting

Appendix G Table 3 Ongoing Systematic Reviews

Study, Year initiated | Study designs included | Follow-up | Population | Intervention | Comparator | Relevant outcomes | Current status
Eisenberg, 2013 PROSPERO CRD42014007105 | RCTs | 12 months | Adult smokers | At least one first-line smoking cessation therapy (varenicline, bupropion, NRT, or behavioral therapy). | Placebo or at least one other first-line smoking cessation therapy | Smoking cessation; adverse events | Ongoing Estimated completion date: October 2015
Kelly, 2013 PROSPERO CRD42013004803 | RCTs, SERs | ≥ 6 months | Smokers of any age or sex either in the general populations or in more specific populations [co morbidities; mental illness; CVD; COPD; diabetes; pregnant women; and heavy smokers] | buproprion, varenicline, nicotine replacement therapies combined with behavioral support programs. | Placebo, no therapy or standard care, monotherapy or head-to-head of included interventions stated. | Smoking cessation; adverse events | Ongoing Estimated completion date: September 2013
Khanna, 2012 Cochrane protocol | RCTs | NR | Adult smokers with schizophrenia or related disorders | Physician advice | Usual care | Smoking cessation, quality of life, adverse events | Protocol published 2012 Estimated completion date: NR
Moffatt, 2014 PROSPERO CRD42014010128 | RCTs or secondary analyses from RCTs of smoking cessation interventions | NR | Adult smokers aged ≥65, or a broader age-range of participants if sub-analyses were provided for smokers aged ≥65 | Any patient-level smoking cessation strategies alone or in combination with other strategies | Usual care or placebo | Smoking cessation | Ongoing Estimated completion date: September 2014
Thomas, 2013 PROSPERO CRD42014009224 | RCTs | NR | Adults prescribed varenicline | Varenicline (1 mg twice a day) | Placebo | Neuropsychiatric adverse events (suicide [fatal self-harm], nonfatal self- harm [parasuicide and attempted suicide], suicidal ideation and depression) | Ongoing Estimated completion date: August 2014