# Forest Plots

Appendix F Figure 1 Any Type of NRT vs. Placebo/No NRT Control: Smoking Abstinence at 6+ Months Followup (Stead, 2012a)140

Source: Stead LF. Nicotine replacement therapy for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2012;(11). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 1 displays a forest plot of the risk ratios for smoking abstinence at 6+ months follow up among studies comparing any type of NRT versus placebo/no NRT control.

Appendix F Figure 2 Combinations of Different Types of NRT vs. Single Type: Smoking Abstinence at 6+ Months Followup (Stead, 2012a)140

Appendix F Figure 2 displays a forest plot of the risk ratios for smoking abstinence at 6+ months follow up among studies comparing combinations of different types of NRT versus single type.

Appendix F Figure 3 Bupropion vs. Placebo/Control: Smoking Abstinence at 6+ Months Followup (Hughes, 2014)121

Source: Hughes JR. Antidepressants for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2014;(1). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 3 displays a forest plot of the risk ratios for smoking abstinence at 6+ months follow up among studies comparing bupropion versus placebo/control.

Appendix F Figure 4 Varenicline vs. Placebo: Continuous Abstinence at Longest Followup (Cahill, 2012)154

Source: Cahill K. Nicotine receptor partial agonists for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2012;(4). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 4 displays a forest plot of the risk ratios for continuous abstinence at longest follow up among studies comparing varenicline versus placebo.

Appendix F Figure 5 Combined Intervention vs. Control: Smoking Abstinence at Longest Followup (Stead 2012b)138

Source: Stead LF. Combined pharmacotherapy and behavioral interventions for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2012;(12). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 5 displays a forest plot of the risk ratios for smoking abstinence at longest follow up among studies comparing combined interventions versus control.

Appendix F Figure 6 Effect of Increasing Behavioral Support: Smoking Abstinence at Longest Followup (Stead, 2013a)142

Source: Stead LF. Behavioral interventions as adjuncts to pharmacotherapy for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2013;(3). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 6 displays a forest plot of the risk ratios for smoking abstinence at longest follow up among studies evaluating the effectiveness of increasing behavioral support.

Appendix F Figure 7 Effect of Advice vs. Control (by Intensity): Smoking Abstinence at Longest Followup (Stead, 2013b)139

Source: Stead LF. Physician advice for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2013;(5). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 7 displays a forest plot of the risk ratios for smoking abstinence at longest follow up among studies evaluating the effectiveness of advice versus control, by intensity.

Appendix F Figure 8 Nursing Interventions vs. Control (by Intensity of Intervention): Smoking Abstinence at Longest Followup (Rice, 2013)136

Source: Rice VH. Nursing interventions for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2013;(8). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 8 displays a forest plot of the risk ratios for smoking abstinence at longest follow up among studies comparing nursing interventions versus control.

Appendix F Figure 9 Interventions for Callers to Quitlines^*^ * Pooled results based on fixed vs. random effects model. : Smoking Abstinence at Longest Followup (Stead 2013c)141

Source: Stead LF. Telephone counseling for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2013;(8). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 9 displays a forest plot of the risk ratios for smoking abstinence at longest follow up among studies evaluating interventions for callers to quitlines.

Appendix F Figure 10 Interventions for Smokers Not Calling Quitlines (by Baseline Support): Smoking Abstinence at Longest Followup (Stead 2013c)141

Source: Stead LF. Telephone counseling for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2013;(8). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 10 displays a forest plot of the risk ratios for smoking abstinence at longest follow up among studies evaluating interventions for smokers not calling quitlines, by baseline support.

Appendix F Figure 11 Internet-Based Interventions (by Type of Intervention and Control): Smoking Abstinence at Longest Followup (Civljak, 2013)113

Source: Civljak M. Internet-based interventions for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2013;(7). . Permission to reprint this figure granted by John Wiley and Sons

Appendix F Figure 11 displays a forest plot of the risk ratios for smoking abstinence at longest follow up among studies evaluating internet-based interventions, by type of intervention and control.

Appendix F Figure 12 Smoking Cessation for All Intervention Comparisons (Bize 2012)102

Source: Bize R. Biomedical risk assessment as an aid for smoking cessation. (Review). Cochrane Database of Systematic Reviews. 2012;(12). . Permission to reprint this figure granted by John Wiley and Sons.

Appendix F Figure 12 displays a forest plot of the risk ratios for studies evaluating smoking cessation for all intervention comparisons.

Appendix F Figure 13 NRT Interventions for Smoking Cessation During Pregnancy, Preterm Birth at <37 Weeks (Coleman 2012 + Study Identified in Bridge Search)92,101

Appendix F Figure 13 displays a forest plot of the risk ratios for preterm birth less than 37 weeks gestation among studies evaluating NRT interventions for smoking cessation during pregnancy.

Appendix F Figure 14 NRT Interventions for Smoking Cessation During Pregnancy, Mean Birth Weight in Grams (Coleman 2012 + Study Identified in Bridge Search)92,101

Appendix F Figure 14 displays a forest plot of the difference in mean birth weight in grams among studies evaluating NRT interventions for smoking cessation during pregnancy.

Appendix F Figure 15 Behavioral Interventions for Smoking Cessation During Pregnancy, Mean Birth Weight in Grams (Chamberlain, 2013)110

Appendix F Figure 15 displays a forest plot of the difference in mean birth weight in grams among studies evaluating behavioral interventions for smoking cessation during pregnancy.

Appendix F Figure 16 Behavioral Interventions for Smoking Cessation During Pregnancy, Preterm Birth (<37 Weeks Gestation) (Chamberlain, 2013)110

Appendix F Figure 16 displays a forest plot of the risk ratios for preterm birth less than 37 weeks gestation among studies evaluating behavioral interventions for smoking cessation during pregnancy.

Appendix F Figure 17 Behavioral Interventions for Smoking Cessation During Pregnancy, Low Birth Weight (<2500 g) (Chamberlain, 2013)110

Appendix F Figure 17 displays a forest plot of the risk ratios for low birth weight less than 2500 grams among studies evaluating behavioral interventions for smoking cessation during pregnancy.

Appendix F Figure 18 Behavioral Interventions for Smoking Cessation During Pregnancy, Stillbirth (Chamberlain, 2013)110

Appendix F Figure 18 displays a forest plot of the risk ratios for stillbirth among studies evaluating behavioral interventions for smoking cessation during pregnancy.

Appendix F Figure 19 NRT Use in Pregnant Women, Validated Smoking Cessation in Later Pregnancy (Coleman 2012 + Study Identified in Bridge Search)92,101

Appendix F Figure 19 displays a forest plot of the risk ratios for validated smoking cessation in later pregnancy among studies of NRT use in pregnant women.

Appendix F Figure 20 Behavioral Interventions for Smoking Cessation During Pregnancy, Smoking Cessation in Late Pregnancy (Chamberlain, 2013)110

Appendix F Figure 20 displays a forest plot of the risk ratios for smoking cessation in late pregnancy among studies evaluating behavioral interventions for smoking cessation during pregnancy.