# Poor-Quality Existing Systematic Reviews

Review | Reasons for Poor Quality Rating
Ferron 2009 | - Dual study selection and dual data extraction not reported; - Number of studies screened and excluded not reported; - List of excluded studies not provided; - Quality assessment of individual studies not performed or documented; - Included single-group studies and calculated effect sizes based on post-measurements only; - Potential conflicts of interest/source(s) of support of the systematic review not reported
Hoedjes 2010 | - Inclusion criteria changed post hoc after no evidence was found related to the a priori study aims; - Literature search terms and supplemental searches not reported; - Dual study selection and dual data extraction not reported; - List of excluded studies not provided; - Quality assessment of individual studies not performed or documented; no discussion of limitations in the body of evidence in the discussion; - Intervention for this review was ill-defined with “lifestyle interventions” broadly considered across a range of topics for postpartum women
Kaur 2009 | - Dual study selection and dual data extraction not reported; - Supplemental searches not reported; - List of excluded studies not provided; - Quality assessment of individual studies not performed or documented; no discussion of limitations in the body of evidence in the discussion; - Potential conflicts of interest/source(s) of support of the included studies and systematic review not reported
Kimura 2009 | - Comprehensive literature search not performed (i.e., search dates not reported, only 1 search database; supplemental searches not reported); - Dual study selection and dual data extraction not reported; - List of excluded studies not provided; - Methods state, “The number of subjects in the selected literature markedly differed; we cannot simply review these data.” Not clear what implications this had on the results.; - Minimal detail provided on included studies; - Quality assessment of individual studies not performed or documented; no discussion of limitations in the body of evidence in the discussion; - Potential conflicts of interest/source(s) of support of the included studies and systematic review not reported
Mantler 2012 | - Literature search dates and search terms not reported; - Dual study selection and dual data extraction not reported; - Number of studies screened and excluded not reported; - List of excluded studies not provided; - Quality of individual studies assessed but overall quality and individual quality domains are not reported for each included study; - No discussion on lack of quantitative pooling; - Potential conflicts of interest/source(s) of support of the systematic review not reported
Mitchell 2009 | - Literature search terms not reported; - Dual study selection and dual data extraction not reported; - Number of studies screened and excluded not reported; - List of excluded studies not provided; - Limited description of included studies; - Quality of individual studies assessed but not documented or used appropriately in formulating conclusions; - Heterogeneity of studies not accounted for in meta-analysis; - Likelihood of publication bias not assessed; - Potential conflicts of interest/source(s) of support of the systematic review not reported
Okoli 2011 | - Aim is to evaluate the efficacy of interventions among men, but included studies did not emphasize sex as a key factor in design or delivery of interventions; - Dual study selection and dual data extraction not reported; - Number of studies screened and excluded not reported; - List of excluded studies not provided; - Quality assessment of individual studies not performed or documented; no discussion of limitations in the body of evidence in the discussion; - Potential conflicts of interest/source(s) of support of the included studies not reported
Sanderson 2011 | - Not all included studies addressed the primary research question (i.e., purpose was to review interventions among ethnic and minority smokers, yet required that only 10% of the sample were ethnic or minority participants); - List of a number of literature search databases but state that MEDLINE was the “primary” source of literature. Not clear how that impacted the results of the search process.; - Dual study selection not reported; - Number of studies screened and excluded not reported; - List of excluded studies not provided; - Quality assessment of individual studies not performed or documented; no discussion of limitations in the body of evidence in the discussion; - Potential conflicts of interest/source(s) of support of the included studies not reported